# References

1 Kaplan SA, Wein AJ, Staskin DR, et al. Urinary retention and post-void residual urine in men: separating truth from tradition. Journal of Urology. Jul. 2008;180(1):47-54. [pmid: 18485378].
2 Negro CLA, Muir GH. Chronic urinary retention in men: How we define it, and how does it affect treatment outcome. BJU international. 2012.
3 Selius BA, Subedi R. Urinary retention in adults: diagnosis and initial management. American Family Physician. Mar. 1. 2008;77(5):643-50. [pmid: 18350762].
4 Yoshimura N, Chancellor MB. Differential diagnosis and treatment of impaired bladder emptying. Reviews in urology. 2004;6(Suppl 1):S24. [pmid: 16985851].
5 DasGupta R, Fowler CJ. The management of female voiding dysfunction: Fowler's syndrome -- a contemporary update. Current Opinion in Urology. Jul. 2003;13(4):293-9. [pmid: 12811293].
6 Scottish Intercollegiate Guidelines Network. Search Filters. 2013. www.sign.ac.uk/methodology/filters.html. July 23 2013.
7 White C, Ip S, McPheeters M, et al. Using existing systematic reviews to replace de novo processes in conducting Comparative Effectiveness Reviews. Agency for Healthcare Research and Quality. Rockville, MD. 2009. http://effectivehealthcare.ahrq.gov/repFiles/methodsguide/systematicreviewsreplacedenovo.pdf.
8 Agency for Healthcare Research and Quality. Grading the strength of a body of evidence when assessing health care interventions--AHRQ and the effective health-care program: An Update Draft Report. Rockville, MD. June. 2012. http://effectivehealthcare.ahrq.gov/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=1163.
9 Atkins D, Chang S, Gartlehner G, et al. Assessing the Applicability of Studies When Comparing Medical Interventions. 2010. www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayProduct&productID=603#2412. Accessed on AHRQ Publication No. 11-EHC019-EF.
10 Datta SN, Kavia RB, Gonzales G, et al. Results of double-blind placebo-controlled crossover study of sildenafil citrate (Viagra) in women suffering from obstructed voiding or retention associated with the primary disorder of sphincter relaxation (Fowler's Syndrome). European Urology. Feb. 2007;51(2):489-95. discussion 95-7. [pmid: 16884844].
11 Tang MW, Kwok TC, Hui E, et al. Intermittent versus indwelling urinary catheterization in older female patients. Maturitas. Feb. 20. 2006;53(3):274-81. [pmid: 16084677].
12 Schelin S, Geertsen U, Walter S, et al. Feedback microwave thermotherapy versus TURP/prostate enucleation surgery in patients with benign prostatic hyperplasia and persistent urinary retention: a prospective, randomized, controlled, multicenter study. Urology. Oct. 2006;68(4):795-9. [pmid: 17070355].
13 Ghalayini IF, Al-Ghazo MA, Pickard RS. A prospective randomized trial comparing transurethral prostatic resection and clean intermittent self-catheterization in men with chronic urinary retention. BJU International. Jul. 2005;96(1):93-7. [pmid: 15963128].
14 Gallien P, Reymann JM, Amarenco G, et al. Placebo controlled, randomised, double blind study of the effects of botulinum A toxin on detrusor sphincter dyssynergia in multiple sclerosis patients. Journal of Neurology, Neurosurgery & Psychiatry. Dec. 2005;76(12):1670-6. [pmid: 16291892].
15 Hindley RG, Brierly RD, Thomas PJ. Prostaglandin E2 and bethanechol in combination for treating detrusor underactivity. BJU International. Jan. 2004;93(1):89-92. [pmid: 14678375].
16 Chen YH, Kuo HC. Botulinum A toxin treatment of urethral sphincter pseudodyssynergia in patients with cerebrovascular accidents or intracranial lesions. Urologia Internationalis. 2004;73(2):156-61. discussion 61-2. [pmid: 15331901].
17 de Seze M, Petit H, Gallien P, et al. Botulinum a toxin and detrusor sphincter dyssynergia: a double-blind lidocaine-controlled study in 13 patients with spinal cord disease. European Urology. Jul. 2002;42(1):56-62. [pmid: 12121731].
18 Jonas U, Fowler CJ, Chancellor MB, et al. Efficacy of sacral nerve stimulation for urinary retention: results 18 months after implantation. Journal of Urology. Jan. 2001;165(1):15-9. [pmid: 11125353].
19 Gujral S, Abrams P, Donovan JL, et al. A prospective randomized trial comparing transurethral resection of the prostate and laser therapy in men with chronic urinary retention: The CLasP study. Journal of Urology. Jul. 2000;164(1):59-64. [pmid: 10840425].
20 Duffy LM, Cleary J, Ahern S, et al. Clean intermittent catheterization: safe, cost-effective bladder management for male residents of VA nursing homes. Journal of the American Geriatrics Society. Aug. 1995;43(8):865-70. [pmid: 7636093].
21 Herbison GP, Arnold EP. Sacral neuromodulation with implanted devices for urinary storage and voiding dysfunction in adults. Cochrane Database of Systematic Reviews. 2009;(2):CD004202. [pmid: 19370596].
22 Moore Katherine N, Fader M, Getliffe K. Long-term bladder management by intermittent catheterisation in adults and children. John Wiley & Sons, Ltd. 2007. http://onlinelibrary.wiley.com/doi/10.1002/14651858.CD006008.pub2/abstract. 4.
23 McNeill SA, Hargreave TB, Geffriaud-Ricouard C, et al. Postvoid residual urine in patients with lower urinary tract symptoms suggestive of benign prostatic hyperplasia: pooled analysis of eleven controlled studies with alfuzosin. Urology. Mar. 2001;57(3):459-65. [pmid: 11248620].