# Methods

The draft Key Questions developed during AHRQ's Topic Refinement process were posted for public comment from October 22, 2012, through November 19, 2012. The comments received suggested that changes to the scope of the draft Key Questions were unnecessary. Comments did, however, suggest that we call the condition “incomplete bladder emptying” or “elevated postvoid residual” instead of CUR. We addressed these comments and conducted preliminary literature reviews in developing the draft protocol during the Comparative Effectiveness Review phase of the project. We next convened a Technical Expert Panel (TEP) of clinicians and researchers in urology, primary care, physical medicine and rehabilitation, and gynecology for topical guidance during the CER. We solicited their expertise in defining populations, interventions, comparisons, and outcomes, and in identifying particular studies. The Key Informants and members of the TEP were required to disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts. Any potential conflicts of interest were balanced or mitigated. TEP members did not perform analysis of any kind, nor did they contribute to the writing of this report. Members of the TEP were invited to provide feedback on an initial draft of the review protocol. That draft was then revised, reviewed by AHRQ, and posted for public access on the AHRQ Effective Health Care Program Web site.

We registered the protocol for this review with the International Prospective Registry of Systematic Reviews, PROSPERO (registration number: CRD42013004639). The final version is available at effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?productid=1539&pageaction=displayproduct. We conducted bibliographic database searches in MEDLINE and the Cochrane Central Register of Controlled Trials (CENTRAL) to identify previous systematic reviews, randomized controlled trials, and prospective cohort studies published from 1946 through February 15, 2014. Because the natural history of CUR is poorly understood, controlled studies are especially important; without a control group, we could not know whether changes in CUR outcomes were due to interventions or part of the natural history of the condition. We searched only for the CUR concept and used relevant medical subject headings and natural language terms to identify studies (Appendix C). We narrowed the search by using filters designed to select experimental designs.6 Bibliographic database searches were supplemented with backward citation searches of highly relevant systematic reviews. Two investigators reviewed titles and abstracts to identify those potentially meeting inclusion criteria (Appendix D). All controlled studies that addressed the PICOTS described previously were eligible and included. Two investigators worked independently to screen the full text of studies identified as potentially meeting inclusion criteria. Differences in inclusion decisions were addressed through consultation; a third investigator was consulted when necessary.

We first assessed the relevance of systematic reviews that met inclusion criteria. If we determined that certain Key Questions or comparisons addressed in the previous systematic review were relevant to our review, we assessed the quality of the methodology using modified AMSTAR criteria.7 When prior systematic reviews were assessed as sufficient quality, and when the review assessed strength of evidence or provided sufficient information for it to be assessed, we used the conclusions from that review to replace the de novo process. If additional studies on these comparisons were identified, we updated the systematic review results. We then abstracted data from eligible trials and prospective cohort studies not included in previous systematic reviews that addressed comparisons not sufficiently addressed by a previous eligible systematic review. One investigator abstracted the relevant data into the Systematic Review Data Repository tool and/or directly to evidence tables. A second investigator reviewed evidence tables and verified them for accuracy. Based on judgments of selection bias, performance and detection bias (allocation concealment and blinding), attrition bias, reporting bias, and other sources of bias, investigators assessed overall risk of bias for each eligible study.

We categorized eligible studies into groups for analysis based on similar populations. We conducted a qualitative synthesis because of heterogeneity in populations, interventions, and outcomes studied.

We evaluated overall strength of evidence for primary outcomes for each treatment comparison and outcome. We included the following primary outcomes a priori: rates of AUR, UTI, successful trial without catheter, and categorical measures of urinary symptom or quality of life scales. We treated change in PVR urine volume and continuous measures of urinary symptoms and/or quality of life as intermediate outcomes. We specifically analyzed PVR to assess whether patients no longer met CUR diagnostic criteria and to better understand the impact of treatment on urinary symptoms and PVR. We abstracted data on any harms reported. Given the relative infrequency of harms occurrence and the inconsistency in reporting harms across studies, we did not formally assess strength of evidence for all harms and focused instead on intervention benefits. In some cases, events we categorized as primary outcomes are also considered treatment harms. For instance, UTI is thought to be both a consequence of CUR; as well as a harm associated with many of the interventions. We chose to categorize this variable as a primary outcome instead of a harm. As a primary outcome, rate of UTI captures the net amount of UTI prevented rather than caused by the intervention. Similarly, we categorized surgical intervention, considered a harm of some CUR interventions, as a primary outcome. Our assessment of strength of evidence for these outcomes is discussed in the benefits section.

Strength of evidence assessments (high, moderate, low, or insufficient) were based on four required domains: (1) study limitations (internal validity); (2) directness (single, direct link between intervention and outcome); (3) consistency (similarity of effect direction and size); and (4) precision (degree of certainty around an estimate).8 A low strength of evidence required at least moderate or low risk of bias and precision. Moderate or high strength of evidence assessments required directness and/or consistency as well. Evidence was rated insufficient if outcomes differences between groups were not significant and imprecise.

We evaluated the applicability or generalizability of study results according to the PICOTS framework, paying particular attention to narrow eligibility criteria and patient characteristics that may differ from those of individuals in the community undergoing treatment for CUR from similar causes.9