# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- James Quentin Clemens, M.D
  University of Michigan
  Ann Arbor, MI
- Ananias Diokno, M.D.
  Oakland University William Beaumont School of Medicine
  Rochester, MI
- Carlo Negro, M.D., FEBU
  Ospedale Cardinal Massaia - ASL AT
  AT Torino, Italy
- Brian Selius, D.O.
  Northeast Ohio Medical University
  Youngstown, OH