# Acknowledgments

We would like to thank Marilyn Eells for outstanding editing support.