# Discussion

Overall, we identified few studies that enrolled patients with CUR. Those that did typically enrolled adults with CUR as well as the contributing condition (e.g., benign prostatic enlargement or multiple sclerosis). Eligible studies were generally small and had moderate risk of bias. We grouped similar populations for analysis. We found that many of the possible CUR etiologies had not been studied in controlled trials. For etiologies that were studied, evidence was most often insufficient to draw conclusions about efficacy and comparative effectiveness of various interventions.

We identified only three studies that examined the treatment for CUR from obstructive causes. All addressed CUR associated with bladder outlet obstruction from benign prostatic enlargement and enrolled men with CUR and urinary symptoms.

- Data were insufficient to draw conclusions regarding most outcomes for each comparison. Low-strength evidence suggested no statistical difference between TURP and microwave therapy in the rate at which men were catheter free at 6 months. Evidence was insufficient to draw conclusions for all other outcomes. Future research is necessary before information is useful in informing practice.
- We found no data to assess the impact of treating CUR independent of treating benign prostatic enlargement and other lower urinary tract symptoms.

We identified one systematic review and four studies that addressed treatments for CUR from non-obstructive causes. Evidence for all comparisons and primary outcomes was insufficient to draw conclusions about treatment, primarily because risk of bias was moderate and estimates were imprecise due to small sample sizes. The previous systematic review provides the highest level of evidence:

- Low-strength evidence suggested that sacral neuromodulation reduces the need for catheterization and PVR urine for CUR not attributable to obstructive causes.

Again, we found sparse data for analysis of treatments in populations with CUR from mixed obstructive/non-obstructive causes or from unknown causes. We identified only two eligible effectiveness studies and one relevant comparison in a previous systematic review. Evidence was insufficient for all comparisons and outcomes. Harms were inconsistently reported and studies were not powered to detect differences in those reported.

## Applicability

The applicability or generalizability of our conclusions applies to patients with conditions similar to those examined in the eligible studies. Eligible studies did not address all possible populations in which CUR is common. Age and sex of subjects appear similar to the populations experiencing CUR from those causes in practice. Recruitment methods varied but were overall judged as likely to represent their respective populations. Conclusions lacked strength due to limited evidence, but participants in the eligible studies reflected the populations they represented.

## Limitations

This review suffers from several limitations. First, we identified few studies that specifically evaluated treatments for CUR or that enrolled patient with CUR. Included studies often evaluated treatments for the underlying condition, such as benign prostatic enlargement and urinary symptoms. Treatments were similar to those used in the broader population (same conditions with only a subpopulation that suffers from CUR).

Many of the identified studies suffered from methodological weaknesses and were underpowered.

## Future Research Needs

Our review provides low-strength evidence at best on a select few treatments for CUR attributed to a variety of underlying conditions. Evidence for most comparisons and outcomes was insufficient, demonstrating large gaps in the research on this topic. Although several ongoing studies (Appendix J) may, when completed, help close some of the gaps, additional research is also needed (specific recommendations appear in Appendix K).

Clarification or agreement on conceptual issues may help direct future research. Improved understanding of the natural history of CUR would provide context. It is not clear whether research on CUR should occur within underlying conditions or across conditions as this review attempted. Resolving these contextual issues would benefit future comparative effectiveness research.

A stronger comparative effectiveness evidence base will also require additional research. Many population groups known to suffer from CUR were not addressed by controlled studies. These include individuals with other obstructive or anatomical causes such as strictures or prolapsed organs, those with neurologic disorders such as diabetes mellitus, diabetic neuropathy, and Parkinson's disease, and women with CUR arising as a complication from surgery for stress urinary incontinence. Additionally, treatments other than those examined in included studies are available and may alleviate CUR. Pharmaceutical interventions are commonly used in men with BPH and evidence from those trials suggests that alpha-blockers help to reduce PVR volumes in men with BPH.23 One study addressing this question is registered with ClinicalTrials.gov; however, results are not available.