# Conclusions

Standard clinical diagnostic criteria are lacking for CUR, and the condition is variably defined in research. Because CUR is typically caused by other medical conditions, treatment options differ based on the underlying problem. The evidence addresses only a subset of possible treatments and just a few of the many possible subgroups of CUR patients based on underlying conditions. In men with bladder outlet obstruction from benign prostatic enlargement, TURP and microwave therapy achieved similar catheter-free rates at 6 months post treatment. However, because evidence on other outcomes was insufficient, we do not know the sustainability of benefits compared for these groups. Therefore, evidence on longer term outcomes is necessary to fully understand this comparison. Evidence on harms was not adequately powered to detect differences between groups. Therefore, these results are not useful in informing practice. We could not determine what portion of the improvement in primary outcomes is attributable to treating CUR (above and beyond treating the underlying condition). Treatment benefits likely result from improvements in lower urinary tract symptoms. In patients with CUR from non-obstructive causes, botulinum injections do not appear to reduce PVR urine volumes. In Fowler's syndrome patients, sacral neuromodulation may be effective. Data on treatment of “asymptomatic” patients with CUR was not informative because the population was not adequately defined.