# Future Research Needs

Table K1 Future research needs

Key Question | Results of Literature Review | Types of Studies; Needed To Answer Question | Future Research Recommendations
General | Many of the studies on interventions for CUR were uncontrolled Intervention studies enrolling men with CUR and BPH typically also required them to have significant lower urinary tract symptoms, not possible to differentiate whether improvements reflect the treatment for CUR or LUTS when they have overlapping interventions Intervention studies enrolling neurogenic bladder patients rarely described type of voiding dysfunction | Observational Qualitative Consensus development | Research to describe the natural history of CUR Standardized definition of CUR Clearly separate AUR and CUR patients in research studies Studies that evaluate if, when, and who it is beneficial to screen for CUR Make determination whether CUR should be addressed as a separate condition or better addressed as a manifestation of the underlying condition Design intervention studies in the neurogenic bladder population that include adequate numbers of different types of neurogenic bladder (incontinent, retention, both) to determine if outcomes vary by type of voiding dysfunction Conduct controlled studies on CUR interventions Studies with adequately powered subgroups of CUR patients should be conducted to determine whether CUR modifies the effect of treatment Only conduct studies that are adequately powered
1a. What is the effectiveness and comparative effectiveness of treatments for chronic urinary retention in adults, male-specific etiologies? | Only three trials were identified. No two studies compared the same interventions BPH was the only male-specific etiology studied We identified no studies that examined BPH as a subgroup of a larger trial Data was identified for only four interventions No data for long-term outcomes available | RCTs; prospective cohort studies | Additional studies necessary to establish consistency for TURP Efficacy and comparative effectiveness of pharmaceutical interventions such as alpha blockers and 5 alpha reductase inhibitors^a^ Studies with followup times extending for several years
1b. What is the effectiveness and comparative effectiveness of treatments for chronic urinary retention in adults, female-specific etiologies? | Only one study addressed a predominantly female etiology (Fowler's syndrome) Only one patient-centered outcome was evaluated No data for long-term outcomes available | RCTs; prospective cohort studies | Controlled studies of interventions for women with CUR resulting from SUI procedures or from pelvic organ prolapse Intervention studies with nonimplanted devices to treat Fowler's syndrome Controlled studies of neuromodulation interventions with long-term followup to determine duration of effectiveness
1c. What is the effectiveness and comparative effectiveness of treatments for chronic urinary retention in adults, nonsex-specific etiologies? | We identified few studies that addressed nonsex-specific etiologies Neurogenic bladder was the only etiology studied Studies often enrolled populations with heterogeneous underlying conditions Small sample sizes Primarily intermediate outcomes studied | RCTs, prospective cohort studies | Additional patient-centered outcomes should be included
1d. What patient or condition characteristics (e.g., age, severity, etc.) modify the effectiveness of treatment? | One study used a more conservative treatment in men with higher prostate volumes | RCTs, prospective cohort studies | Stratify enrolled CUR patients by severity
2a. What are the harms and comparative harms of treatments for chronic urinary retention in adults with male-specific, female-specific, and nonsex-specific etiologies? | Harms were inconsistently measured and reported | | Adequately collect and report data on harms.
2d. What patient or condition characteristics (e.g., age, severity, etc.) modify the harms of treatment? | Not addressed by current literature | | Larger sample sizes will enable this type of analysis

a One RCT was identified in Clinicaltrials.gov; completed in 2008, but results are not available