# Ongoing Studies

Table J1 Ongoing studies

NCT Number | Title | Conditions | Interventions | Study Designs
NCT01460303 | Patient-operated Valved Catheter Versus Indwelling Transurethral Catheter | Bladder Dysfunction\|Urinary Retention | Device: Bladder catheter: OPTION-vf patient controlled catheter vs. indwelling transurethral catheter with leg bag Device: Transurethral catheter with leg bag | Allocation: Randomized\|Endpoint Classification: Efficacy Study\|Intervention Model: Parallel Assignment\|Masking: Open Label\|Primary Purpose: Treatment
NCT00878176 | Sacral Neuromodulation Test With Bilateral First Stage Tined Lead Procedure in Patients with Non-obstructive Urinary Retention: A Pilot Study | Urinary Retention | Procedure: First stage tined lead procedure | Endpoint Classification: Efficacy Study\|Intervention Model: Crossover Assignment\|Masking: Open Label\|Primary Purpose: Screening
NCT00680680 | Treatment of Refractory Urinary Retention Secondary to Benign Prostatic Hyperplasia (BPH) with Dual Five Alpha Reductase Inhibition Combined with an Alpha Blocker | Urinary Retention\|Benign Prostatic Hyperplasia | Drug: Dutasteride | Allocation: Non-Randomized\|Endpoint Classification: Efficacy Study\|Intervention Model: Single Group Assignment\|Masking: Open Label\|Primary Purpose: Treatment
NCT00700505 | A Study to Determine the Safety and Efficacy of a New Non-invasive Heating Garment to Reduce Urinary Hesitancy | Benign Prostatic Hyperplasia (BPH)\|Urinary Retention\|Urinary Hesitancy Intermittent | Device: FlowPants(R) Garment | Endpoint Classification: Safety/Efficacy Study\|Intervention Model: Single Group Assignment\|Masking: Open Label\|Primary Purpose: Treatment
NCT00441935 | InterStim Prospective Database | Urinary Retention\|Urinary Incontinence\|Pelvic Pain | Device: InterStim Neuromodulation | Time Perspective: Prospective
NCT00970242 | Ambulatory Urodynamic Evaluation of Sacral Neuromodulation for Non-Obstructive Urinary Retention | Acontractile Bladder | | Time Perspective: Prospective
NCT01404481 | Clean Intermittant Self Catheterisation: A Trial Comparing Single Use vs. Reuse of Nelaton Catheters | Urinary Retention | Device: clean intermittent self catheterisation single use vs. re use | Observational Model: Cohort\|Time Perspective: Prospective
NCT01771159 | Tissue Bonding Cystostomy (TBC) | Spinal Cord Injury (SCI)\|Chronic Urinary Retention\|Urinary Incontinence | Device: TBC | Intervention Model: Single Group Assignment\|Masking: Open Label\|Primary Purpose: Treatment
NCT01164280 | Effect of Pulse Rate Changes on Clinical Outcome | Overactive Bladder Syndrome\|Chronic Urinary Retention | Other: Pulse Rate Change | Intervention Model: Single Group Assignment\|Primary Purpose: Treatment
NCT00883220 | Self Management in Urinary Catheter Users | Urinary Retention\|Neurogenic Bladder | Behavioral: Self-management of urinary catheter | Allocation: Randomized\|Endpoint Classification: Safety/Efficacy Study\|Intervention Model: Parallel Assignment\|Masking: Single Blind (Investigator)\|Primary Purpose: Prevention
NCT00225966 | Patient Registry to Study the Tined Lead Used with the InterStim System for Urinary Control | Urge Incontinence\|Urinary Retention | Device: Device Medtronic InterStim Tined Leads Models 3889 and 3093 | Allocation: Non-Randomized\|Endpoint Classification: Safety/Efficacy Study\|Intervention Model: Single Group Assignment\|Masking: Open Label\|Primary Purpose: Treatment
NCT01284361 | Comparison of Two Intermittent Urinary Catheters | Urinary Retention | Device: test and control intermittent urinary catheters | Allocation: Randomized\|Intervention Model: Crossover Assignment\|Masking: Open Label
NCT01305681 | Bacterial Properties with LoFric® Catheters During Clean Intermittent Catheterization | Neurogenic Bladder\|Urinary Retention | Device: LoFric® catheters during clean intermittent catheterization | Allocation: Non-Randomized\|Intervention Model: Parallel Assignment\|Masking: Open Label\|Primary Purpose: Treatment
NCT00200031 | A Cost Analysis of Interstim Therapy | Urinary Retention and Symptoms of Overactive Bladder (Urge, Frequency) | Device: Interstim therapy
NCT01130415 | Screening Method in Sacral Neuromodulation | Overactive Bladder\|Urinary Retention | | Observational Model: Cohort\|Time Perspective: Retrospective