# Strength of Evidence

Appendix Table I1 Strength of evidence assessments: comparative effectiveness of treatments for CUR from obstructive causes

Comparison; # of Studies; N | Outcomes | Summary Statistics [95% CI] | Risk of Bias | Directness | Precision | Consistency | Evidence Rating
Microwave therapy vs. TURP or prostate enucleation surgery 1 RCT N=120 | Primary Outcomes
Microwave therapy vs. TURP or prostate enucleation surgery 1 RCT N=120 | Urinary tract infection | RR 1.49 [95% CI 0.82 to 2.71] | Moderate | Direct | Imprecise | Single study | Insufficient
Microwave therapy vs. TURP or prostate enucleation surgery 1 RCT N=120 | Catheter-free status | RR 0.89 [95% CI 0.76 to 1.05] | Moderate | Direct | Precise | Single study | Low
Microwave therapy vs. TURP or prostate enucleation surgery 1 RCT N=120 | Intermediate Outcomes
Microwave therapy vs. TURP or prostate enucleation surgery 1 RCT N=120 | IPSS, mean at endpoint | MD 2.9 [95%CI 0.5 to 5.3] | Moderate | Indirect | Imprecise | Single study | Insufficient
Microwave therapy vs. TURP or prostate enucleation surgery 1 RCT N=120 | IPSS QoL, mean change | NS between interventions^*^ | Moderate | Indirect | Unclear | Single study | Insufficient
Microwave therapy vs. TURP or prostate enucleation surgery 1 RCT N=120 | PVR (ml) | Not reported | - | - | - | - | Insufficient
TURP vs. clean intermittent self-catheterization 1 RCT N=51 | Primary Outcomes
TURP vs. clean intermittent self-catheterization 1 RCT N=51 | None reported | | - | - | - | -
TURP vs. clean intermittent self-catheterization 1 RCT N=51 | Intermediate Outcomes
TURP vs. clean intermittent self-catheterization 1 RCT N=51 | IPSS, mean at endpoint | MD -8.0 [95%CI -13.3 to 2.8] | Moderate | Indirect | Imprecise | Single study | Insufficient
TURP vs. clean intermittent self-catheterization 1 RCT N=51 | IPSS QoL, mean change | MD -0.5 [95%CI -1.4 to 0.4] | Moderate | Indirect | Imprecise | Single study | Insufficient
TURP vs. clean intermittent self-catheterization 1 RCT N=51 | PVR (ml) | MD -254 [95%CI -553 to 45] | Moderate | Indirect | Imprecise | Single study | Insufficient
TURP vs. laser therapy 1 RCT N=82 | Primary Outcomes
TURP vs. laser therapy 1 RCT N=82 | Urinary tract infection | RR 1.73 [95% CI 0.16 to 18.31] | High | Direct | Imprecise | Single study | Insufficient
TURP vs. laser therapy 1 RCT N=82 | IPSS category, adjusted | RR 1.27 [95% CI 0.97 to 1.68] | Moderate | Direct | Imprecise | Single study | Insufficient
TURP vs. laser therapy 1 RCT N=82 | Intermediate Outcomes
TURP vs. laser therapy 1 RCT N=82 | IPSS, mean at endpoint | MD -2.0 [95%CI -6.4 to 2.4] | Moderate | Indirect | Imprecise | Single study | Insufficient
TURP vs. laser therapy 1 RCT N=82 | IPSS QoL, mean change | MD -0.4 [95%CI -1.3 to 0.5] | Moderate | Indirect | Imprecise | Single study | Insufficient
TURP vs. laser therapy 1 RCT N=82 | PVR (ml), adjusted | MD -135 [95%CI -233 to -37] | Moderate | Indirect | Precise | Single study | Low

RR = relative risk [95 percent confidence intervals]; MD = mean difference [95 percent confidence intervals]; TURP = transurethral resection of the prostate; NS = No statistically significant difference.

* Mean difference could not be calculated

Table I2 Strength of evidence assessments: comparative effectiveness of treatments for CUR from non-obstructive causes

Study; Comparison; N | Outcomes | Summary Statistics [95% CI] | Risk of Bias | Directness | Precision | Consistency | Evidence Rating
Botulinum A toxin injected into sphinter vs. placebo 1 RCT N=86 | Primary Outcomes
Botulinum A toxin injected into sphinter vs. placebo 1 RCT N=86 | Urinary tract infection | RR 1.21 [95% CI 0.66 to 2.25] | Moderate | Direct | Imprecise | Single study | Insufficient
Botulinum A toxin injected into sphinter vs. placebo 1 RCT N=86 | Intermediate Outcomes
Botulinum A toxin injected into sphinter vs. placebo 1 RCT N=86 | IPSS, mean at endpoint | MD 2.0 [95%CI -1.0 to 5.0] | Moderate | Indirect | Imprecise | Single study | Insufficient
Botulinum A toxin injected into sphinter vs. placebo 1 RCT N=86 | IPSS QoL, mean change | Not reported | - | - | - | - | Insufficient
Botulinum A toxin injected into sphinter vs. placebo 1 RCT N=86 | PVR (ml) | MD -20 [95%CI -85 to 45] | Moderate | Indirect | Imprecise | Single study | Insufficient
Bethanechol chloride plus prostaglandin E2 vs. placebo 1 RCT N=19 | Primary Outcomes
Bethanechol chloride plus prostaglandin E2 vs. placebo 1 RCT N=19 | Urinary tract infection | Not reported | - | - | - | - | Insufficient
Bethanechol chloride plus prostaglandin E2 vs. placebo 1 RCT N=19 | Intermediate Outcomes
Bethanechol chloride plus prostaglandin E2 vs. placebo 1 RCT N=19 | IPSS, mean at endpoint | Not reported | - | - | - | - | Insufficient
Bethanechol chloride plus prostaglandin E2 vs. placebo 1 RCT N=19 | QoL, mean change | NS between interventions^*^ | High | Indirect | Imprecise | Single study | Insufficient
Bethanechol chloride plus prostaglandin E2 vs. placebo 1 RCT N=19 | PVR (ml) | NS between interventions^*^ | Moderate | Indirect | Imprecise | Single study | Insufficient
Botulinum A toxin injected into sphinter vs. Lidocaine 1 RCT N=13 | Primary Outcomes
Botulinum A toxin injected into sphinter vs. Lidocaine 1 RCT N=13 | Urinary tract infection | Not reported | - | - | - | - | Insufficient
Botulinum A toxin injected into sphinter vs. Lidocaine 1 RCT N=13 | Intermediate Outcomes
Botulinum A toxin injected into sphinter vs. Lidocaine 1 RCT N=13 | IPSS, mean at endpoint | Not reported | - | - | - | - | Insufficient
Botulinum A toxin injected into sphinter vs. Lidocaine 1 RCT N=13 | IPSS QoL, mean change | Not reported | - | - | - | - | Insufficient
Botulinum A toxin injected into sphinter vs. Lidocaine 1 RCT N=13 | PVR (ml) | MD 538 [95% CI 350 to 1775] | Moderate | Indirect | Imprecise | Single study | Insufficient
Botulinum A toxin injected into sphinter vs. Lidocaine 1 Prospective study N=21 | Primary Outcomes
Botulinum A toxin injected into sphinter vs. Lidocaine 1 Prospective study N=21 | Urinary tract infection | Not reported | - | - | - | - | Insufficient
Botulinum A toxin injected into sphinter vs. Lidocaine 1 Prospective study N=21 | Intermediate Outcomes
Botulinum A toxin injected into sphinter vs. Lidocaine 1 Prospective study N=21 | IPSS, mean at endpoint | MD -9.5 [95%CI -14.3 to -4.7] | High | Indirect | Imprecise | Single study | Insufficient
Botulinum A toxin injected into sphinter vs. Lidocaine 1 Prospective study N=21 | IPSS QoL, mean change | MD -1.2 [95%CI -2.1 to -0.3] | High | Indirect | Imprecise | Single study | Insufficient
Botulinum A toxin injected into sphinter vs. Lidocaine 1 Prospective study N=21 | PVR (ml) | MD -135 [95%CI -233 to -37] | High | Indirect | Imprecise | Single study | Insufficient
Sacral neuromodulation with implanted device: Immediate vs. delayed implant SR | Primary Outcomes
Sacral neuromodulation with implanted device: Immediate vs. delayed implant SR | Catheter free | RR 7.21 [95% CI 1.87 to 27.73 ] | SR: Low | Direct | Precise | Single study | Low
Sacral neuromodulation with implanted device: Immediate vs. delayed implant SR | Intermediate Outcomes
Sacral neuromodulation with implanted device: Immediate vs. delayed implant SR | PVR (ml) | MD -1068 [95% CI --1493to -643 ] | Moderate | Indirect | Precise | Single study | Low

SR=systematic review; RR = relative risk [95 percent confidence intervals] MD = mean difference [95 percent confidence intervals]; NS = No statistically significant difference.

* Mean difference could not be calculated

Appendix Table I3 Strength of evidence assessments: comparative effectiveness of treatments for CUR: mixed populations/unknown causes

Study; Comparison; N | Outcomes | Summary Statistics [95% CI] | Risk of Bias | Directness | Precision | Consistency | Evidence Rating
Sildenafil vs. placebo 1 RCT N=19 | Primary Outcomes
Sildenafil vs. placebo 1 RCT N=19 | Acute urinary retention | Not reported | - | - | - | - | Insufficient
Sildenafil vs. placebo 1 RCT N=19 | Urinary tract infection | 1 event in sildenafil arm | Moderate | Direct | Imprecise | Single study | Insufficient
Sildenafil vs. placebo 1 RCT N=19 | Surgical intervention | Not reported | - | - | - | - | Insufficient
Sildenafil vs. placebo 1 RCT N=19 | Treatment failure | Not reported | - | - | - | - | Insufficient
Sildenafil vs. placebo 1 RCT N=19 | Catheter outcomes | Not reported | - | - | - | - | Insufficient
Sildenafil vs. placebo 1 RCT N=19 | Intermediate Outcomes
Sildenafil vs. placebo 1 RCT N=19 | IPSS, mean at endpoint | NS between interventions^*^ | Moderate | Indirect | Imprecise | Single study | Insufficient
Sildenafil vs. placebo 1 RCT N=19 | QoL, mean change | Not reported | - | - | - | - | Insufficient
Sildenafil vs. placebo 1 RCT N=19 | PVR (ml) | NS between interventions^*^ | Moderate | Indirect | Imprecise | Single study | Insufficient
Intermittent urinary catheterization vs. indwelling urinary catheterization 1 RCT N=81 | Primary Outcomes
Intermittent urinary catheterization vs. indwelling urinary catheterization 1 RCT N=81 | Acute urinary retention | Not reported | - | - | - | - | Insufficient
Intermittent urinary catheterization vs. indwelling urinary catheterization 1 RCT N=81 | Urinary tract infection | 1 event in IMC arm | Moderate | Direct | Imprecise | Single study | Insufficient
Intermittent urinary catheterization vs. indwelling urinary catheterization 1 RCT N=81 | Surgical intervention | Not reported | - | - | - | - | Insufficient
Intermittent urinary catheterization vs. indwelling urinary catheterization 1 RCT N=81 | Treatment failure | Not reported | - | - | - | - | Insufficient
Intermittent urinary catheterization vs. indwelling urinary catheterization 1 RCT N=81 | Catheter outcomes | RR 0.86 [95% CI 0.59 to 1.25] | Moderate | Direct | Imprecise | Single study | Insufficient
Intermittent urinary catheterization vs. indwelling urinary catheterization 1 RCT N=81 | Intermediate Outcomes
Intermittent urinary catheterization vs. indwelling urinary catheterization 1 RCT N=81 | IPSS, mean at endpoint | Not reported | - | - | - | - | Insufficient
Intermittent urinary catheterization vs. indwelling urinary catheterization 1 RCT N=81 | QoL, mean change | Not reported | - | - | - | - | Insufficient
Intermittent urinary catheterization vs. indwelling urinary catheterization 1 RCT N=81 | PVR (ml) | MD -23 [95% CI -47 to 0.63] | Moderate | Indirect | Precise | Single study | Low

Single study = not applicable; RR = relative risk [95 percent confidence intervals]; MD = mean difference [95 percent confidence intervals]; NS = No statistically significant difference.

* Mean difference could not be calculated