# Detailed Results

## Comparative Effectiveness of Treatments for CUR: Obstructive Causes

We identified only three eligible studies comparing treatments for CUR from obstructive causes. Three eligible RCTs compared treatments for CUR in men with bladder outlet obstruction secondary to benign prostatic enlargement.1-3 Each of these studies included men with CUR (defined as persistent PVR >300ml) and other lower urinary tract symptoms. Study and patient characteristics appear in Table H1. The mean age of the 243 men enrolled in these studies was 71. Two studies reported mean baseline IPSS scores and PVR volumes with a mean baseline total IPSS score of 21.4 (severe symptoms) and mean baseline PVR volume of 626 ml. All three trials compared surgery (transurethral resection of the prostate or prostate enucleation) to a less invasive intervention (laser, microwave, clean intermittent sterile catheterization). Two of these trials were conducted in Europe and one in Asia. All three RCTs demonstrated methodological problems (limited ability for blinding and allocation concealment) and each was assessed to have an overall medium risk of bias.

Table H1 Comparative effectiveness of treatments for CUR from obstructive causes: summary of included studies

Number of studies | 3
Randomized controlled trials | 3
Number of patients enrolled (range) | 243 (41 to 120)
Age of subjects, mean years (range) | 71 (68 to 73)
Gender (range) | Men 100%
Baseline mean IPSS total score (range) (range 0 to 35)^*^ | 21.4 (20.0 to 24.3; 2 studies^†^)
Baseline mean PVR, mL (range) | 626 (459 to 959; 2 studies^†^)
Neurogenic disease etiology | NR
Neurogenic disease duration, mean years | NR
Trials conducted in the United States (% of patients) | None
Trials conducted in Europe (% of patients) | 2 (83)
Trials conducted in Asia (% of patients) | 1 (17)
Studies reporting primary outcomes | 2
Studies reporting secondary outcomes | 3

* IPSS = International Prostate Symptom Score: Scoring criteria are: Mild (score 1-7); Moderate (score 8-19); Severe (score 20-35); NR = not reported; PVR=post-void residual

† Number of studies reporting this variable

### Primary Outcomes

Two of the three RCTs reported on five primary outcomes (UTI, treatment failure, trial without catheter [TWOC], need for surgical intervention, and IPSS category) (Table H2). The third RCT assessed only intermediate outcomes. We included IPSS category as a primary outcome because no study reported those achieving a minimum clinically important difference as the primary variable and the categorization better measures a clinical difference than changes in mean scores. Overall, the studies reported few differences in primary outcomes between groups, with both treatment groups typically showing improvements over baseline.

Table H2 Comparative effectiveness of treatments for CUR from obstructive causes: primary outcomes

Study Design Followup | Treatment Arms | Acute Urinary Retention n/N (%) | Urinary Tract Infection n/N (%) | Surgical Intervention n/N (%) | IPSS^*^ n/N (%) | Catheter Free n/N (%)
Schelin, 2006^3^ RCT 6 months | TUMT (n=61) | NR | 20/61 (32.8) | NR | NR | 48/61^††^ (78.7)
Schelin, 2006^3^ RCT 6 months | TURP or enucleation (n=59) | NR | 13/59 (22) | NR | NR | 52/59^††^ (88.1)
Schelin, 2006^3^ RCT 6 months | RR [95% CI] | | 1.49 [0.82 to 2.71] | | | 0.89 [0.76 to 1.05]
Ghalanyini, 2005^1^ RCT 6 months | TURP (n=22) | NR | NR | NR | NR | NR
Ghalanyini, 2005^1^ RCT 6 months | CISC (n=29) | NR | NR | NR | NR | NR
Ghalanyini, 2005^1^ RCT 6 months | RR [95% CI]
Gujral, 2000 RCT2 7.5 months | TURP (n=44) | NR | 2/44 (4.5) | 0/44 | “good”^†^ 29/33 (87.9) | NR
Gujral, 2000 RCT2 7.5 months | Laser (n=38) | NR | 1/38 (2.6) | 3/38 (7.9)^**^ | good”^†^ 20/29 (69.0) | NR
Gujral, 2000 RCT2 7.5 months | RR [95% CI] | | 1.73 [0.16 to 18.31] | 0.12 [0.01 to 2.32] | 1.27 [0.97 to 1.68]
Gujral, 2000 RCT2 7.5 months | Adjusted OR | | NR | NR | 3.9 [1.0 to 14.3]

CI = confidence interval; CISC = clean intermittent self-catheterization; IPSS = International Prostate Symptom Score (range 0 (mild symptoms) to 35 (severe symptoms); NR – not reported; RCT = randomized controlled trial; RR=risk ratio; TUMT = transurethral microwave therapy; TURP = transurethral resection of the prostate

* Subjects with clinically relevant improvement from baseline

** These patients required a TURP following laser surgery due to “unacceptable levels of symptoms.”

† “Good” defined as postoperative score <8 or ≥50% reduction from baseline

†† All patients required catheterization at baseline

No studies reported AUR. Schelin et al. and Gujral et al. reported rates of UTI. More than 30 percent of the microwave therapy patients and 22 percent of the TURP patients experienced a UTI over the 6-month followup period.3 UTI was recorded only as a postsurgical complication in the other study with nearly 5 percent of the TURP patients and nearly 3 percent of the laser therapy patients experiencing a postsurgical UTI.2 Neither difference between treatment groups was statistically significant.

Gujral, et al. reported on surgical interventions. Three patients in the laser therapy group required TURP for continuing symptoms. None of the TURP patients needed to return to surgery; the difference was not statistically significant.2 IPSS category was also measured in this study. Nearly 88 percent of the TURP patients and 69 percent of the laser therapy patients were in the good category after treatment. Once adjusted (groups differed at baseline in marital status and prostate volume), the proportional odds model indicated this difference was statistically significant favoring TURP (OR=3.9; CI: 1.0 to 14.3).

### Intermediate Outcomes

Outcomes that we classified as intermediate were more frequently reported and authors may have considered them primary outcomes in their research (Table H3). Mean changes in continuous IPSS scores were reported in two of the three trials. When TURP is compared to clean intermittent self-catheterization, the TURP patients mean IPSS score improved by 20 points whereas the catheter patients mean score improved by 12 points. This level of change would be considered clinically important; however, confidence intervals were too wide for the difference to be statistically significant and included values that would not represent clinically meaningful change. Schelin, et al., report that after 3 months, the mean IPSS score in the microwave therapy group was 7.3 and 5.1 in the TURP/enucleation group3. At 6 months, these scores were 7.3 and 4.1, respectively.3 This difference did not reach statistical significance nor are the values clinically important. The adjusted mean change in IPSS scores for the TURP versus laser therapy group was statistically significant after adjustment (adjusted mean difference = -3.6; CI: -7.2 to -0.1).2 No other changes in intermediate outcomes (IPSS Quality of Life scores, PVR) were statistically significant for either comparison.

Table H3 Comparative effectiveness of treatments for CUR from obstructive causes: intermediate outcomes

Study; Design; Followup | Treatment Arms | IPSS, Mean (SD) at Baseline | IPSS, Mean (SD) Change from Baseline | IPSS QoL, Mean (SD) at Baseline | IPSS QoL, Mean Change (SD) from Baseline | PVR (mL), Mean (SD) at Baseline | PVR (mL), Mean (SD) Change from Baseline
Schelin, 2006^3^ RCT 6 months | TUMT (n=61) | NR | 7.3^**^ (7.3) (n=50) | ∼4.6^†^ [3.2 to 5.9] | ∼1.5^††^ [0 to 3.0] | NR | NR^†††^
Schelin, 2006^3^ RCT 6 months | TURP/enucleation surgery (n=59) | NR | 4.4^**^ (4.9) (n=49) | ∼4.7^†^ [3.5 to 5.9] | ∼0.9^††^ [0 to 2.0] | NR | NR^†††^
Schelin, 2006^3^ RCT 6 months | | Mean difference between groups [95% CI] | 2.90 [0.46 to 5.34] | Mean difference between groups [95% CI] | NR^a^
Ghalanyini, 2005^1^ RCT 6 months | TURP (n=17) | 25.8 (4.2) | -20.3 (8.9) | 4.4 (0.9) | -3.0 (1.5) | 954 (531) | -854.4 (437)
Ghalanyini, 2005^1^ RCT 6 months | CISC (n=24) | 23.2 (6.1) | -12.3 (7.8) | 4.2 (1.1) | -2.5 (1.4) | 963 (503) | -600.5 (537)
Ghalanyini, 2005^1^ RCT 6 months | | Mean difference between groups [95% CI] | -8.0 [-13.3 to 2.8] | Mean difference between groups [95% CI] | -0.5 [-1.4 to 0.4] | Mean difference between groups [95% CI] | -253.9 [-552.8 to 45.0]
Gujral, 2000 RCT2 7.5 months | TURP (n=44) | 19.5 (7.2) | -14.2 (8.4) (n=33) | 4.5 (2.6) median | -3.2 (1.8) (n=33) | 545 (275) | -464 (280) (n=40)
Gujral, 2000 RCT2 7.5 months | Laser (n=38) | 20.9 (6.4) | -12.2 (9.2) (n=29) | 5 (2.6) median | -2.8 (1.7) (n=30) | 438 (151) | -329 (135) (n=33)
Gujral, 2000 RCT2 7.5 months | | Mean difference between groups [95% CI] | -2.0 [-6.4 to 2.4] | Mean difference between groups [95% CI] | -0.4 [-1.3 to 0.5] | Mean difference between groups [95% CI] | -135.0^*^ [-233.2 to -36.8]
Gujral, 2000 RCT2 7.5 months | | Adj. mean difference between groups [95% CI] | -3.6 [-7.2 to -0.1] | Adj. mean difference between groups [95% CI] | -0.6 [-1.3 to 0.1] | Adj. mean difference between groups [95% CI] | -27.5 [-68.1 to 13]

CI= confidence interval; CISC = clean intermittent self-catheterization; IPSS = International Prostate Symptom Score (range 0 [mild symptoms] to 35 [severe symptoms]; NR = not reported; PLFT = ProstaLund Feedback Treatment; PVR: post-void residual urine volume; QoL = quality of life. IPSS QoL ranges from 1 (delighted) to 6 (terrible); RCT = randomized controlled trial; SD = standard deviation; TURP = transurethral resection of the prostate

a could not be calculated.

* Analysis of covariance, adjusting for center effects and baseline measurements, found no statistically significant difference between groups. Difference in means at followup was -27.5 mL [-68.1 to 13.0].

** Mean at endpoint

† Mean score at baseline (extracted from graph)

†† Mean at endpoint (extracted from graph)

††† All patients had PVR volumes over 300 ml at baseline; 2 patients in the TURP group and 4 patients in the TUMT group still had PVR volumes above 300 ml at followup.

### Harms

Each study measured adverse effects differently, reporting either the incidence of serious adverse effects or complication rates (Table H4). These harms did not differ between groups in the surgery versus microwave therapy or in surgery versus clean intermittent self-catheterization. However, a larger proportion of the TURP group experienced complications than the laser group. Strength of evidence was not assessed for harms.

Table H4 Comparative effectiveness of treatments for CUR from obstructive causes: adverse events

Study; Design; Followup | Treatment Arms | Death n/N (%) | Septicemia n/N (%) | Blood Transfusion n/N (%) | Major Bleeding n/N (%) | Complication Rate n/N (%) | Serious Adverse Events n/N (%) | Withdrawals
Schelin, 2006^3^ RCT 6 months | TUMT (n=61) | NR | NR | NR | NR | NR | 1/61 (1.6) | 2/61 (3.3)
Schelin, 2006^3^ RCT 6 months | TURP/enucleation surgery (n=59) | NR | NR | NR | NR | NR | 5/59 (8.5) | 3/59 (5.1)
Schelin, 2006^3^ RCT 6 months | Risk ratio [95% CI] | | | | | | 0.19 [0.02 to1.61]
Ghalanyini, 2005^1^ RCT 6 months | TURP (n=22) | NR | NR | NR | NR | 2/17^*^ (11.8) | NR
Ghalanyini, 2005^1^ RCT 6 months | CISC (n=29) | NR | NR | NR | NR | 8/24^*^ (33.3) | NR
Ghalanyini, 2005^1^ RCT 6 months | Risk ratio [95% CI] | | | | | 0.35 [0.09 to 1.46]
Gujral, 2000 RCT2 7.5 months | TURP (n=44) | 1/44 (2.3) | 3 incidences^**^ | 3 incidences^**^ | 6 incidences^**^ | 13/44 (29.5) | NR
Gujral, 2000 RCT2 7.5 months | Laser (n=38) | 0/38 (0.0) | 1/38 (2.6) | 0/38 | 0/38 | 3/38 (7.9) | NR
Gujral, 2000 RCT2 7.5 months | Risk ratio [95% CI] | 2.60 [0.11 to 62.01] | | | | 3.74 [1.15 to 12.15]

CI = confidence interval; CISC = clean intermittent self-catheterization; IPSS = International Prostate Symptom Score (range 0 [mild symptoms] to 35 [severe symptoms]; NR = not reported; RCT = randomized controlled trial; TUMT = transurethral microwave therapy; TURP = transurethral resection of the prostate

* Symptomatic infection (6), bleeding (2) or both (2)

** Number of patients unclear

## Comparative Effectiveness of Treatments for CUR: Non-Obstructive Causes

Four small efficacy studies and one systematic review compared treatments for CUR attributed to nonobstructive causes in adults. The systematic review was conducted by the Cochrane Incontinence Group and was assessed as being of good quality. Herbison et al. conducted a systematic review evaluating the efficacy of sacral neuromodulation with implanted devices in individuals with voiding dysfunction.8 They found one RCT that evaluated the efficacy of this intervention in a CUR population. We report the conclusion from that review in lieu of de novo abstraction and analysis of the original research addressing that comparison (Table H5).

Table H5 Description and conclusions from previous systematic review relevant to treatment for CUR from non-obstructive causes

Study Information | Literature Through; SR Quality | Population; Relevant Comparison | Results; Conclusion Strength of Evidence
Herbison 2009^8^ (Cochrane Incontinence Group) Sacral neuromodulation with implanted devices for urinary storage and voiding dysfunction in adults | Literature search through February, 2009 Good | Women with Fowler's syndrome. Immediate/delayed implant (1 trial with CUR patients) | Catheter free: Implant>Delay PVR: Implant>Delay Low

PVR = post void residual; SR=systematic review; UTI = urinary tract infection

We identified four studies that compared treatments for CUR attributed to neurogenic disorders in adults. Summary statistics for these studies appear in Table H6. Three of these studies were RCTs with moderate risk of bias, and one was a controlled before-and-after design with a high risk of bias. All four studies were efficacy trials. Studies enrolled a total of 139 patients with sample sizes ranging from 13 to 86. The mean age of enrolled patients was 54 with a range from 46 to 66. Patient sex was fairly evenly distributed with 51 percent men and 49 percent women. Baseline mean IPSS scores were 21.4 across the two studies that measured IPSS, suggesting a severe level of symptoms. Neurogenic disorders among the patients included MS (64 percent), SCI (7 percent), and other (29 percent). Patients had been living with these neurogenic disorders for an average of 13 years in the three studies reporting. Trials were conducted in Europe and Asia. Three studies compared injections of botulinum A into the sphincter to an inactive control (placebo, lidocaine, usual care). The fourth study compared bethanechol/prostaglandin (BC/PGE2) to placebo.

Table H6 Comparative effectiveness of treatments for CUR from non-obstructive causes: summary of included studies

Number of studies | 4
Randomized controlled trials | 3
Number of patients enrolled (range) | 139 (13 to 86)
Age of subjects, mean years (range) | 54 (46 to 66)
Gender (range) | Men 51% (35 to 92) Women 49% (8 to 65)
Baseline mean IPSS total score (range) (range 0 to 35)^*^ | 21.4 (20.5 to 25.0; 2 studies^†^)
Baseline mean PVR, mL (range) | 277 (219 to 530; 3 studies^†^)
Neurogenic disease etiology | Multiple sclerosis 64% Spinal cord injury 7% Other 29% (stroke, detrusor underactivity)
Neurogenic disease duration, mean years | 12.8 (1.4 to 16.1; 3 studies^†^)
Trials conducted in the United States (% of patients) | None
Trials conducted in Europe (% of patients) | 3 (85)
Trials conducted in Asia (% of patients) | 1 (15)
Studies reporting primary outcomes | 1
Studies reporting secondary outcomes | 4

* IPSS = International Prostate Symptom Score: Scoring criteria are: Mild (score 1-7); Moderate (score 8-19); Severe (score 20-35)

† Number of studies reporting this variable

### Primary Outcomes

Herbison et al. reviewed sacral neuromodulation with implanted devices for urinary storage and voiding dysfunction in adults.8 The Cochrane review addressed one comparison relevant to our review, immediate implant versus a delayed implant (i.e., 6-month waitlist control) in treating CUR from nonobstructive retention. We identified one RCT that studied this comparison. At 6 months post-intervention, a greater proportion of the immediate implant group (19/29) no longer needed catheterization compared to the delayed implant group (2/22) with a relative risk of 7.21 [CI: 1.87-27.73]. Those in the immediate implant group also had significantly lower PVR urine volumes. The Cochrane review concludes that sacral neuromodulation with implanted devices is effective in treating nonobstructive CUR. They do not appear to provide strength of evidence for this conclusion.

Only one study reported a primary outcome (Table H7). Gallien, et al. report the rate of UTI at 6 month followup to be 35 percent in the botulinum patients and 29 percent in the placebo patients.4 This difference was not statistically significant.

Table H7 Comparative effectiveness of treatments for CUR from non-obstructive causes: primary outcomes

Study; Design; Followup | Treatment Arms | Acute Urinary Retention n/N (%) | Urinary Tract Infection n/N (%) | Catheter Outcomes n/N (%)
Gallien 2005^4^ RCT 120 days | botulinum A (n=45) | NR | 16/45 (35.6) | NR
Gallien 2005^4^ RCT 120 days | placebo (n=41) | NR | 12/41 (29.3) | NR
Gallien 2005^4^ RCT 120 days | RR [95% CI] | | 1.21 [0.66 to 2.25]
Hindley 2004^6^ RCT 6 weeks | BC/PGE2 (n=9) | NR | NR | NR
Hindley 2004^6^ RCT 6 weeks | placebo (n=10) | NR | NR | NR
Hindley 2004^6^ RCT 6 weeks | RR [95% CI]
De Seze 2002^7^ RCT 30 days | botulinum A (n=5) | NR | NR | NR
De Seze 2002^7^ RCT 30 days | lidocaine (n=8) | NR | NR | NR
De Seze 2002^7^ RCT 30 days | RR [95% CI]
Chen 2004^5^ Prospective study 6 months | botulinum A (n=11) | NR | NR | NR
Chen 2004^5^ Prospective study 6 months | usual care (n=10) | NR | NR | NR
Chen 2004^5^ Prospective study 6 months | RR [95% CI]

BC/ PGE2 = bethanechol chloride/prostaglandin E2; CI = confidence interval; NR = not reported, RR=risk ratio

### Intermediate Outcomes

All four studies reported on at least one of our prespecified intermediate outcomes. (Table H8). Gallien reports IPSS scores at baseline and at 30 day followup for each treatment group. The mean IPSS score improved by three points in the botulinum group, but the placebo group improved by four points.4 The difference was not significant. In another study of a similar comparison, the botulinum group improved their IPSS mean score by 13 points and the usual care group by only four points.5 However, this study was not blinded and patients were allowed to select their treatments. Two studies reported quality of life using the IPSS quality of life scale. Hindley et al. found that the botulinum group improved by one point, but the placebo group remained unchanged.6 Chen et al. found a significant improvement in the botulinum patients over and above the improvement in the usual care patients.5 Gallien et al., Hindley et al., and de Seze et al. measured PVR at baseline and again at followup. Patients in Gallien et al. had PVRs at baseline of below 300 ml. Both groups showed minimal decreases with no significant difference between groups4. Hindley et al. found PVR decreases in both groups from fairly high baseline levels (over 500ml), but only the botulinum patients showed a significant reduction.6 De Seze et al. also found a significantly greater change in mean PVR in the botulinum group.7

Table H8 Comparative effectiveness of treatments for CUR from non-obstructive causes: intermediate outcomes

Study Design Followup | Treatment Arms | TWOC n/N (%) | IPSS, Mean (SD) Value | Quality of Life Measure | PVR (mL), Mean (SD)
Gallien 2005^4^ RCT 30 days | botulinum A (n=43) | NR | Baseline 21 (7) | NR | Baseline 220 (99)
Gallien 2005^4^ RCT 30 days | | | Endpoint 18 (7) | | Endpoint 186 (158)
Gallien 2005^4^ RCT 30 days | placebo (n=40) | NR | Baseline 20 (7) | NR | Baseline 217 (96)
Gallien 2005^4^ RCT 30 days | | | Endpoint 16 (7) | | Endpoint 206 (145)
Gallien 2005^4^ RCT 30 days | Between group comparison ([95% CI] if applicable) | | Mean difference at endpoint 2.00 [-1.01 to 5.01] | | Mean difference at endpoint -20.00 [-85.19 to 45.19]
Hindley 2004^6^ RCT 6 weeks | BC/PGE2 (n=9) | - | | Baseline^*^ median (range) 4^*^ (3 to 4.5) | Baseline median (range) 426 (405 to 480)
Hindley 2004^6^ RCT 6 weeks | | | | Endpoint^*^ median (range) 3^*^ (2.5 to 3.5) | Endpoint median (range) 325 (290 to 1,252)
Hindley 2004^6^ RCT 6 weeks | placebo (n=10) | | | Baseline^*^ median (range) 3.5^*^ (2 to 4) | Baseline median (range) 575 (539 to 777)
Hindley 2004^6^ RCT 6 weeks | | | | Endpoint^*^ median (range) 3.5^*^ (2.5 to 4) | Endpoint median (range) 537.5 (350 to 1,775)
Hindley 2004^6^ RCT 6 weeks | between group comparison ([95% CI] if applicable) | | | 1 point improvement in active arm, unchanged in placebo arm | Significant improvement from baseline in active arm but not placebo arm
de Sèze 2002^7^ RCT 30 days | botulinum A (n=5) | NR | NR | NR | Baseline 264.4 (141.3)
de Sèze 2002^7^ RCT 30 days | | | | | Endpoint 105.0 (100.6)
de Sèze 2002^7^ RCT 30 days | lidocaine (n=8) | NR | NR | NR | Baseline 313.1 (138.1)
de Sèze 2002^7^ RCT 30 days | | | | | Endpoint 263.3 (115.9)
de Sèze 2002^7^ RCT 30 days | Between group comparison ([95% CI] if applicable) | | | | Mean difference at endpoint -158.30 [-277.57 to -39.03]
Chen 2004^5^ Prospective study 6 months | botulinum A (n=11) | NR | Baseline 27.3 (12.1) | IPSS QoL, baseline 4.7 (1.5) | Baseline 125.5 (88.8)
Chen 2004^5^ Prospective study 6 months | | | Mean change from baseline -13.6 (5.7) | Mean change from baseline 2.4 (1.1) | Endpoint 69.1 (61.4)
Chen 2004^5^ Prospective study 6 months | usual care (n=10) | NR | Baseline 22.5 (11.7) | IPSS, baseline 4.3 (2.1) | NR
Chen 2004^5^ Prospective study 6 months | | | Mean change from baseline -4.1 (5.5) | Mean change from baseline 1.2 (1.0)
Chen 2004^5^ Prospective study 6 months | Between group comparison ([95% CI] if applicable) | | Mean difference at endpoint -9.50 [-14.29 to -4.71] | Mean difference at endpoint -1.20 [-2.10 to -0.30]

BC/ PGE2 = bethanechol chloride/prostaglandin E2; C I= confidence interval; CISC = clean intermittent self-catheterization; IPSS = International Prostate Symptom Score (range 0 [mild symptoms] to 35 [severe symptoms]); NR = not reported; PVR: post-void residual; RCT = randomized controlled trial; RR=risk ratio; SD = standard deviation

* Quality of life scale and range not reported

### Harms

Adverse effects were measured differently in each RCT (Table H9). Adverse effects were rare in all treatment arms. No differences between groups were reported; however, the small sample sizes were likely unable to detect differences in rare events. Strength of evidence was not assessed for harms.

Table H9 Comparative effectiveness of treatments for CUR from non-obstructive causes: adverse events

Study; Design; Followup | Treatment Arms | Serious Adverse Effects n/N (%) | Urinary Leakage/Incontinence n/N (%) | Any Adverse Event n/N (%)
Gallien, 2005^4^ RCT 120 days | botulinum A (n=45) | 3/45 (2.2)^*^ | 2/45 (4.4) | NR
Gallien, 2005^4^ RCT 120 days | placebo (n=41) | 3/41 (2.4)^*^ | 2/41 (4.9) | NR
Gallien, 2005^4^ RCT 120 days | RR [95% CI] | 0.91 [0.19 to 4.26] | 0.91 [0.13 to 6.18]
Hindley, 2004^6^ RCT 6 weeks | BC/PGE2 (n=9) | 0/9 (0.0) | NR | 3/9 (33.3)^**^
Hindley, 2004^6^ RCT 6 weeks | placebo (n=10) | 0/10 (0.0) | NR | 0/10 (0.0)
Hindley, 2004^6^ RCT 6 weeks | RR [95% CI] | - | | 7.70 [0.45 to 131.36]
De Seze 2002^7^ RCT 30 days | botulinum A (n=5) | 0/5 (0.0)^i^ | 0/5 (20.0) | 1/5 (0.0)^†^
De Seze 2002^7^ RCT 30 days | lidocaine (n=8) | 0/8 (12.5)^i^ | 0/8 (0.0)^j^ | 1/8 (0.0)^†^
De Seze 2002^7^ RCT 30 days | RR [95% CI] | - | - | 1.60 [0.13 to 20.22]
Chen 2004^5^ Prospective study 6 months | botulinum A (n=11) | 0/11 (0.0) | NR | NR
Chen 2004^5^ Prospective study 6 months | usual care (n=10) | 0/10 (0.0) | NR | NR
Chen 2004^5^ Prospective study 6 months | RR [95% CI] | -

BC/ PGE2 = bethanechol chloride/prostaglandin E2; CI = confidence interval; NR = not reported; RR=risk ratio

* Uterine leiomyoma, drug induced confusion, and dyspnoea (one patient in the botulinum A toxin group for each event) and pyelonephritis, lumbar radicular pain, and femoral fracture (one patient in the placebo group for each event)

** Symptomatic adverse effects of BC, including mild lower abdominal cramps, diarrhea and increased perspiration.

† Botulinum - transitory exacerbation of per-existing urine incontinence for 2 weeks, lidocaine -anal incontinence one day after injection

## Comparative Effectiveness of CUR Treatments in Adults With Other Causes of CUR

We identified four studies addressing four different comparisons for treatments for CUR from mixed etiologies or etiologies that were not obstructive or neurogenic. One comparison was adequately addressed by a previous systematic reviews. The systematic review was conducted by the Cochrane Incontinence Group. We reviewed the PICOTS and assessed the quality of the review to determine that relevance and quality was sufficient and we identified no new studies comparing the same interventions; therefore, we report conclusions from the relevant systematic review in lieu of de novo abstraction and analysis of the original research addressing that comparison.10 Table H10 summarizes the relevant conclusion from the previous systematic review.

Table H10 Description and conclusions from previous systematic reviews on treatments for CUR in mixed populations/unknown causes

Study Information | Literature Through/SR Quality | Population/Relevant Comparison | Results; Conclusion; Strength of Evidence
Moore, 2007^9^ (Cochrane Incontinence Group) Long-term bladder management by intermittent catheterization in adults and children | Literature search through June 2007 Good | Adults and children with incomplete bladder emptying Sterile technique/clean technique (3 trials; only one with only CUR population) | No significant difference in rates of UTI between groups. insufficient
Herbison, 2009^8^ (Cochrane Incontinence Group) Sacral neuromodulation with implanted devices for urinary storage and voiding dysfunction in adults | Literature search through February 2009 Good | Women with Fowler's syndrome. Immediate/delayed implant (1 trial with CUR patients) | Catheter free: Implant>Delay PVR: Implant>Delay Strength of evidence – not reported; Author's conclude ‘Continuous stimulation offers benefits for urinary retention without obstruction.’

UTI = urinary tract infection; PVR = post void residual urine volume

The relevant comparison from the Moore et al. systematic review compared clean versus sterile intermittent catheterization techniques in individuals needing long-term bladder management.9

Two RCTs also studied efficacy and comparative effectiveness of CUR interventions in mixed or other populations. Datta et al. conducted a crossover RCT in Europe evaluating the efficacy of sildenafil in women suffering from obstructed voiding or retention associated with Fowler's syndrome.12 Tang et al. evaluated intermittent versus indwelling catheterization among elderly women with CUR admitted to a geriatric rehabilitation ward.

### Primary Outcomes

In assessing the data for clean versus sterile catheterization technique, Moore et al. found the data from three studies insufficient to draw conclusions about the comparative rates of UTI.9 Only one of these trials was eligible for our review.10 Because the data from the three trials eligible for the Cochrane review were consistent and this data was assessed insufficient, we reiterate their conclusion of insufficient evidence.

Primary outcomes from the two abstracted studies appear in Table H11. Datta et al. report rates of UTI and successful trial without catheter. Only one patient in either group had a UTI, with no difference between groups.12 Tang reported only one instance of UTI in either group and TWOC was successful in 59 percent of the intermittent catheter patients and in 69 percent of the indwelling catheter patients.13 This difference was not statistically significant.

Table H11 Comparative effectiveness of treatments for CUR in mixed populations/unknown causes: primary outcomes

Study; Design; Followup | Treatment Arms | Acute Urinary Retention n/N (%) | Urinary Tract Infection n/N (%) | Surgical Intervention n/N (%) | IPSS n/N (%) | TWOC n/N (%)
Datta, 2007^12^ Randomized crossover trial 10 weeks | sildenafil citrate (n=20) | NR | 1/20 (0.05) | NR | NR | NR
Tang, 2006^13^ RCT 2 weeks | placebo (n=20) | NR | 0/20 (0.0) | NR | NR | NR
Tang, 2006^13^ RCT 2 weeks | RR [95% CI] | | No statistically significant difference
Tang, 2006^13^ RCT 2 weeks | RR [95% CI] | | 3.73 [0.16 to 88.90] | | | 0.86 [0.59 to 1.25]

CI = confidence interval; IDC = indwelling urinary catheterization; IMC = intermittent urinary catheterization; IPSS = International Prostate Symptom Score (range 0 [mild symptoms] to 35 [severe symptoms]; NR = not reported; RCT = randomized controlled trial; TWOC = successful trial without catheter

### Intermediate Outcomes

Both studies reported several prespecified intermediate outcomes (Table H12). Datta et al. reported before and after data on mean IPSS scores and PVRs. These intermediate outcomes did not improve substantially for either groups and changes from baseline did not differ with statistical significance between sildenafil citrate and placebo patients.12 Tang et al. report substantial reductions in PVRs after 2 weeks with indwelling versus intermittent catheter; however, the difference was not statistically significant.13

Table H12 Comparative effectiveness of treatments for CUR in mixed populations/unknown causes: intermediate outcomes

Study; Design; Followup | Treatment Arms | IPSS, Mean (SD) Value | Quality of Life Measure | PVR (mL), Mean (SD)
Datta, 2007^12^ Randomized crossover trial 10 weeks | sildenafil citrate (n=20) | Baseline 21.5^*^ [20 to 23] | NR | Baseline 140^*^ [90 to 180]
Datta, 2007^12^ Randomized crossover trial 10 weeks | | Mean change from baseline -3.6 | | Endpoint 90^*^ [70 to 120]
Datta, 2007^12^ Randomized crossover trial 10 weeks | placebo (n=20) | Baseline 21.5^*^ [20 to 23] | NR | Baseline 140^*^ [90 to180]
Datta, 2007^12^ Randomized crossover trial 10 weeks | | Endpoint 19^*^ [18 to 20] | | Endpoint 99^*^ [70 to 130]
Datta, 2007^12^ Randomized crossover trial 10 weeks | Between group comparison ([95% CI] if applicable) | Mean difference at endpoint. No statistically significant difference | | Mean difference at endpoint: no statistically significant difference
Tang, 2006^13^ RCT 2 weeks | IMC (n=27) | NR | NR | Baseline 539.8 (219.7)
Tang, 2006^13^ RCT 2 weeks | | | | Endpoint 54.4 (49.1)
Tang, 2006^13^ RCT 2 weeks | IDC (n=39) | NR | NR | Baseline 545.9 (187.2)
Tang, 2006^13^ RCT 2 weeks | | | | Endpoint 77.6 (48.2)
Tang, 2006^13^ RCT 2 weeks | Between group comparison ([95% CI] if applicable) | | | Mean difference at endpoint -23.20 [-47.03 to 0.63]

IDC = indwelling urinary catheterization; IMC = intermittent urinary catheterization; NR = no response; SD = standard deviation

* Extracted from graph

### Harms

Adverse effects were measured differently in each RCT (Table H13). These events were rare, and results did not differ between treatment groups.

Table H13 Comparative effectiveness of treatments for CUR in mixed populations/unknown causes: adverse events

Study; Design; Followup | Treatment Arms | Death n/N (%) | Clinical Deterioration n/N (%) | Urinary Leakage/Incontinence n/N (%) | Total Adverse Events n/N (%)
Datta, 2007^12^ Randomized crossover trial 10 weeks | sildenafil citrate (n=20) | 0/20 (0.0) | NR | 0/20 (0.0) | 14/20 (0.7)
Datta, 2007^12^ Randomized crossover trial 10 weeks | Placebo (n=20) | 1/20 (0.05) | NR | 1/20 (0.05) | 14/20 (0.7)
Datta, 2007^12^ Randomized crossover trial 10 weeks | RR [95% CI] | No statistically significant difference | | No statistically significant difference | No statistically significant difference
Tang, 2006^13^ RCT 2 weeks | IMC (n=36) | 0/36 (0.0) | 4/36 (11.1) | NR | NR
Tang, 2006^13^ RCT 2 weeks | IDC (n=45) | 2/45 (4.4) | 1/45 (2.2) | NR | NR
Tang, 2006^13^ RCT 2 weeks | RR [95% CI] | 0.25 [0.01 to 5.02] | 5.00 [0.58 to 42.80]

IDC = indwelling urinary catheterization; IMC = intermittent urinary catheterization; NR = not reported; RR=risk ratio

* Based on number of urine cultures sent on day 14.

## References for Appendix H

1 Ghalayini IF, Al-Ghazo MA, Pickard RS. A prospective randomized trial comparing transurethral prostatic resection and clean intermittent self-catheterization in men with chronic urinary retention. BJU International. Jul. 2005;96(1):93-7. [pmid: 15963128].
2 Gujral S, Abrams P, Donovan JL, et al. A prospective randomized trial comparing transurethral resection of the prostate and laser therapy in men with chronic urinary retention: The CLasP study. Journal of Urology. Jul. 2000;164(1):59-64. [pmid: 10840425].
3 Schelin S, Geertsen U, Walter S, et al. Feedback microwave thermotherapy versus TURP/prostate enucleation surgery in patients with benign prostatic hyperplasia and persistent urinary retention: a prospective, randomized, controlled, multicenter study. Urology. Oct. 2006;68(4):795-9. [pmid: 17070355].
4 Gallien P, Reymann JM, Amarenco G, et al. Placebo controlled, randomised, double blind study of the effects of botulinum A toxin on detrusor sphincter dyssynergia in multiple sclerosis patients. Journal of Neurology, Neurosurgery & Psychiatry. Dec. 2005;76(12):1670-6. [pmid: 16291892].
5 Chen YH, Kuo HC. Botulinum A toxin treatment of urethral sphincter pseudodyssynergia in patients with cerebrovascular accidents or intracranial lesions. Urologia Internationalis. 2004;73(2):156-61. discussion 61-2. [pmid: 15331901].
6 Hindley RG, Brierly RD, Thomas PJ. Prostaglandin E2 and bethanechol in combination for treating detrusor underactivity. BJU International. Jan. 2004;93(1):89-92. [pmid: 14678375].
7 de Seze M, Petit H, Gallien P, et al. Botulinum a toxin and detrusor sphincter dyssynergia: a double-blind lidocaine-controlled study in 13 patients with spinal cord disease. European Urology. Jul. 2002;42(1):56-62. [pmid: 12121731].
8 Herbison GP, Arnold EP. Sacral neuromodulation with implanted devices for urinary storage and voiding dysfunction in adults. Cochrane Database of Systematic Reviews. 2009;(2). CD004202. [pmid: 19370596].
9 Moore K, Fader M, Getliffe K. Long-term bladder management by intermittent catheterisation in adults and children. John Wiley & Sons, Ltd. 2007. http://onlinelibrary.wiley.com/doi/10.1002/14651858.CD006008.pub2/abstract. 4.
10 Duffy LM, Cleary J, Ahern S, et al. Clean intermittent catheterization: safe, cost-effective bladder management for male residents of VA nursing homes. Journal of the American Geriatrics Society. Aug. 1995;43(8):865-70. [pmid: 7636093].
11 Jonas U, Fowler CJ, Chancellor MB, et al. Efficacy of sacral nerve stimulation for urinary retention: results 18 months after implantation. Journal of Urology. Jan. 2001;165(1):15-9. [pmid: 11125353].
12 Datta SN, Kavia RB, Gonzales G, et al. Results of double-blind placebo-controlled crossover study of sildenafil citrate (Viagra) in women suffering from obstructed voiding or retention associated with the primary disorder of sphincter relaxation (Fowler's Syndrome). European Urology. Feb. 2007;51(2):489-95. discussion 95-7. [pmid: 16884844].
13 Tang MW, Kwok TC, Hui E, et al. Intermittent versus indwelling urinary catheterization in older female patients. Maturitas. Feb. 20. 2006;53(3):274-81. [pmid: 16084677].