# Risk of Bias and Quality

Table G1 Risk of bias of included original research

Study | Outcome | Risk of Selection Bias Due to Inadequate Randomization | Risk of Selection Bias Due to Inadequate Allocation | Risk of Performance Bias Due to Inadequate Blinding of Provider and Patient | Risk of Detection Bias Due to Inadequate Blinding | Risk of Attrition Bias | Risk of Reporting Bias Due to Selective Outcome Reporting | Intent To Treat | Groups Similar at Baseline | Other Risks of Bias | Overall Risk of Bias per Study-Outcome
RCTs
Datta 2007^1^ | UTI | Unclear | Unclear | Low | Unclear | Low | Low | Yes | Yes | No | Moderate
Datta 2007^1^ | IPSS | Unclear | Unclear | Low | Unclear | Low | Low | Yes | Yes | No | Moderate
Datta 2007^1^ | PVR | Unclear | Unclear | Low | Unclear | Low | Low | Yes | Yes | No | Moderate
Schelin 2006^2^ | UTI | Unclear | High | High | Unclear | Low | Low | Unclear | Yes | No | Moderate
Schelin 2006^2^ | Cath Free | Unclear | High | High | Unclear | Low | Low | Unclear | Yes | No | Moderate
Schelin 2006^2^ | IPSS | Unclear | High | High | Unclear | Low | Low | Unclear | Yes | No | Moderate
Schelin 2006^2^ | IPSS QoL | Unclear | High | High | Unclear | Low | Low | Unclear | Yes | No | Moderate
Tang 2006^3^ | UTI | Low | Unclear | High | High | Low | Low | Yes | Yes | No | Moderate
Tang 2006^3^ | TWOC | Low | Unclear | High | High | Low | Low | Yes | Yes | No | Moderate
Tang 2006^3^ | PVR | Low | Unclear | High | High | Low | Low | Yes | Yes | No | Moderate
Gallien 2005^4^ | UTI | Low | Low | Low | Unclear | Low | Low | Yes | Yes | Yes | Moderate
Gallien 2005^4^ | IPSS | Low | Low | Low | Unclear | Low | Low | Yes | Yes | Yes | Moderate
Gallien 2005^4^ | PVR | Low | Low | Low | Unclear | Low | Low | Yes | Yes | Yes | Moderate
Ghalayini 2005^5^ | IPSS | High | Unclear | High | High | Low | Low | Yes | No | No | Moderate
Ghalayini 2005^5^ | PVR | High | Unclear | High | High | Low | Low | Yes | No | No | Moderate
Hindley 2004^6^ | QoL | High | Unclear | Low | Unclear | Low | Low | Yes | No | No | High
Hindley 2004^6^ | PVR | High | Unclear | Low | Unclear | Low | Low | Yes | No | No | Moderate
de Sèze 2002^7^ | PVR | Low | Unclear | Low | Unclear | Low | Low | Yes | Yes | No | Moderate
Gujral 2000^8^ | UTI | High | Low | High | Unclear | Low | Low | Yes | No | Yes | High
Gujral 2000^8^ | IPSS Category, adjusted | High | Low | High | Unclear | Low | Low | Yes | No | No | Moderate
Gujral 2000^8^ | PVR, adjusted | High | Low | High | Unclear | Low | Low | Yes | No | No | Moderate
Cohort
Chen 2004^9^ | IPSS | High | NA | NA | NA | NA | Low | Low | Unclear | Yes^1^ | High
Chen 2004^9^ | IPSS QoL | High | NA | NA | NA | NA | Low | Low | Unclear | Yes^1^ | High
Chen 2004^9^ | PVR | High | NA | NA | NA | NA | Low | Low | Unclear | Yes^1^ | High

IPSS = International Prostate Symptom Score; PVR: post-void residual urine volume; QoL = quality of life.

1 No adjustments for selection bias during analysis.

Table G2 Quality of previous systematic reviews

Study | A priori Study Design | Dual Study Selection and Data Abstraction | Comprehensive literature search | Publication Status | Lists of Included and Excluded Studies Provided? | Scientific Quality of Included Studies Assessed and Documented? | Scientific Quality of Included Studies Used Appropriately in Formulating Conclusions? | Methods of Combining Studies Appropriate? | Likelihood of Publication Bias Assessed? | Conflict of Interest Stated? | Overall Quality
Moore 2007^1^ | yes | yes | yes | yes | yes | yes | yes | yes | Unclear | yes | good
Herbison 2009^2^ | yes | yes | yes | yes | yes | yes | yes | yes | Unclear | yes | good

## References for Table G1

1 Datta SN, Kavia RB, Gonzales G, et al. Results of double-blind placebo-controlled crossover study of sildenafil citrate (Viagra) in women suffering from obstructed voiding or retention associated with the primary disorder of sphincter relaxation (Fowler's Syndrome). European Urology. Feb. 2007;51(2):489-95. discussion 95-7. [pmid: 16884844].
2 Schelin S, Geertsen U, Walter S, et al. Feedback microwave thermotherapy versus TURP/prostate enucleation surgery in patients with benign prostatic hyperplasia and persistent urinary retention: a prospective, randomized, controlled, multicenter study. Urology. Oct. 2006;68(4):795-9. [pmid: 17070355].
3 Tang MW, Kwok TC, Hui E, et al. Intermittent versus indwelling urinary catheterization in older female patients. Maturitas. Feb. 20. 2006;53(3):274-81. [pmid: 16084677].
4 Gallien P, Reymann JM, Amarenco G, et al. Placebo controlled, randomised, double blind study of the effects of botulinum A toxin on detrusor sphincter dyssynergia in multiple sclerosis patients. Journal of Neurology, Neurosurgery & Psychiatry. Dec. 2005;76(12):1670-6. [pmid: 16291892].
5 Ghalayini IF, Al-Ghazo MA, Pickard RS. A prospective randomized trial comparing transurethral prostatic resection and clean intermittent self-catheterization in men with chronic urinary retention. BJU International. Jul. 2005;96(1):93-7. [pmid: 15963128].
6 Hindley RG, Brierly RD, Thomas PJ. Prostaglandin E2 and bethanechol in combination for treating detrusor underactivity. BJU International. Jan. 2004;93(1):89-92. [pmid: 14678375].
7 de Seze M, Petit H, Gallien P, et al. Botulinum a toxin and detrusor sphincter dyssynergia: a double-blind lidocaine-controlled study in 13 patients with spinal cord disease. European Urology. Jul. 2002;42(1):56-62. [pmid: 12121731].
8 Gujral S, Abrams P, Donovan JL, et al. A prospective randomized trial comparing transurethral resection of the prostate and laser therapy in men with chronic urinary retention: The CLasP study. Journal of Urology. Jul. 2000;164(1):59-64. [pmid: 10840425].
9 Chen YH, Kuo HC. Botulinum A toxin treatment of urethral sphincter pseudodyssynergia in patients with cerebrovascular accidents or intracranial lesions. Urologia Internationalis. 2004;73(2):156-61. discussion 61-2. [pmid: 15331901].

## References for Table G2

1 Moore Katherine N, Fader M, Getliffe K. Long-term bladder management by intermittent catheterisation in adults and children. John Wiley & Sons, Ltd. 2007. http://onlinelibrary.wiley.com/doi/10.1002/14651858.CD006008.pub2/abstract. 4.
2 Herbison GP, Arnold EP. Sacral neuromodulation with implanted devices for urinary storage and voiding dysfunction in adults. Cochrane Database of Systematic Reviews. 2009;(2). CD004202. [pmid: 19370596].