# Description and Characteristics of Included Studies

Table F1 Characteristics of included studies

Author, Year, Funding, Design | Inclusion/Exclusion Criteria | Patient Characteristics | CUR Characteristics | CUR Urodynamics/Severity (Expressed in means unless noted) | Risk of Bias
Datta, 2007^1^ UK Grant RCT N=20 | Inclusion criteria: women aged 18-65 year suffering with complete or partial retention or obstructive voiding. Exclusion criteria: major hematologic, renal, or hepatic impairment and major psychiatric disorders not well controlled by treatment; significant cardiovascular disease and a history of stroke or myocardial infarction in the previous 6 months; resting blood pressure over 90/50mmHg and 180/110 mmHg; known history of retinitis pigmentosa; uses of nitrates or NO donors | Age, mean: 39 Gender: women 100% Race: NR Comorbidities: NR Intervention: sildenafil citrate Control: placebo | Definition/etiology max flow rate <15ml/min, max urethral closure pressure 92-age cmH_2_O, sphincter volume >1.6 cm^3^ Fowler's syndrome Concurrent treatment: NR Previous treatments: NR | PVR (ml): 140 IPSS: 21.5 MUCP (cmH_2_O): 106.6 Sphincter volume (cm^3^): 2.1 Detrusor pressure at qmax (cmH_2_O): 35.2 Voiding time (sec): 90.5 | Overall risk of bias: medium
Schelin, 2006^2^ Sweden, Denmark, and Norway Not reported RCT N=120 | Inclusion criteria: patients ≥45 years, with symptomatic BPH and persistent urinary retention requiring an indwelling catheter or clean intermittent catheterization for at least 1 month before screening. Exclusion criteria: Patients who were medically and/or psychologically unable to tolerate surgery | Intervention: ProstaLund feedback treatment n=61 Age, mean: 73 Gender: men 100% Race: NR Comorbidities: NR Control: TURP or prostate enucleation surgery n=59 Age, mean: 73 Gender: men 100% Race: NR Comorbidities: NR | Definition/etiology: PVR ≥300 ml BPH Concurrent treatment: NR Previous treatments: NR | Intervention: PLFT Indwelling catheter: 87% Catheterization Control: TURP and prostate enucleation surgery Indwelling catheter: 86% Catheterization | Overall risk of bias: medium
Tang, 2006^3^ Hong Kong, China Not reported RCT N=81 | Inclusion criteria: female patients ≥65 years of age admitted to a female geriatric rehabilitation ward with PVR over ≥300 ml on two occasions Exclusion criteria: terminally ill or those who required an indwelling urinary catheter for urine output monitoring. | Intervention: intermittent urinary catheterization n=36 Age, mean: 80 Gender: women 100% Race: NR Mean Barthel index (baseline disability) (out of 20): 7.8 Comorbidities: NR Control: indwelling urinary catheterization n=45 Age, mean: 81 Gender: women 100% Race: NR Mean Barthel index (baseline disability) (out of 20): 6.2 Comorbidities: NR | Definition/etiology PVR persistently ≥300 ml Concurrent treatment: diuretics: 25% calcium channel blockers: 11% anticholinergic agents:19% alpha-blockers: 3% distigmine bromide: 0% Previous treatments: NR | Intervention: PVR (ml): 545.9 Past history of urinary retention: 6% Control: PVR (ml): 539.8 Past history of urinary retention: 0% | Overall risk of bias: medium
Gallien, 2005^4^ France Not for profit organizations RCT N=86 | Inclusion criteria: Patients >18 years of age and suffering from MS with DSD. The diagnosis of MS had to have been made according to Poser criteria at least 6 months before inclusion Exclusion criteria: Urine or prostate febrile infection, perineal skin disorders, or myasthenia, or if they took any treatment which could have altered neuromuscular transmission. Pregnant women or non-menopausal women who did not take effective contraception were also excluded. | Intervention: botulinum A toxin n=45 Age, mean: 50 Gender: men 38% Race: NR Expanded disability status scale: 5.4 Comorbidities: NR Time from onset of urinary disorders (months): 98 Incontinence: 78% Control: placebo n=41 Age, mean: 51 Gender: men 27% Race: NR Expanded disability status scale: 6.0 Comorbidities: NR Time from onset of urinary disorders (months): 111 Incontinence: 83% | Definition/etiology: Patients with CUR were included if they had PVR between 100 and 500 ml. Concurrent treatment: Patients were prescribed an alpha blocker (5 mg tablet of slow release alfuzosin bid) over 4 months. Previous treatments: Alpha blocker use before inclusion: 56% | Intervention: botulinum A toxin PVR (ml): 220 Peak urine flow(ml/s): 13 IPSS: 21 Voiding volume (ml): 135 Blaivas's classification of DSD: Type 2: 40% Type 3: 44% Control: placebo PVR (ml): 217 Peak urine flow (ml/s): 16 IPSS: 20 Voiding volume (ml): 166 Blaivas's classification of DSD: Type 2: 34% Type 3: 44% | Overall risk of bias: medium
Ghalayini, 2005^5^ Jordan Not reported RCT N=41 | Inclusion criteria: men with LUTS and an IPSS of >7, together with CUR, defined as a PVR of >300 ml measured by ultrasonography on two occasions, with patients and physicians agreeing that the findings justified intervention. Exclusion criteria: clinical evidence of prostate cancer, infection, previous prostatic surgery, uncontrolled renal impairment, a life-expectancy of <6 months, proven neurological bladder dysfunction, or inability to practice CISC. | Intervention: transurethral resection of the prostate (TURP) n=17 Age, mean: 67 Gender: men 100% Race: NR Comorbidities: NR Control: Clean intermittent self-catheterization (CISC) n=24 Age, mean: 69 Gender: men 100% Race: NR Comorbidities: NR | Definition/etiology: PVR of >300 ml Concurrent treatment: All had a 4-6-week period of indwelling catheterization to stabilize renal function before starting the allocated management Previous treatments: NR | Intervention: IPSS: 25.8 IPSS QoL: 4.4 PVR (ml): 954 Control: IPSS: 23.2 IPSS QoL: 4.2 PVR (ml): 963 | Overall risk of bias: medium
Chen, 2004^6^ Taiwan, China Grant Prospective study | Inclusion criteria: Patients with chronic cerebrovascular accidents or intracranial lesions were enrolled. All patients had symptoms of severe difficulty in initiation of urination or urinary retention. Exclusion criteria: NR | N=21 Intervention: botulinum A toxin n=11 Age, mean: 67 Gender: men 45% Race: NR Comorbidities: Stroke: 73% Intracranial hemorrhage:18% Meningitis: 9% Detrusor hyperreflexia: 91% Detrusor underactivity: 9% Urethral sphincter pseudodyssynergia: 100% Control: usual care n=10 Age, mean: 65 Gender: men 70% Race: NR Comorbidities: Stroke: 100% Detrusor hyperreflexia: 80% Detrusor underactivity: 20% | Definition/etiology: NR Concurrent treatment: NR Previous treatments: Medications such as α-blockers, skeletal muscle relaxants, or nitric oxide donors without remarkable effect. | Intervention: PVR (ml): 126 IPSS: 27.3 QoL: 4.7 Control: PVR (ml): NR IPSS: 22.5 QoL: 4.3 | Overall risk of bias: medium
Hindley 2004^7^ UK Not reported RCT N=19 | [underlined: Inclusion criteria:] Patients with suspected detrusor underactivity. [underlined: Exclusion criteria]: Asthma, hyperthyroidism, severe bradycardia, hypotension, recent myocardial infarction, bowel obstruction, active peptic ulcer disease, epilepsy, parkinsonism and evidence of serious concomitant psychiatric disease. Patients who were categorized as obstructed on the nomogram were also excluded from the study (all patients had an Abrams-Griffiths number of <40). | [underlined: Intervention:] bethanechol chloride (BC) plus prostaglandin E2 (PGE2) n=9 Age, mean: 67 Gender: men 89% Race: NR Comorbidities: bladder neck incision: 22% TURP: 33% interstitial radiofrequency therapy to the prostate: 11% chronic retention: 11% [underlined: Control:] placebo n=10 Age, mean: 64 Gender: men 90% Race: NR Comorbidities: Bladder neck incision: 10% TURP: 30% Chronic retention: 40% | [underlined: Definition/etiology:] PVR consistently >300ml in the absence of BOO. [underlined: Concurrent treatment]: NR [underlined: Previous treatments:] NR | [underlined: Intervention:] Frequency of CISC/day: 2.22 CISC volume drained (ml): 381.25 PVR (ml), median: 426 [underlined: Control:] Frequency of CISC/day: 2.70 CISC volume drained (ml): 505 PVR (ml), median: 575.5 | Overall risk of bias: medium
de Sèze, 2002^8^ France The Coloplast Foundation for quality of life RCT N=13 | [underlined: Inclusion criteria]: presence of DSD in patients affected by upper motor neuron type bladder dysfunction due to medical (MS, myelitis) or traumatic spinal disease which was neurologically stable (i.e., no progression in neurological symptoms in the previous 3 months). [underlined: Exclusion criteria:] pregnancy, blood coagulation, abnormalities, inflammation or infection of the injection site, myasthenia, aminoglycoside treatment, hypersensitivity to botulinum toxin or lidocaine, lidocaine contraindications and lower motor neuron perineal lesion. | [underlined: Intervention]: botulinum A toxin n=5 Age, mean: 41 Gender: men 80% Race: NR Comorbidities: Spinal cord injury: 80% MS: 20% [underlined: Control]: lidocaine n=8 Age, mean: 49 Gender: men 100% Race: NR Comorbidities: Spinal cord injury: 63% MS: 25% Dural fistulization: 12.5% | [underlined: Definition/etiology]: PVR >100 ml [underlined: Concurrent treatment]: No concurrent treatments [underlined: Previous treatments]: NR | [underlined: Intervention:] PVR (ml): 264.4 MUP (cmH_2_O): 109.4 Blaivas's classification of DSD: Type 3: 40% Type 2: 40% Type 1: 20% DP (cmH_2_O): 74.2 [underlined: Control:] PRV (ml): 313.1 MUP (cmH_2_O): 83.2 Blaivas's classification of DSD: Type 3: 38% Type 2: 62% DP (cmH_2_O): 88.6 | Overall risk of bias: medium
Gujral, 2000^9^ UK Government (NHS) RCT N=82 | Inclusion criteria: LUTS with an IPSS) ≥8 indicating moderate to severe symptoms. Patients had a urinary flow rate of <15, <13, <10 ml/s when voided volume was >200, between 150 and 200, and between 100 and 149 ml, as measured on at least 2 occasions. Exclusion criteria: Clinically diagnosed prostate cancer, previous prostatic surgery, life expectancy <6 months, neuropathic bladder dysfunction, serum creatinine >250 mmol, abnormal upper tracts on renal tract ultrasonography or a prostate volume >120 cc, men on long-term active medication for the lower urinary tract. | Intervention: Transurethral prostatic resection n=44 Age, mean:71 Gender: men 100% Race: white 100% Comorbidities: NR Control: Laser therapy n=38 Age, mean: 70 Gender: men 100% Race: white 100% Comorbidities: NR | Definition/etiology: PVR >300 ml BPH Concurrent treatment: NR Previous treatments: NR | Intervention: PVR (ml): 545 IPSS: 19.5 IPSS quality of life score, median: 4.5 Peak urine flow (ml/s): 8.5 Control: Laser therapy PVR (ml): 438 IPSS: 20.9 IPSS quality of life score, median: 5.0 Peak urine flow (ml/s): 11.2 | Overall risk of bias: medium

BOO = bladder outflow obstruction; BPH = benign prostatic hyperplasia; BPO = benign prostatic obstruction; CISC = clean intermittent self-catheterization; CUR = chronic urinary retention; DP = detrusor pressure; DSD = detrusor sphincter dyssynergia; IPSS = International Prostate Symptom Score; LUTS = lower urinary tract symptoms; MS = multiple sclerosis; MUCP = maximal urethral closure pressure; MUP = maximal urethral pressure; NR = not reported; PLFT = ProstaLund Feedback Treatment; PVR = post-voiding residual urine volume; TURP = transurethral resection of the prostate; UTI = urinary tract infection

## References for Appendix F

1 Datta SN, Kavia RB, Gonzales G, et al. Results of double-blind placebo-controlled crossover study of sildenafil citrate (Viagra) in women suffering from obstructed voiding or retention associated with the primary disorder of sphincter relaxation (Fowler's Syndrome). European Urology. Feb. 2007;51(2):489-95. discussion 95-7. [pmid: 16884844].
2 Schelin S, Geertsen U, Walter S, et al. Feedback microwave thermotherapy versus TURP/prostate enucleation surgery in patients with benign prostatic hyperplasia and persistent urinary retention: a prospective, randomized, controlled, multicenter study. Urology. Oct. 2006;68(4):795-9. [pmid: 17070355].
3 Tang MW, Kwok TC, Hui E, et al. Intermittent versus indwelling urinary catheterization in older female patients. Maturitas. Feb. 20. 2006;53(3):274-81. [pmid: 16084677].
4 Gallien P, Reymann JM, Amarenco G, et al. Placebo controlled, randomised, double blind study of the effects of botulinum A toxin on detrusor sphincter dyssynergia in multiple sclerosis patients. Journal of Neurology, Neurosurgery & Psychiatry. Dec. 2005;76(12):1670-6. [pmid: 16291892].
5 Ghalayini IF, Al-Ghazo MA, Pickard RS. A prospective randomized trial comparing transurethral prostatic resection and clean intermittent self-catheterization in men with chronic urinary retention. BJU International. Jul. 2005;96(1):93-7. [pmid: 15963128].
6 Chen YH, Kuo HC. Botulinum A toxin treatment of urethral sphincter pseudodyssynergia in patients with cerebrovascular accidents or intracranial lesions. Urologia Internationalis. 2004;73(2):156-61. discussion 61-2. [pmid: 15331901].
7 Hindley RG, Brierly RD, Thomas PJ. Prostaglandin E2 and bethanechol in combination for treating detrusor underactivity. BJU International. Jan. 2004;93(1):89-92. [pmid: 14678375].
8 de Seze M, Petit H, Gallien P, et al. Botulinum a toxin and detrusor sphincter dyssynergia: a double-blind lidocaine-controlled study in 13 patients with spinal cord disease. European Urology. Jul. 2002;42(1):56-62. [pmid: 12121731].
9 Gujral S, Abrams P, Donovan JL, et al. A prospective randomized trial comparing transurethral resection of the prostate and laser therapy in men with chronic urinary retention: The CLasP study. Journal of Urology. Jul. 2000;164(1):59-64. [pmid: 10840425].