# Excluded Studies

## Original Research Excluded

Yi WM, Pan AZ, Li JJ, et al. Clinical observation on the acupuncture treatment in patients with urinary retention after radical hysterectomy. Chinese Journal of Integrative Medicine. Nov. 2011;17(11):860-3. Not CUR population. [pmid: 21809126].
Hakvoort RA, Thijs SD, Bouwmeester FW, et al. Comparing clean intermittent catheterisation and transurethral indwelling catheterisation for incomplete voiding after vaginal prolapse surgery: a multicentre randomised trial. BJOG: An International Journal of Obstetrics & Gynaecology. Aug. 2011;118(9):1055-60. Not CUR population. [pmid: 21481147].
Chartier-Kastler E, Lauge I, Ruffion A, et al. Safety of a new compact catheter for men with neurogenic bladder dysfunction: a randomised, crossover and open-labelled study. Spinal Cord. Jul. 2011;49(7):844-50. Not CUR population. [pmid: 21339763].
Autorino R, Damiano R, Di Lorenzo G, et al. Four-year outcome of a prospective randomised trial comparing bipolar plasmakinetic and monopolar transurethral resection of the prostate. European Urology. Apr. 2009;55(4):922-9. Not CUR population. [pmid: 19185975].
Bjerklund Johansen T, Hultling C, Madersbacher H, et al. A novel product for intermittent catheterisation: its impact on compliance with daily life--international multicentre study. European Urology. Jul. 2007;52(1):213-20. Not eligible study design. [pmid: 17166653].
Yamanishi T, Yasuda K, Kamai T, et al. Combination of a cholinergic drug and an alpha-blocker is more effective than monotherapy for the treatment of voiding difficulty in patients with underactive detrusor. International Journal of Urology. Feb. 2004;11(2):88-96. Not CUR population. [pmid: 14706012].
McNeill SA, Hargreave TB, Geffriaud-Ricouard C, et al. Postvoid residual urine in patients with lower urinary tract symptoms suggestive of benign prostatic hyperplasia: pooled analysis of eleven controlled studies with alfuzosin. Urology. Mar. 2001;57(3):459-65. Not CUR population. [pmid: 11248620].
Bernier F, Davila GW. The treatment of nonobstructive urinary retention with high-frequency transvaginal electrical stimulation. Urologic Nursing. Aug. 2000;20(4):261-4. Not eligible study design. [pmid: 11998089].
Lukkarinen O, Hellstrom P, Leppilahti M, et al. Antibiotic prophylaxis in patients with urinary retention undergoing transurethral prostatectomy. Annales Chirurgiae et Gynaecologiae. 1997;86(3):239-42. Not a treatment for CUR. [pmid: 9435936].
Belzner S. Eucalyptus oil dressings in urinary retention. Pflege Aktuell. Jun. 1997;51(6):386-7. Not available in English. [pmid: 9287850].
Mompo Sanchis JA, Paya Navarro JJ, Prosper Rovira F. Transurethral thermotherapy with microwaves in patients with benign prostatic hypertrophy and urinary retention: comparative study between high energy (25) and standard energy (2.0). Archivos Espanoles de Urologia. May. 1996;49(4):337-46. Not available in English. [pmid: 8754190].
King RB, Carlson CE, Mervine J, et al. Clean and sterile intermittent catheterization methods in hospitalized patients with spinal cord injury. Archives of Physical Medicine & Rehabilitation. Sep. 1992;73(9):798-802. Not CUR population. [pmid: 1514886].
Abrams PH, Shah PJ, Gaches CG, et al. Role of suprapubic catheterization in retention of urine. Journal of the Royal Society of Medicine. Dec. 1980;73(12):845-8. Not CUR population. [pmid: 7005439].

## Systematic Reviews Excluded

Barendrecht MM, Oelke M, Laguna MP, et al. Is the use of parasympathomimetics for treating an underactive urinary bladder evidence-based?. BJU International. Apr. 2007;99(4):749-52. Not Relevant. [pmid: 17233798].
Chartier-Kastler E, Denys P. Intermittent catheterization with hydrophilic catheters as a treatment of chronic neurogenic urinary retention. Neurourology & Urodynamics. Jan. 2011;30(1):21-31. Not SR. [pmid: 20928913].
Getliffe K, Fader M, Allen C, et al. Current evidence on intermittent catheterization: sterile single-use catheters or clean reused catheters and the incidence of UTI. Journal of Wound, Ostomy, & Continence Nursing. May-Jun. 2007;34(3):289-96. Not Relevant. [pmid: 17505249].
Hagen S, Stark D. Conservative prevention and management of pelvic organ prolapse in women. John Wiley & Sons, Ltd. 2011. http://onlinelibrary.wiley.com/doi/10.1002/14651858.CD003882.pub4/abstract. Not Relevant.
Jahn P, Beutner K, Langer G. Types of indwelling urinary catheters for long-term bladder drainage in adults. John Wiley & Sons, Ltd. 2012. http://onlinelibrary.wiley.com/doi/10.1002/14651858.CD004997.pub3/abstract. Not Relevant.
Jamison J, Maguire S, McCann J. Catheter policies for management of long term voiding problems in adults with neurogenic bladder disorders. John Wiley & Sons, Ltd. 2011. http://onlinelibrary.wiley.com/doi/10.1002/14651858.CD004375.pub3/abstract. Not Relevant.
Lefevre F, Civic D, Aronson N, et al. Percutaneous tibial nerve stimulation for the treatment of voiding dysfunction. Technology Evaluation Center Assessment Program. Mar. 2011;25(8):1-7. Not Relevant. [pmid: 21638944].
Mehta S, Hill D, Foley N, et al. A meta-analysis of botulinum toxin sphincteric injections in the treatment of incomplete voiding after spinal cord injury. Archives of Physical Medicine & Rehabilitation. Apr. 2012;93(4):597-603. Not Relevant. [pmid: 22365478].
Moore KN, Burt J, Voaklander DC. Itermittent catheterization in the rehabilitation setting: a comparison of clean and sterile technique. Clinical rehabilitation. 2006;20(6):461-8. Not Relevant. [pmid: 16892928].
Utomo E, Blok B. Surgical management of functional bladder outlet obstruction in adults with neurogenic bladder dysfunction. John Wiley & Sons, Ltd. 2011. http://onlinelibrary.wiley.com/doi/10.1002/14651858.CD004927.pub3/abstract. Not Relevant.