# Inclusion Criteria

Table D1 Study inclusion criteria

Category | Criteria for Inclusion
Study enrollment | Studies that enroll adults with CUR and test the effectiveness of treatments for CUR.
Study design | Meta-analyses, systematic reviews, RCTs, and nonrandomized controlled trials for each population and treatment option. Controlled before and after studies for KQs that cannot be answered using trial data alone.
Time of publication | Search all literature from 1946 forward.
Study quality | For all studies meeting inclusion criteria after title and abstract review, the full articles were screened for eligibility; studies of any risk of bias level were included.
Language of publication | Given that literature on this topic published in English best represents interventions available and accessible in the United States, we limited inclusion to studies with full text published in English. However, we did not limit our search based on language so that potential language bias could be assessed.

CUR = chronic urinary retention; KQ = key question; RCT = randomized controlled trial