# Search Strategy

## MEDLINE

Database: Ovid MEDLINE(R) <1946 to November Week 3 2012> Search Strategy:

1. exp *Urinary Retention/ (1930)
2. “urinary retention”.ti,ab. (5318)
3. “voiding dysfunction”.ti,ab. (1312)
4. “incomplete voiding”.ti,ab. (50)
5. “voiding difficult*”.ti,ab. (423)
6. “underactive bladder”.ti,ab. (27)
7. “incomplete bladder empt*”.ti,ab. (117)
8. “elevated post void residual”.ti,ab. (13)
9. ischuria.ti,ab. (29)
10. or/1-9 (7624)
11. limit 10 to “all child (0 to 18 years)” (1408)
12. limit 11 to “all adult (19 plus years)” (560)
13. 10 not 11 (6216)
14. 12 or 13 (6776)
15. limit 14 to animals (370)
16. 14 not 15 (6406)
17. Randomized Controlled Trials as Topic/ (84921)
18. randomized controlled trial/ (342334)
19. Random Allocation/ (76596)
20. Double Blind Method/ (118498)
21. Single Blind Method/ (17086)
22. clinical trial/ (476450)
23. clinical trial, phase i.pt. (12809)
24. clinical trial, phase ii.pt. (20505)
25. clinical trial, phase iii.pt. (7571)
26. clinical trial, phase iv.pt. (759)
27. controlled clinical trial.pt. (85694)
28. randomized controlled trial.pt. (342334)
29. multicenter study.pt. (153247)
30. clinical trial.pt. (476450)
31. exp Clinical Trials as topic/ (264416)
32. or/17-31 (949526)
33. (clinical adj trial$).tw. (178736)
34. ((singl$ or doubl$ or treb$ or tripl$) adj (blind$3 or mask$3)).tw. (116076)
35. PLACEBOS/ (31583)
36. placebo$.tw. (141131)
37. randomly allocated.tw. (14209)
38. (allocated adj2 random$).tw. (16559)
39. 33 or 34 or 35 or 36 or 37 or 38 (363492)
40. Epidemiologic studies/ (5579)
41. exp case control studies/ (586243)
42. exp cohort studies/ (1234174)
43. Case control.tw. (63924)
44. (cohort adj (study or studies)).tw. (65854)
45. Cohort analy$.tw. (2895)
46. (Follow up adj (study or studies)).tw. (33920)
47. (observational adj (study or studies)).tw. (33241)
48. Longitudinal.tw. (115334)
49. Retrospective.tw. (223737)
50. Cross sectional.tw. (130903)
51. Cross-sectional studies/ (150828)
52. 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 (1654583)
53. Meta-Analysis as Topic/ (12608)
54. meta analy$.tw. (43811)
55. metaanaly$.tw. (1130)
56. Meta-Analysis/ (37918)
57. (systematic adj (review$1 or overview$1)).tw. (35503)
58. exp Review Literature as Topic/ (6626)
59. or/53-58 (89518)
60. 32 or 39 or 52 or 59 (2503667)
61. 16 and 60 (2820)

Note: a search with similar concept terms was used for the Cochrane Central Register of Controlled Trials.