# Analytical Framework

Figure B1 Analytical framework

Figure B1 is the analytical framework describing the flow of individuals through the intervention process after identified with chronic urinary retention. These patients enter the system and receive an intervention to treat their chronic urinary retention. Interventions can have associated harms which may lead to treatment discontinuation. After treatment, intermediate outcomes may include post void residual urine and other measures of retention symptoms. Final health outcomes include the reduction in urinary tract infections and episodes of acute urinary retention, successful trials without catheters, and meaningful changes in urinary symptom scores.