# CUR Treatments

Table A1 Treatments for chronic urinary retention

Intervention | Type or Class
Catheterization | In-dwelling catheterization, intermittent catheterization (clean or sterile technique)
Surgical interventions (etiology-specific) | Male-specific etiologies: prostate surgeries Female-specific etiologies: pelvic organ prolapse repair, adjustment to stress urinary incontinence (SUI) procedures Nonsex-specific etiologies: sacral nerve stimulation, urethroplasty Multiple etiologies: urinary diversion procedures
Pharmacological interventions | Alpha blockers (AB) (doxazosin, prazosin, tamsulosin, terazosin, alfuzosin, silodosin); 5-Alpha Reductase Inhibitors (5-ARI): dutasteride, finasteride; AB + 5-ARI combination therapy: tamsulosin/dutasteride Neurogenic etiologies: botulinum toxin

AB = alpha blockers; SUI = stress urinary incontinence; 5-ARI = 5-alpha reductase inhibitors