# Abbreviations

AUR: Acute urinary retention
BPH: Benign prostate hyperplasia
CI: Confidence interval
CISC: Clean intermittent self-catheterization
CUR: Chronic urinary retention
DSD: Detrusor sphincter dyssynergia
IPSS: International Prostate Symptom Score
LUTS: Lower urinary tract symptoms
MD: Mean difference
MS: Multiple sclerosis
NA: Not assessed
NR: Not reported
NS: No statistical difference
PICOTS: Population, interventions, comparison, outcomes, timing, setting
PVR: Post void residual
QoL: Quality of life
RCT: Randomized controlled trial
RR: Risk ratio
SR: Systematic review
TURP: Transurethral resection of the prostate
TWOC: Trial without catheter
UTI: Urinary tract infection