# List of Abbreviations

μg | Microgram
μmol/L | Micromol per liter
AA | African American
AHRQ | Agency for Healthcare Research and Quality
B | Baseline
BDI-II | Beck Depression Inventory - revised
B-F | Mean difference from baseline
BG | Blood glucose
BHI | Biphasic human insulin
BIAsp | Biphasic insulin aspart
BID | Twice daily
BMI | Body mass index
BS | Blood sugar
C | Caucasian
CGMS | Continuous glucose monitoring system
CI | Confidence interval
CINAHL | Cumulative Index to Nursing & Allied Health Literature
CNS | Central nervous system
CRP | C-reactive protein
CVD | Cardiovascular disease
D | Duration
DBP | Diastolic blood pressure
DCCT | Diabetes Control and Complications Trial
dl | Deciliter
DM | Diabetes mellitus
DTSQ | Diabetes Treatment Satisfaction Questionnaire
EMEA | European Medicines Agency
EPC | Evidence-based Practice Centers
EQ-5D | Euroqol-5D
F | Final
F-B | Mean difference from baseline
FBG | Fasting blood glucose
FDA | Food and Drug Administration
FPG | Fasting plasma glucose
g/day | Gram per day
GAD | Glutamic acid decarboxylase
GP | Group
GP1–GP2 | Mean difference between the difference from baseline
h | Hour
H | Hispanic
HgbA1c | Hemoglobin A1c
IHCIS | Integrated healthcare information services
IQR | Interquartile range
IU | International unit
kg | Kilogram
mg | Milligram
kg/m2 | Kilogram per square meter
L | Liter
lbs | Pounds
m | Meter
mg | Milligram
mg/dL | Milligram per deciliter
min | Minute
ml | Milliliter
mmHg | Millimeter of mercury
mmol | Millimole
NA | Not applicable
ng/mL | Nanograms per milliliter
NHIS | National health interview survey
NIH | National Institutes of Health
nmol | Nanomole
NPH | Neutral protamine hagedorn
NR | Not reported
NS | Not significant
OA | Oral antidiabetic
OAM | Oral antidiabetic medication
ODM | Oral diabetes medicine
OR | Odds ratio
p | P-value
PG | Plasma glucose
PPG | Postprandial glucose
qd | Once daily
RCTs | Randomized controlled trial
ref | Reference group
RR | Relative risk
SBP | Systolic blood pressures
SD | Standard deviation
SE | Standard error
SEM | Standard error of the mean
SU | Sulfonylurea
T | Time of day when insulin taken
T1DM | Type 1 diabetes mellitus
T2DM | Type 2 diabetes mellitus
TZD | Thiazolidinedione
U | Unit
UKPDS | United Kingdom Prospective Diabetes Study
ULN | Upper limit of normal
US | United States
v | Dosing varied
WHO-DTSQ | World Health Organization-Diabetes Treatment Satisfaction Questionnaire