# Acknowledgments

The Evidence-based Practice Center thanks Catherine Witkop and Bushra Abid for their assistance with article reviewing and Ritu Sharma for her assistance with final preparations of the report.

## Peer Reviewers

- Christopher H. Schmid, Ph.D.
- Tufts Medical Center
- Boston, MA

- Leonard Pogach, M.D.
- East Orange VAMC
- East Orange, NJ

- Arshag D. Mooradian, M.D.
- University of Florida College of Medicine
- Jacksonville, FL

## AHRQ Contacts

Beth A. Collins Sharp, Ph.D. | Barbara A. Bartman, M.D., M.P.H.
Director | Task Order Officer
Evidence-based Practice Center Program | Evidence-based Practice Center Program
Agency for Healthcare Research and Quality | Agency for Healthcare Research and Quality
Rockville, MD | Rockville, MD