# Discussion

This report addresses the comparative effectiveness and safety of premixed insulin analogues that are available in the U.S. Changes in blood glucose before or after a meal were the most frequently reported outcomes, followed by changes in A1c. Among adverse events, hypoglycemia was the most frequently reported outcome. Although premixed insulin analogues appear to be promising agents for treating hyperglycemia in type 2 diabetics, their effectiveness when compared to that of other antidiabetic agents has not yet been fully studied.

The Diabetes Control and Complication Trial (DCCT) and the UKPDS have highlighted the importance of achieving tighter glycemic control, with an aim of achieving an A1c of less than 7 percent or 6.5 percent (depending on the organization issuing the guidelines). ^94,^ ^95^ To achieve either of these targets, both fasting and postprandial glucose levels need to be controlled. ^96^ Current evidence suggests that in patients with higher A1c levels, targeting fasting glucose is more beneficial in bringing A1c closer to the desired target; however, as the A1c approaches 7 percent, controlling postprandial glucose becomes more important for achieving the target A1c. ^96^ – ^98^ The American Diabetic Association guidelines recommend a target fasting glucose of 70 to130 mg/dL and a postprandial glucose under 180 mg/dL. ^99^

A near-physiologic insulin replacement regimen generally requires four daily injections of insulin, a requirement that may affect overall patient satisfaction. Premixed insulin analogues can provide a convenient and effective alternative to a near-physiologic insulin replacement regimen by providing bolus insulin with meals through a rapid-acting component and by fulfilling basal insulin requirements through a protaminated slower-release component. A major caveat of premixed insulin preparations, however, is the assumption that a particular proportion of rapid- and intermediate-acting components will be suitable for all patients; thus, they offer only limited opportunity for individualizing glycemic control.

## Key Findings and Implications

### Fasting Glucose

In this systematic review, we found that as compared to long-acting insulin analogues and premixed human insulin preparations, premixed insulin analogues were either less effective or similar in lowering fasting glucose. Premixed insulin analogues may be better than rapid-acting insulin analogues in lowering fasting glucose. When compared to oral antidiabetic agents, premixed insulin analogues appeared to be more effective in lowering fasting glucose. This finding has important clinical implications, since controlling fasting glucose is more effective than controlling postprandial glucose in bringing a relatively high A1c closer to the target range. ^100^ Most studies included in this systematic review excluded patients with very high A1c levels. Thus, the findings of this systematic review should not be extrapolated to the subpopulation of diabetic patients with uncontrolled diabetes.

### Postprandial Glucose

In contrast to our findings with regard to fasting glucose (discussed above), we found that premixed insulin analogues were more effective than the long-acting insulin analogues or premixed human insulin preparations in lowering postprandial glucose levels. However, the injections were given at the recommended time before meals in only eight studies ^10,^ ^15,^ ^45,^ ^53,^ ^67,^ ^70,^ ^77,^ ^101^ that compared premixed insulin analogues to premixed human insulin. Administration of premixed human insulin injections immediately before meals may have been responsible for the observed benefit of the premixed insulin analogues. Controlling postprandial glucose is important, because cardiovascular complications of diabetes, such as coronary heart disease, stroke, cardiovascular mortality, sudden cardiac death, and all-cause mortality, have been found to be closely related to postprandial glucose levels in epidemiological studies. ^102^ – ^105^ Better control of postprandial hyperglycemia may reduce cardiovascular complications. ^106^ – ^109^ However, whether the effectiveness of premixed insulin analogues in lowering postprandial hyperglycemia translates into lower incidence of cardiovascular disease is not known, since very few studies reported any measurable clinical outcomes.

### Hemoglobin A1c

We found premixed insulin analogues to be more effective than long-acting insulin analogues in lowering A1c, probably because of the ability of premixed insulin analogues to control postprandial hyperglycemia. However, this finding may also reflect the fact that the total daily dose of the long-acting insulin analogue was lower than that for the daily premixed insulin analogue in several studies. We found premixed insulin analogues to be more effective than oral antidiabetic agents in lowering A1c. A1c is the standard of care for monitoring long-term glycemic control and reflects both fasting and postprandial glucose control. ^99^ A decrease in A1c is associated with a decrease in diabetic complications, such as retinopathy, nephropathy, and neuropathy. ^1,^ ^110^ Only one of these microvascular complications, diabetic nephropathy, was evaluated, and in only one study. ^32^ This study found no difference between premixed insulin analogues (insulin aspart 70/30), long-acting insulin analogues (insulin detemir), and rapid-acting insulin analogues (insulin aspart) in decreasing the albumin-to-creatinine ratio, even though the premixed insulin analogue was found to be more effective than the long-acting insulin analogue in lowering A1c. ^32^

### Clinical Outcomes

Clinical outcomes (such as all-cause mortality, cardiovascular mortality, and morbidity) were reported in only 16 RCTs. No statistically significant differences were found between premixed insulin analogues and their comparators in terms of all-cause mortality, cardiovascular mortality, or cardiovascular morbidity. While a suggestion of harm was seen in the pooled odds ratios for all-cause mortality, cardiovascular mortality, and the combined outcome for cardiovascular morbidity and mortality, these point estimates were based on few absolute events in only a few studies, in which clinical outcomes were not the primary outcomes.

Reporting bias may also be a concern, since we noted that the majority of the trials did not report on clinical outcomes; if there were no clinical outcomes, they did not report the absence of any adverse clinical effects. Also, three studies from the pharmaceutical industry reported no deaths in either arm, but these studies were not published in the peer-reviewed literature. Cardiovascular morbidity was reported in the pharmaceutical data for one study that was not peer-reviewed. The addition of these data did not significantly change our results. However, if further data were missing from the other studies for which we did not have industry data, our results could have been shifted in either direction.

The definitions of cardiovascular morbidity varied from one study to another. Two studies ^49,^ ^111^ combined serious and less serious events together, potentially masking any real differences in serious cardiovascular morbidity between drugs. When we considered studies that separated more serious from less serious cardiovascular morbidity, the pooled odds ratio for the more serious cardiovascular morbidity indicated a potentially harmful effect of the premixed insulin analogues, although the results were not statistically significant in the case of either more or less serious mortality. While the rosiglitazone and pioglitazone labels have warnings about increased congestive heart failure events in subjects who use insulin of any type in conjunction with these oral medications (versus insulin alone), ^84,^ ^85^ we did not observe any congestive heart failure events in the few available studies, which reported only very few absolute events. In addition, rosiglitazone labels have warnings regarding the increased ischemic risk in patients who use rosiglitazone with insulin, as compared to insulin alone. The evidence was insufficient to allow us to determine whether this risk might be increased in the presence of premixed insulin analogues, as compared to other insulins used alone.

There was also insufficient evidence to allow us to draw conclusions about nephropathy outcomes. One study evaluated changes in plasma creatinine and reported a 0.02-mg/dL difference between groups, favoring insulin detemir (a long-acting insulin analogue). The clinical importance of this small difference is, however, unclear. Two other studies reported one withdrawal as a result of renal insufficiency, yet no consistent results were seen according to drug arm.

No studies were identified that evaluated any other clinical outcomes. Also, evidence is lacking on potential differences in the efficacy and safety of these medications by age, gender, race, or any comorbidity, such as a history of cardiovascular disease. We also found no evidence on the impact of potential interactions between premixed insulin analogues and other medications.

No previous systematic review has synthesized clinical outcomes comparing premixed insulin analogues to their comparators. These outcomes are the most clinically relevant, yet they require studies with long-term followup in which the clinical outcomes are the primary outcomes. While glycemic control has been associated with improved microvascular, and potentially macrovascular, outcomes in subjects with type 2 diabetes, ^112^ – ^116^ diabetes drugs that lower glycemic control (i.e., muraglitazar and rosiglitazone) have been potentially associated with cardiovascular harm. ^117,^ ^118^ This finding demonstrates the importance of evaluating potential clinical harms in all evaluations of diabetes drugs. We found no study that compared intensive control to standard glycemic control, compared premixed insulin analogues to other comparators, and reported clinical outcomes. This aspect is especially important in light of the recent early termination of the Action to Control Cardiovascular Risk in Diabetes (ACCORD) trial, ^119^ which found higher mortality in patients randomized to the intensive therapy arm. An ongoing retrospective observational study funded by Sanofi-Aventis comparing cardiovascular outcomes in those initiating insulin glargine to those initiating premixed insulin analogues using the Integrated HealthCare Information Services (IHCIS) databases was completed in January 2008. The results of this study will give us further information regarding this important area of study.

### Adherence

No evidence was found with regard to patient adherence outcomes; therefore, we decided to review studies reporting on quality of life, since such factors may affect patient adherence.

### Quality of Life

Only six RCTs reported on quality of life measures. ^32,^ ^48,^ ^59,^ ^72,^ ^74,^ ^76^ No firm conclusions could be drawn because of the differences between studies in terms of outcome definitions, measurement techniques, populations, and comparators. In the four studies ^32,^ ^48,^ ^59,^ ^74^ using validated measurement tools, only one of six quality of life outcomes (psychological distress) showed a statistically significant difference, favoring the premixed insulin analogues over other antidiabetic agents In the other two studies that showed potential differences between groups that favored the premixed insulin analogues, the active comparator arms were not the best alternative comparators to use, and this choice may have influenced patient satisfaction and willingness to continue treatment. ^72,^ ^76^

No systematic review has synthesized quality of life outcomes comparing premixed insulin analogues to their comparators. While quality of life may affect adherence to a medication and thereby indirectly affect intermediate and clinical outcomes, outcomes related to quality of life were rarely reported. Two industry-sponsored studies are currently underway to evaluate quality of life and treatment satisfaction with regard to premixed insulin analogues and the long-acting insulin glargine, with or without rapid-acting glulisine. The data are expected to be available later in 2008 or 2009. ^120,^ ^121^ If validated measures are used, then this study will constitute a helpful step toward amassing data on this important outcome.

### Hypoglycemia

A relatively common side-effect of the treatment of diabetes, hypoglycemia is the major limiting factor in the management of hyperglycemia. ^122^ As compared to long-acting insulin analogues, premixed insulin analogues are more likely to cause hypoglycemia. This increased risk of hypoglycemia needs to be weighed against the better glycemic control obtained with premixed insulin analogues. Evidence was lacking to allow us to conclusively compare premixed insulin analogues with other antidiabetic treatments in terms of hypoglycemia incidence or hypoglycemic events. Since tighter glycemic control is associated with higher risk of hypoglycemia, it is possible that the difference in hypoglycemia between premixed insulin analogues and long-acting insulin analogues is a result of the difference in glycemic control. Davidson et al. ^123^ reviewed the incidence of hypoglycemia with insulin aspart 70/30 treatment and found that the risk of major hypoglycemia was lower for insulin aspart 70/30 than for premixed human insulin, but there was no difference in the incidence of minor hypoglycemia. Our conclusions are only partially consistent with theirs, for two reasons: First, we have included additional studies that have been published since their review, and, second, they included trials without a comparator in their review, whereas we did not.

### Weight Change

Weight gain is a common side-effect of insulin replacement therapy. ^124^ According to one estimate, each 5-kg weight gain is associated with a 30 percent increase in the risk of coronary heart disease. ^124^ Given the paucity of data, we were able to evaluate the change in weight in the case of only one premixed insulin analogue, insulin aspart 70/30. As compared to long-acting insulin analogues, insulin aspart 70/30 was associated with greater weight gain. However, this finding is difficult to interpret, in light of the fact that long-acting insulin analogues were less effective in controlling hyperglycemia and lowering A1c. Weight gain with insulin aspart 70/30 was also evaluated in the review by Davidson et al., ^123^ who reported that the weight gain seen with insulin aspart 70/30 monotherapy also occurred when this drug was used in combination with oral antidiabetic agents. Our systematic review adds to this knowledge by including more recently published trials. A recent systematic review by Gough and Tibaldi ^125^ evaluated the efficacy and safety of insulin aspart 70/30. Their results were similar to ours, except that they found that the degree of hypoglycemia and weight gain associated with insulin aspart 70/30 were similar to that seen with the long-acting insulin analogue. Since our systematic review includes more recently published trials and we have compared the effect across all premixed insulin analogues, we suggest that our results are more reflective of the current state of knowledge.

## Limitations

There are several potential limitations to this systematic review. No studies reported on all the outcomes included in this review. In addition, the studies varied in terms of the manner in which the findings were reported. Several studies presented data on changes in blood glucose in a figure and only commented on the significant findings in the text, forcing us to abstract data from figures when possible. Some studies reported point estimates but did not report dispersion around the point estimates. Some studies did report enough data to make it possible to impute standard error of the means. Almost half of the studies were crossover studies, and the data were not reported in a manner that could be used in a quantitative synthesis without some assumptions being made. These assumptions may have affected the quantitative synthesis of the evidence. Because of the relatively small number of studies available for each comparison, a full analysis and exploration for heterogeneity could not be done. We addressed this limitation by using a random-effects model for all analyses, regardless of the presence or absence of statistical heterogeneity. The small number of studies also precluded our ability to fully assess the potential for publication bias. In addition, the small number of trials in each comparison limited our ability to analyze noninferiority and superiority trials separately.

Management of the control group was not optimal in several studies. For example, in several studies the dose of premixed insulin analogues was titrated to achieve optimal glycemic control, while the dose of oral antidiabetic agents was kept constant. ^51,^ ^57,^ ^59,^ ^60,^ ^72^ Also, the studies used different targets for fasting glucose to guide the titration of insulin. In cases in which a relatively less aggressive target for fasting glucose (<120 mg/dL) was applied, the trial may not have used the optimal dose of long-acting insulin analogues, resulting in a bias in favor of the premixed analogues. However, in light of the results of the ACCORD trial, ^119^ which reported increased mortality in patients randomized to intensive glycemic control as compared to patients randomized to standard glycemic control, it is difficult to determine the ideal target for fasting glucose.

The methodological quality of the studies evaluated was good, but the applicability was fair to good. The main reason for this limited applicability was that these were efficacy studies, which were designed to evaluate premixed insulin analogues in a limited subgroup of patients. Thus, most of the studies excluded patients with diabetic complications, other comorbid conditions, or certain subpopulations. Another factor that limited the applicability of these trials was the relatively short duration of followup of patients while on treatment. This limited followup fails to mirror the real-world situation: Once diabetic patients require insulin, they usually continue to take it for rest of their lives. Thus, whether the relative effectiveness of premixed insulin analogues with regard to some outcome measures would persist over a longer period of administration cannot be extrapolated from these studies.

Almost all of the studies that reported their source of funding were funded by the pharmaceutical industry, raising the possibility of publication bias. However, our search of the FDA scientific review did not reveal any additional studies that had not yet been reported. We found only one relevant unpublished study at www.clinicalstudyresults.org, which was completed recently.

Only in the case of some comparisons and a few outcomes were we able to find sufficient evidence to allow us to comment on the effectiveness of premixed insulin analogues. For several other comparisons and outcomes, the evidence was insufficient regarding the effectiveness of premixed insulin analogues. We found very few studies that commented on clinical outcomes.

The quality of life associated with choosing a particular treatment may influence adherence to therapy and should be addressed in the case of patients with chronic diseases. However, we found very few studies that looked at quality of life, and none addressed adherence. Moreover, those that reported quality of life did not use validated scales in some cases.

This systematic review examines the effectiveness of premixed insulin analogues compared with other antidiabetic agents (insulin or noninsulin) alone or in combination. This systematic review does not specifically examine the comparative effectiveness of different insulin regimens (such as those that vary by the frequency of premixed insulin injections in a day) for the treatment of type 2 diabetes.

## Gaps in the Evidence

### Intermediate Outcomes

Because of the current lack of effectiveness studies, the results of the research analyzed here should be applied with caution to individual patients with type 2 diabetes. Not all comparisons provided enough data to allow us to compare premixed insulin analogues with other antidiabetic treatments. However, several ongoing studies may provide valuable additional data to bridge the gap in the current evidence. ^120,^ ^121,^ ^126^

### Clinical Outcomes

Scant data exist for use in assessing clinical outcomes when premixed insulin analogues are compared with other antidiabetic treatments. The few studies that reported clinical outcomes were of relatively short duration and were neither designed nor powered to assess clinical outcomes.

### Adherence and Quality of Life

No studies evaluated patient adherence. Few studies have compared the effectiveness of premixed insulin analogues to that of other antidiabetic treatments in terms of improving quality of life. In addition, two of the studies that did evaluate quality of life used non-validated scales. ^72,^ ^76^ Since diabetes is a chronic disease that requires different injection patterns and glucose testing depending on type of insulin regimen prescribed, longer-duration studies are needed to assess the effect of premixed insulin analogues on adherence and quality of life.

### Hypoglycemia

Very few studies (or, in some cases, no studies) were available that included comparisons between certain combinations of premixed insulin analogues and other antidiabetic treatments. The relatively short duration of followup in the available studies limited our ability to draw conclusions about the incidence of hypoglycemia over a longer duration of time. Only one study that compared hypoglycemia incidence at 1 year and 2 years found a lower incidence during the second year. ^45^ Patients with comorbid conditions need to be included in future studies. Patients with comorbid conditions, who may be at a different risk of developing hypoglycemia from these medications, were excluded from the available trials. Thus, the results of these trials cannot be extrapolated to patients with comorbid conditions. Furthermore, definitions of minor hypoglycemia and symptoms of hypoglycemia differed among the studies.

### Weight Change

The main gap in the evidence on weight change was related to the short duration of the studies. Weight gain is a relatively slowly progressing outcome, and therefore studies with a longer duration of followup can provide better insight into the extent to which premixed insulin analogues can cause weight gain.

## Future Directions for Research

1 Very few studies compared a premixed insulin analogue with another premixed analogue in patients with type 2 diabetes. As premixed insulin analogues vary in their insulin structure and the ratio of rapid-acting and long-acting components, future comparative research is needed to study whether one premixed analogue is better than the other. Future research should also focus on the type of patients and/or type of glycemic controls in which a particular premixed analogue preparation is better than the other. Such studies should not only aim to evaluate intermediate clinical outcomes (such as A1c) but should also evaluate clinical outcomes.
2 We also found very few studies comparing a near-physiologic regimen (consisting of prandial rapid-acting insulin analogue injections and long-acting insulin analogues) with a relatively convenient regimen consisting of premixed insulin analogues in type 2 diabetic pateints. Such studies should not only evaluate the intermediate outcomes, clinical outcomes, and safety, but should also evaluate patient adherence to insulin treatment and quality of life.
3 Most of the studies included in this systematic review had a short followup duration. Studies with longer followup are needed to determine whether the effects observed early in treatment are sustainable and whether differences between the comparators appear later in treatment.
4 All studies had inclusion criteria that excluded certain type 2 diabetic subpopulations (such as morbidly obese, or with very poor glycemic control). These inclusion criteria limit the generalizability of these findings to all type 2 diabetic patients. Studies designed to examine the effectiveness and safety of premixed insulin analogues in type 2 diabetic patients should be conducted with less restrictive inclusion criteria. In addition, research should be conducted in representative primary care settings to assess the effectiveness and safety of premixed insulin analogues.
5 Patients with comorbid conditions, racial minorities, and very elderly patients were either excluded from the studies or were under-represented in the study populations. Such subpopulations of diabetic patients need to be included in studies examining the effectiveness and safety of premixed insulin analogues.
6 Most studies were relatively small and could not evaluate the effect of patient characteristics on study outcomes. Studies of the effectiveness and safety of premixed insulin analogues should be large enough to permit analysis of how effects may vary by patient characteristics, such as age, gender, race/ethnicity, socioeconomic status, and comorbidity.
7 We did not find any study which was specifically designed to compare the effect of premixed insulin analogues with comparators on clinical outcomes (such as cardiovascular morbidity and/or mortality). As improvement in intermediate outcomes may not always result in improvement in clinical outcomes, studies specifically designed to evaluate clinical outcomes are needed. Thus, we believe that studies should compare the potential benefits and harms of premixed insulin analogues, compared to other diabetes medications, especially in light of the wide confidence intervals we found for the risk of cardiovascular morbidity and mortality associated with premixed insulin analogues. Studies need to be sufficiently powered to make it possible to assess clinical outcomes.
8 Quality of life and adherence to treatment were evaluated in very few studies. Because diabetes is a chronic disease, the effects of premixed insulin analogues on quality of life and patient satisfaction need to be examined.
9 Another area of research that was not addressed by any study in this systematic review but needs to explored is how type 2 diabetic patients' preferences regarding the use of different insulin regimens depend on the convenience of dosing as well as the expected effects on mortality, morbidity, glycemic control, hypoglycemia, and body weight.

## Conclusion

In summary, premixed insulin analogues are more effective than long-acting insulin analogues administered alone in terms of lowering postprandial glucose and A1c. Premixed insulin analogues are also more effective than premixed human insulin preparations in lowering postprandial glucose, but not A1c. The studies analyzed had several limitations that call for caution in applying the results to individual patients with type 2 diabetes. These results can only be extended to a larger population of patients with type 2 diabetes if we assume that the unstudied subpopulations of patients will respond similarly to the patients in these studies. Individual patient factors should continue to play an important role in the selection of a particular type of insulin. Moreover, studies with a longer duration and sufficient power to allow assessment of clinical outcomes still need to be performed.