# Evidence Tables

Table 1 Grading of the body of evidence of the effects of premixed insulin analogues compared to other diabetes medications for each outcome

| Fasting glucose
| Premixed vs. long-acting insulin analogues | Premixed vs. rapid-acting insulin analogues | Premixed vs. rapid-acting + long-acting insulin analogues | Premixed insulin analogues vs. premixed human insulin | Premixed insulin analogues vs. NPH | Premixed insulin analogues vs. noninsulin antidiabetic agents
[underlined: Quantity of evidence:] Number of studies | 11 | 2 | 2 | 9 | 2 | 10
Range of sample sizes | 20–469 | 107–473 | 145 | 25–177 | 93–403 | 49–597
[underlined: Quality and consistency of evidence:] Were study designs mostly RCTs (high quality), non-RCTs (medium quality), observational studies (low quality), or about a 50:50 mix of experimental and observational (medium quality)? | High | High | Moderate | High | High | High
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | 0 | 0 | 0 | 0 | 0 | 0
Did the studies have important inconsistency? (-1) | 0 | -1 | 0 | -1 | 0 | -1
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest)? | -1 | 0 | 0 | 0 | 0 | -1
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | 0 | 0 | 0 | 0 | 0 | 0
Did the studies have high probability of reporting bias? (-1) | 0 | 0 | -1 | 0 | 0 | 0
Did the studies show strong evidence of association between intervention and outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2)) [underlined: - use your clinical judgment for absolute differences.] | 0 | 0 | 0 | 0 | 0 | 0
Did the studies have evidence of a dose-response gradient? (+1) | 0 | 0 | 0 | 0 | 0 | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0 | 0 | 0 | 0 | 0
Overall grade of evidence (high, moderate, low) | Moderate | Low | Low | Moderate | Low | Moderate
| Pre-dinner glucose
| Premixed vs. long-acting insulin analogues | Premixed vs. rapid-acting insulin analogues | Premixed vs. rapid-acting + long-acting insulin analogues | Premixed insulin analogues vs. premixed human insulin | Premixed insulin analogues vs. NPH | Premixed insulin analogues vs. noninsulin antidiabetic agents
[underlined: Quantity of evidence:] Number of studies | 8 | 3 | 1 | 7 | 1 | 8
Range of sample sizes | 20–469 | 106–474 | 374 | 25–187 | 394 | 49–501
[underlined: Quality and consistency of evidence:] Were study designs mostly RCTs (high quality), non-RCTs (medium quality), observational studies (low quality), or about a 50:50 mix of experimental and observational (medium quality)? | High | High | Moderate | High | High | High
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | 0 | 0 | 0 | 0 | 0 | 0
Did the studies have important inconsistency? (-1) | 0 | 0 | 0 | 0 | 0 | 0
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest)? | 0 | 0 | 0 | 0 | 0 | 0
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | 0 | 0 | 0 | 0 | 0 | 0
Did the studies have high probability of reporting bias? (-1) | 0 | 0 | 0 | 0 | 0 | 0
Did the studies show strong evidence of association between intervention and outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2)) [underlined: - use your clinical judgment for absolute differences.] | 0 | 0 | 0 | 0 | 0 | 0
Did the studies have evidence of a dose-response gradient? (+1) | 0 | 0 | 0 | 0 | 0 | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0 | 0 | 0 | 0 | 0
Overall grade of evidence (high, moderate, low) | Moderate | Moderate | Moderate | Moderate | Moderate | Moderate
| 2-hour postprandial glucose after breakfast
| Premixed vs. long-acting insulin analogues | Premixed vs. rapid-acting insulin analogues | Premixed vs. rapid-acting + long-acting insulin analogues | Premixed insulin analogues vs. premixed human insulin | Premixed insulin analogues vs. NPH | Premixed insulin analogues vs. noninsulin antidiabetic agents
[underlined: Quantity of evidence:] Number of studies | 9 | 1 | 1 | 11 | 2 | 10
Range of sample sizes | 20–315 | 107 | 374 | 23–177 | 140–403 | 143–597
[underlined: Quality and consistency of evidence:] Were study designs mostly RCTs (high quality), non-RCTs (medium quality), observational studies (low quality), or about a 50:50 mix of experimental and observational (medium quality)? | High | High | Moderate | High | High | High
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | 0 | 0 | 0 | 0 | 0 | 0
Did the studies have important inconsistency? (-1) | 0 | NA | 0 | 0 | NA | 0
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest)? | -1 | 0 | 0 | 0 | 0 | 0
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | 0 | -1 | 0 | 0 | -1 | 0
Did the studies have high probability of reporting bias? (-1) | 0 | 0 | 0 | 0 | 0 | 0
Did the studies show strong evidence of association between intervention and outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2)) [underlined: - use your clinical judgment for absolute differences.] | 1 | 0 | 0 | 0 | 0 | 0
Did the studies have evidence of a dose-response gradient? (+1) | 0 | 0 | 0 | 0 | 0 | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0 | 0 | 0 | 0 | 0
Overall grade of evidence (high, moderate, low) | High | Low | Low | Moderate | Low | Moderate
| 2-hour postprandial glucose after dinner
| Premixed vs. long-acting insulin analogues | Premixed vs. rapid-acting insulin analogues | Premixed vs. rapid-acting + long-acting insulin analogues | Premixed insulin analogues vs. premixed human insulin | Premixed insulin analogues vs. NPH | Premixed insulin analogues vs. noninsulin antidiabetic agents
[underlined: Quantity of evidence:] Number of studies | 10 | 2 | 2 | 8 | 2 | 9
Range of sample sizes | 20–469 | 107–473 | 145–374 | 25–177 | 140–143 | 49–597
[underlined: Quality and consistency of evidence:] Were study designs mostly RCTs (high quality), non-RCTs (medium quality), observational studies (low quality), or about a 50:50 mix of experimental and observational (medium quality)? | High | High | Moderate | High | High | high
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | 0 | 0 | 0 | 0 | 0 | 0
Did the studies have important inconsistency? (-1) | 0 | 0 | NA | 0 | -1 | -1
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest)? | 0 | 0 | 0 | 0 | 0 | 0
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | 0 | -1 | -1 | 0 | -1 | 0
Did the studies have high probability of reporting bias? (-1) | 0 | 0 | 0 | 0 | 0 | 0
Did the studies show strong evidence of association between intervention and outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2)) [underlined: - use your clinical judgment for absolute differences.] | 0 | 0 | 0 | 0 | 0 | 0
Did the studies have evidence of a dose-response gradient? (+1) | 0 | 0 | 0 | 0 | 0 | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0 | 0 | 0 | 0 | 0
Overall grade of evidence (high, moderate, low) | High | Moderate | Low | High | Low | Moderate
| HbA1c
| Premixed vs. long-acting insulin analogues | Premixed vs. rapid-acting insulin analogues | Premixed vs. rapid-acting + long-acting insulin analogues | Premixed insulin analogues vs. premixed human insulin | Premixed insulin analogues vs. NPH | Premixed insulin analogues vs. noninsulin antidiabetic agents
[underlined: Quantity of evidence:] Number of studies | 9 | 2 | 1 | 7 | 2 | 6
Range of sample sizes | 20–708 | 159–708 | 145 | 40–177 | 140–403 | 129–597
[underlined: Quality and consistency of evidence:] Were study designs mostly RCTs (high quality), non-RCTs (medium quality), observational studies (low quality), or about a 50:50 mix of experimental and observational (medium quality)? | High | High | Low | High | High | High
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | 0 | 0 | -1 | 0 | 0 | 0
Did the studies have important inconsistency? (-1) | 0 | 0 | 0 | 0 | 0 | 0
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest)? | 0 | 0 | 0 | 0 | 0 | 0
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | 0 | 0 | 0 | 0 | 0 | 0
Did the studies have high probability of reporting bias? (-1) | 0 | 0 | -1 | 0 | 0 | 0
Did the studies show strong evidence of association between intervention and outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2)) [underlined: - use your clinical judgment for absolute differences.] | + 1 | 0 | 0 | + 1 | 0 | 0
Did the studies have evidence of a dose-response gradient? (+1) | + 1 | 0 | 0 | + 1 | 0 | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0 | 0 | 0 | 0 | 0
Overall grade of evidence (high, moderate, low) | High | Low | Low | High | Low | Moderate
| Hypoglycemia
| Premixed vs. long-acting insulin analogues | Premixed vs. rapid-acting insulin analogues | Premixed vs. rapid-acting + long-acting insulin analogues | Premixed insulin analogues vs. premixed human insulin | Premixed insulin analogues vs. NPH | Premixed insulin analogues vs. noninsulin antidiabetic agents
[underlined: Quantity of evidence:] Number of studies | 11 | 2 | 2 | 16 | 2 | 10
Range of sample sizes | 20–708 | 159–708 | 145–374 | 13–187 | 140–403 | 49–597
[underlined: Quality and consistency of evidence:] Were study designs mostly RCTs (high quality), non-RCTs (medium quality), observational studies (low quality), or about a 50:50 mix of experimental and observational (medium quality)? | High | High | Moderate | High | High | High
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | 0 | 0 | 0 | 0 | 0 | 0
Did the studies have important inconsistency? (-1) | 0 | 0 | 0 | 0 | 0 | 0
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest)? | 0 | 0 | 0 | 0 | 0 | 0
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | 0 | 0 | 0 | 0 | 0 | 0
Did the studies have high probability of reporting bias? (-1) | 0 | 0 | 0 | 0 | 0 | 0
Did the studies show strong evidence of association between intervention and outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2)) [underlined: - use your clinical judgment for absolute differences.] | 0 | 0 | 0 | 0 | 0 | 0
Did the studies have evidence of a dose-response gradient? (+1) | 0 | 0 | 0 | 0 | 0 | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0 | +1 | 0 | 0 | 0
Overall grade of evidence (high, moderate, low) | High | Low | Low | High | Low | High
| Weight change
| Premixed vs. long-acting insulin analogues | Premixed vs. rapid-acting insulin analogues | Premixed vs. rapid-acting + long-acting insulin analogues | Premixed insulin analogues vs. premixed human insulin | Premixed insulin analogues vs. NPH | Premixed insulin analogues vs. noninsulin antidiabetic agents
[underlined: Quantity of evidence:] Number of studies | 10 | 2 | 2 | 7 | 2 | 10
Total number of patients studied | 20–469 | 98–473 | 145–374 | 30–151 | 93–403 | 49–597
[underlined: Quality and consistency of evidence:] Were study designs mostly RCTs (high quality), non-RCTs (medium quality), observational studies (low quality), or about a 50:50 mix of experimental and observational (medium quality)? | High | High | Medium | High | High | High
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | 0 | 0 | 0 | 0 | 0 | 0
Did the studies have important inconsistency? (-1) | 0 | 0 | 0 | 0 | 0 | 0
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest)? | 0 | 0 | 0 | 0 | 0 | 0
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | 0 | 0 | 0 | 0 | 0 | 0
Did the studies have high probability of reporting bias? (-1) | 0 | 0 | 0 | 0 | 0 | 0
Did the studies show strong evidence of association between intervention and outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2)) [underlined: - use your clinical judgment for absolute differences.] | 0 | 0 | 0 | 0 | 0 | 0
Did the studies have evidence of a dose-response gradient? (+1) | 0 | 0 | 0 | 0 | 0 | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0 | +1 | 0 | 0 | 0
Overall grade of evidence (high, moderate, low, very low) | High | Low | Low | High | Low | High
| All-cause mortality
| Premixed vs. long-acting insulin analogues | Premixed vs. exenatide | Premixed vs. another premixed insulin analogue | Premixed vs. premixed human insulin | Other comparisons | Premixed vs. oral antidiabetic agents
[underlined: Quantity of evidence:] Number of studies | 2 | 1 | 1 | 2 | 0 | 2
Total number of patients studied | 804 | 501 | 133 | 167 | NA | 926
[underlined: Quality and consistency of evidence:] Were study designs mostly RCTs (high quality), mostly non-RCTs (medium quality), observational studies (low quality), or about a 50:50 mix of experimental and observational (medium quality)? | High | High | High | High | NA | High
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | 0 | 0 | 0 | 0 | NA | 0
Did the studies have important inconsistency? (-1) | 0 | 0 | 0 | -1 | NA | 0
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest)? | 0 | 0 | 0 | 0 | NA | 0
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | -1 | -1 | -1 | -1 | NA | -1
Did the studies have high probability of reporting bias? (-1) | -1 | -1 | -1 | -1 | NA | -1
Did the studies show strong evidence of association between intervention and outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2)) [underlined: - use your clinical judgment for absolute differences.] | 0 | 0 | 0 | 0 | NA | 0
Did the studies have evidence of a dose-response gradient? (+1) | 0 | 0 | 0 | 0 | NA | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0 | 0 | 0 | NA | 0
Overall grade of evidence (high, moderate, or low) | Low | Low | Low | Low | Insufficient | Low
| Cardiovascular mortality
| Premixed vs. long-acting insulin analogues | Premixed vs. premixed human insulin | | | Other comparisons | Premixed vs. oral antidiabetic agents
[underlined: Quantity of evidence:] Number of studies | 2 | 1 | | | 0 | 1
Total number of patients studied | 804 | 186 | | | NA | 329
[underlined: Quality and consistency of evidence:] Were study designs mostly RCTs (high quality), non-RCTs (medium quality), observational studies (low quality), or about a 50:50 mix of experimental and observational (medium quality)? | High | High | | | NA | High
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | 0 | 0 | | | NA | 0
Did the studies have important inconsistency? (-1) | 0 | 0 | | | NA | 0
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest)? | 0 | 0 | | | NA | 0
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | -1 | -1 | | | NA | -1
Did the studies have high probability of reporting bias? (-1) | -1 | -1 | | | NA | -1
Did the studies show strong evidence of association between intervention and outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2)) [underlined: - use your clinical judgment for absolute differences.] | 0 | 0 | | | NA | 0
Did the studies have evidence of a dose-response gradient? (+1) | 0 | 0 | | | NA | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0 | | | NA | 0
Overall grade of evidence (high, moderate, low, very low) | Low | Low | | | Insufficient | Low
| Cardiovascular morbidity
| Premixed vs. long-acting insulin analogues | Premixed vs. exenatide | Premixed vs. premixed human insulin | | Other comparisons | Premixed vs. oral antidiabetic agents
[underlined: Quantity of evidence:] Number of studies | 2 | 1 | 2 | | 0 | 3
Total number of patients studied | 456 | 501 | 368 | | NA | 530
[underlined: Quality and consistency of evidence:] Were study designs mostly RCTs (high quality), non-RCTs (medium quality), observational studies (low quality), or about a 50:50 mix of experimental and observational (medium quality)? | High | High | High | | NA | High
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | 0 | 0 | 0 | | NA | 0
Did the studies have important inconsistency? (-1) | 0 | 0 | 0 | | NA | 0
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest)? | 0 | 0 | 0 | | NA | 0
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | -1 | -1 | -1 | | NA | -1
Did the studies have high probability of reporting bias? (-1) | -1 | -1 | -1 | | NA | -1
Did the studies show strong evidence of association between intervention and outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2)) [underlined: - use your clinical judgment for absolute differences.] | 0 | 0 | 0 | | NA | 0
Did the studies have evidence of a dose-response gradient? (+1) | 0 | 0 | 0 | | NA | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0 | 0 | | NA | 0
Overall grade of evidence (high, moderate, low, very low) | Low | Low | Low | | Insufficient | Low
| Nephropathy
| Premixed vs. long-acting insulin analogues or oral agents | | | Other comparisons
[underlined: Quantity of evidence:] Number of studies | 3 | | | 0
Total number of patients studied | 1223 | | | NA
[underlined: Quality and consistency of evidence:] Were study designs mostly RCTs (high quality), non-RCTs (medium quality), observational studies (low quality), or about a 50:50 mix of experimental and observational (medium quality)? | High | | | NA
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | 0 | | | NA
Did the studies have important inconsistency? (-1) | 0 | | | NA
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest)? | 0 | | | NA
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | -1 | | | NA
Did the studies have high probability of reporting bias? (-1) | -1 | | | NA
Did the studies show strong evidence of association between intervention and outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2)) [underlined: - use your clinical judgment for absolute differences.] | 0 | | | NA
Did the studies have evidence of a dose-response gradient? (+1) | 0 | | | NA
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | | | NA
Overall grade of evidence (high, moderate, low, very low) | Low | | | Insufficient
| Quality of life
| Premixed vs. long-acting insulin analogues | Premixed vs. rapid-acting insulin analogues | Premixed vs. rapid-acting + long-acting insulin analogues | Premixed insulin analogues vs. premixed human insulin | Premixed insulin analogues vs. NPH | Premixed insulin analogues vs. oral antidiabetic agents
[underlined: Quantity of evidence:] Number of studies | 3 | 1 | 0 | 1 | 0 | 2
Total range in number of patients studied | 45 to 708 | 159 | NA | 160 | NA | 451
[underlined: Quality and consistency of evidence:] Were study designs mostly RCTs (high quality), non-RCTs (medium quality), observational studies (low quality), or about a 50:50 mix of experimental and observational (medium quality)? | High | High | NA | High | NA | High
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | 0 | -1 | NA | 0 | NA | -1
Did the studies have important inconsistency? (-1) | 0 | 0 | NA | 0 | NA | -1
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest)? | 0 | -1 | NA | 0 | NA | -1
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | -1 | -1 | NA | -1 | NA | -1
Did the studies have high probability of reporting bias? (-1) | 0 | -1 | NA | 0 | NA | -1
Did the studies show strong evidence of association between intervention and outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2)) [underlined: - use your clinical judgment for absolute differences.] | 0 | 0 | NA | 0 | NA | 0
Did the studies have evidence of a dose-response gradient? (+1) | 0 | 0 | NA | 0 | NA | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0 | NA | 0 | NA | 0
Overall grade of evidence (high, moderate, low, very low) | Low | Low | Insufficient | Low | Insufficient | Low

High = further research is very unlikely to change our confidence in the estimates; moderate = further research is likely to have an important impact on our confidence in the estimate of effect and [underlined: may] change the estimate; low = further research is likely to have an important impact on our confidence in the estimate of effect and [underlined: is likely to] change the estimate.

Table 2 Characteristics of the studies comparing a premixed insulin analogue to other diabetes treatments

Author, year Country | Study design | Study duration | Exclusion criteria | Target glucose values
Abrahamian, 2005 ^53^ Austria | Parallel-arms, randomized controlled trial | Intended duration: 24 weeks | A1c < 7%, no T2DM, BMI > 40 kg/m^2^, history of insulin use or OA agent plus insulin and under good control | Target glucose was according to local practice
Bebakar, 2007 ^46^ Western Pacific | Parallel-arms, randomized controlled trial | Intended duration: 24 weeks | Age < 18 years, any liver disease, any kidney disease, A1c < 7 and > 12%, no T2DM, BMI < 18 and > 30 kg/m^2^, duration of diabetes < 24 and > 60 months, OA agents for < 4 months (SU, biguanide, glinide, alpha-glucosidase inhibitor, or combination (more than two not permissible), CRP < 0.33 nmol/L, TZD therapy in last 6 months | A1c ≤ 8.5% FPG ≤ 7 mmol/L (126 mg/dL)
Boehm, 2004 ^45^ Boehm, 2002 ^9^ * United Kingdom, Germany, Ireland | Parallel-arms, randomized controlled trial | Intended duration: 104 weeks | Age < 18 years, A1c > 11%, no T2DM, BMI > 35 kg/m^2^, duration of diabetes < 2 years | NR
Christiansen, 2003 ^13^ 9 countries | Parallel-arms, randomized controlled trial | Intended duration: 16 weeks | Age < 18 years, A1c > 11%, no T2DM, BMI > 35 kg/m^2^, insulin doses ≥ 1.8 IU/kg/day, history of serious late diabetic complications or other serious disease | NR
Coscelli, 2003 ^67^ Italy | Cross-over, randomized controlled trial, no washout period | Mean: 24 days Intended duration: 12 weeks | Age < 35 and > 70 years, any liver disease, any kidney disease, history of CVD, A1c > 9.5%, no T2DM, BMI < 27 and > 35 kg/m^2^, not already taking twice daily premixed insulin (30/70) or NPH insulin therapy for at least 6 months, cancer, drug or alcohol abuse, insulin allergy, recurrent severe hypoglycemia, anemia, hemoglobinopathy, breastfeeding, pregnant, or intending to become pregnant, any treatment with OA agents, systemic glucocorticoids, or insulin doses > 2.0 IU/kg/day | FPG ≤ 7.8 mmol/L (140 mg/dL) 2-hr PPG < 10 mmol/L (180 mg/dL)
Cox, 2007 ^74^ United States | Cross-over, randomized controlled trial, no washout period | Intended duration: 24 weeks | A1c < 7 and > 10%, no T2DM, have not used metformin, pregnant, breastfeeding, patients with a previous diagnosis of depression or treated with centrally acting medications (e.g., antidepressants or anxiolytics) | FPG < 6.7 mmol/L (121 mg/dL) 2-hr PPG < 8.0 mmol/L (144 mg/dL)
Hermansen, 2002 ^58^ Denmark | Cross-over, randomized controlled trial, washout period: at least 5 days | Intended duration: 1 day | Age < 18 years, any liver disease, any kidney disease, history of CVD, neuropathy, retinopathy, A1c ≥ 11%, no T2DM, BMI > 32 kg/m^2^, not insulin treated, insulin doses ≥ 1.4 U/kg/day, recurrent severe hypoglycemia, alcohol or drug abuse | NR
Herz, 2002 ^71^ Croatia | Cross-over, randomized controlled trial, no washout period | Intended duration: 4 weeks | Age < 38 and > 69 years, A1c ≥ 10%, no T2DM, BMI > 35 kg/m^2^, not treated with a fixed mixture of human insulin twice daily for at least 1 month, not capable of exercising for 30 minutes on a cycle ergometer at a heart rate of 120 beats/minute during two exercise sessions separated by 30 minutes on rest, being treated with OA agents, systemic glucocorticoids, or insulin doses > 2.0 U/kg/day | FPG < 7.0 mmol/L (126 mg/dL) 2-hr PPG < 10.0 mmol/L (180 mg/dL)
Herz, 2002 ^72^ Czech Republic, Hungary, Slovenia, Croatia, Poland, Sweden, Australia and New Zealand | Parallel-arms, randomized controlled trial | Intended duration: 16 weeks | Age < 60 and > 80 years, any liver disease, history of CVD, retinopathy, A1c < 1.2 fold ULN at visit 1, FBG < 7.8 mmol/L (140 mg/dL) on at least 2 of 3 occasions during 4 week lead-in, no T2DM, BMI > 35 kg/m^2^, insulin allergy, treatment with insulin in the last 6 months, taking OA agents other than SU or acarbose, not on maximum dose of SU for at least 1 month, duration of diabetes < 1 year, renal dialysis or renal transplant | FPG < 7 mmol/L (126 mg/dL) (encouraged by the study investigators but targets were at the discretion of the physician) 2 hour PPG < 10 mmol/L (180 mg/dL)
Herz, 2003 ^12^ South Africa | Cross-over, randomized controlled trial, no washout period | Intended duration: 4 weeks | Age < 40 and > 70 years, A1c > 10%, no T2DM, BMI > 35 kg/m^2^, not treated with human insulin 30/70 twice daily, have not practiced self-monitoring of BG for at least 3 months, usually injected human insulin 30–45 minutes before meals, being treated with OA agents, systemic glucocorticoids, or insulin doses > 2.0 U/kg/day | FPG < 7.0 mmol/L (126 mg/dL) 2-hr PPG < 10 mmol/L (180 mg/dL)
Hirao, 2008 ^61^ Japan | Parallel-arms, randomized controlled trial | Intended duration: 6 months | A1c < 8%, soft drink ketoacidosis | A1c < 7%
Holman, 2007 ^32^ United Kingdom, Ireland | Parallel-arms, randomized controlled trial | Mean: 52 weeks Median: 156 weeks, results reported at 52 weeks Intended duration: 156 weeks | Age < 18 years, any liver disease, any kidney disease, history of CVD, history of insulin treatment, retinopathy, A1c < 7 and > 10%, no T2DM, BMI > 40 kg/m^2^, retinopathy, on less than maximally tolerated doses of metformin and SU for at least 4 months, unawareness of hypoglycemia, pregnant, duration of diabetes < 12 months, TZD treatment or triple OA agents within the previous 6 months, uncontrolled hypertension (SBP > 180 or DBP > 105 mmHg) | A1c 6.5% FPG 72 – 99 mg/dL PPG 90 – 126 mg/dL
Jacober, 2006 ^64^ United States | Cross-over, randomized controlled trial, no washout period | Intended duration: 16 weeks | Age < 30 years, any liver disease, any kidney disease, history of CVD, history of insulin treatment, A1c < 1.2 – 2 times the ULN reference range as defined by the local laboratory, no T2DM, BMI > 40 kg/m^2^, had adequate blood glucose control, as determined by the investigator, while receiving at least 2 OA agents of different classes used in combination for at least 2 months, undergoing treatment for a malignancy other than basal cell or squamous cell skin cancer, insulin allergy, pregnant or intending to become pregnant, history of severe hypoglycemia within 6 months, currently taking rosiglitazone, long term insulin therapy, chronic systemic glucocorticoid therapy, fibric acid derivatives, niacin or a bile acid sequestant to treat hypertriglyceridemia, chronic anemia | FPG < 120 mg/dL (6.7 mmol/L) For treatment with insulin lispro mixtures, the target 2-hr PPG was < 180 mg/dL (10.00 mmol/L)
Joshi, 2005 ^52^ India | Prospective study | Intended duration: 12 weeks | No T2DM | A1c < 7% but was up to the individual clinician to titrate
Kann, 2006 ^50^ Austria, Czech Republic, Germany, Hungary, Poland, Slovakia, Slovenia | Parallel-arms, randomized controlled trial | Intended duration: 26 weeks | A1c ≤ 7 and > 12%, no T2DM, BMI > 40 kg/m^2^, any kidney disease, history of CVD, duration of diabetes < 6 months, not receiving one of the following: SU (at least half maximum dose) with or without metformin, metformin (< 2 g/day), insulin therapy > 7days in last 6 months, alcohol or drug abuse, pregnant, breastfeeding, intending to become pregnant, taking medication interfering with glucose regulation | FPG 5 – 8mmol/L (90 – 144 mg/dL) for both groups 90-min PPG 5 – 10 mmol/L (90 – 180 mg/dL) for BIAsp group
Kapitza, 2004 ^56^ Germany | Cross-over, randomized controlled trial, washout period: 3 –21 days | Intended duration: 5 hours | No T2DM, not treated with insulin for the past 6 months | BG < 10 mmol/L (180 mg/dL)
Kazda, 2006 ^76^ Germany | Parallel-arms, randomized controlled trial | Intended duration: 24 weeks | Age < 30 or > 75 years, A1c < 6 or > 10.50%, no T2DM, BMI ≥ 40 kg/m^2^, duration of diabetes < 1 and > 10 years, insulin treatment during last 3 months | FPG < 7 mmol/L (126 mg/dL) for insulin glargine 2-hr PPG < 10 mmol/L (180 mg/dL) for lispro groups
Kilo, 2003 ^15^ United States | Parallel-arms, randomized controlled trial | Intended duration: 12 weeks | Age < 18 years, any liver disease, any kidney disease, history of CVD, history of insulin treatment, A1c < 7.5%, FBG < 126 mg/dL, no T2DM, BMI > 40 kg/m^2^, body weight > 100 kg, if significant cardiovascular, liver or kidney disease, NOT on metformin monotherapy or combination with SU or repaglinide for ≥ 3 months, controlled on metformin after 4 week run-in period | FPG 90 – 26 mg/dL
Kvapil, 2006 ^51^ Croatia, Czech Republic, Denmark, France, Greece, Hungary, Norway, Poland, Portugal, Russia, Spain | Parallel-arms, randomized controlled trial | Intended duration: 16 weeks | Any liver disease, any kidney disease, history of CVD, no T2DM, not on metformin, adequately controlled on metformin monotherapy, significant medical problems (proliferative retinopathy, impaired hepatic or renal function, recurrent severe hypoglycemia, cardiac disease, anemia), change in dose of medications known to interfere with metformin | Breakfast insulin aspart 70/30 dose adjusted to target post-breakfast and pre-dinner glucoses of 5 – 8 mmol/L (90 – 144 mg/dL); evening insulin aspart 70/30 dose adjusted to target post-dinner, nighttime, and pre-breakfast blood glucose of 5 – 8 mmol/L (90 – 144 mg/dL)
Malone, 2000 ^44^ Malone, 2000 ^14^ Canada | Cross-over, randomized controlled trial, washout period: 3–11 days | Intended duration: 1 day | Age < 38 and > 74 years, A1c > 1.5 times ULN, no T2DM, BMI > 35 kg/m^2^, not using a manufactured or self-prepared human insulin mixture in the morning, a short-acting insulin at dinner, and a second NPH insulin dose either at dinner or separately at bedtime, total daily insulin dose > 2.0 U/kg, using an OA agent or glucocorticoids within 2 weeks, using Ultralente insulin, pregnant, breastfeeding | NR
Malone, 2003 ^68^ 14 countries | Parallel-arms, randomized controlled trial | Mean: 16 weeks | Age < 35 and > 75 years, A1c < 125% of ULN within 4 weeks, no T2DM, BMI > 40 kg/m^2^, adequately controlled diabetes, not using a single OA agent, specifically metformin or SU, at a maximally clinically effective dose within last 3 months | FPG and pre-meal BG < 7 mmol/L (126 mg/dL) 2-hr PPG < 10 mmol/L (180 mg/dL)
Malone, 2004 ^65^ United States | Cross-over, randomized controlled trial, no washout period | Intended duration: 16 weeks | Age < 30 and > 80 years, history of insulin treatment, A1c < 1.3 and > 2.0 times ULN while using ≥ 1 OA agents without insulin for 30 days before study start, no T2DM, BMI > 40 kg/m^2^ | FPG 90 – 126 mg/dL 2-hr PPG 144 – 180 mg/dL
Malone, 2005 ^66^ Spain and France | Cross-over, randomized controlled trial, no washout period | Intended duration: 16 weeks | Age < 30 and > 75 years, A1c < 1.3 and > 2.0 times ULN by a local laboratory within 30 days, no T2DM, used TZDs within 30 days, not using NPH once or twice daily, alone or in combination with an OA agent, or a once-daily human insulin mixture with an OA agent for at least 30 days | FPG 5 – 7 mmol/L (90 – 126 mg/dL); 8 – 10 mmol/L (144 – 180 mg/dL) for Humalog 75/25 only
Mattoo, 2003 ^70^ India, Pakistan, Malaysia, Singapore, Egypt, Morocco, and South Africa | Cross-over, randomized controlled trial, no washout period | Intended duration: 2 weeks | Any liver disease, any kidney disease, history of CVD, retinopathy, no T2DM, BMI > 35 kg/m^2^, not treated with conventional insulin therapy for at least 2 months, not complying with dietary and insulin treatment, not capable or willing to perform self-BG monitoring and use a patient diary, cancer, insulin allergy, drug or alcohol abuse, more than 1 unexplained episode of severe hypoglycemia within 6 months or a history of clinically significant hypoglycemia unawareness, treated with systemic glucocorticoids or insulin doses > 2.0 U/kg | NR
McNally, 2007 ^48^ United Kingdom | Cross-over, randomized controlled trial, no washout period | Intended duration: 16 weeks | A1c ≥ 9.5%, no T2DM, BMI ≥ 40 kg/m^2^, not treated with insulin for at least 6 months | FPG 5 – 7 mmol/L (90 – 126 mg/dL) Preprandial glucose 5 – 7 mmol/L (90 – 126 mg/dL)
McSorley, 2002 ^11^ NR | Cross-over, randomized controlled trial, no washout period | Intended duration: 2 weeks | Age < 40 and > 75 years, no T2DM, history of type 2 diabetes < 1 year, not using twice-daily BHI 30 for at least 6 months | NR
Nauck, 2007 ^49^ 13 countries | Parallel-arms, randomized controlled trial | Intended duration: 52 weeks | Age < 30 and > 75 years, A1c < 7 and > 11%, BMI < 25 and > 40 kg/m^2^, not on “optimally effective” metformin and sulfonylurea treatment for at least 3 months, lack of stable body weight (> 10% variation in last 3 months), more than 3 episodes of severe hypoglycemia within 6 months prior to screening, use of a weight loss prescription drug in the last 3 months, treated with insulin, TZDs, alpha-glucosidase inhibitors, or meglitinides for > 2 weeks in last 3 months | FPG < 7 mmol/L (126 mg/dL) 2-hr PPG < 10 mmol/L (180 mg/dL)
Niskanen, 2004 ^55^ United Kingdom, Finland, Norway, Sweden | Cross-over, randomized controlled trial, no washout period | Intended duration: 12 weeks | Age < 18 years, any liver disease, any kidney disease, history of CVD, A1c > 12%, no T2DM, BMI > 35 kg/m^2^, did not require insulin for the past 6 months, insulin dose ≥ 1.8 IU/kg/day, not eligible for BID mixed insulin treatment, not willing or able to perform self monitoring of BG, previous treatment with insulin analogues or use of OA agents within the last 4 weeks, severe uncontrolled hypertension, known or suspected allergy to trial products, pregnant, alcohol or drug abuse | FPG 5.0 – 8.0 mmol/L (90 – 144 mg/dL) Postprandial BG (1–3 hours after a meal) 5.0 – 10.0 mmol/L (90 – 180 mg/dL)
Raskin, 2005 ^39^ Raskin, 2007 ^40^ Brod, 2007 ^41^ United States | Parallel-arms, randomized controlled trial | Intended duration: 28 weeks | Age < 18 and > 75 years, history of insulin treatment, A1c < 8%, no T2DM, BMI > 40 kg/m^2^, body weight > 275 lbs, not on metformin > 1000 mg/day as a single agent or as part of combination therapy for at least 3 months, pregnant, breastfeeding, or not practicing contraception | FPG 80 – 110 mg/dL
Raskin, 2007 ^60^ United States | Parallel-arms, randomized controlled trial | Intended duration: 34 weeks | Age < 18 years, history of insulin treatment, A1c < 7.5 and > 12, no T2DM, BMI > 42 kg/m^2^, not treated with 2 OA agents for at least 6 months | FPG 4.4 – 6.1 mmol/L (79.2 – 109.8 mg/dL)
Raz, 2003 ^57^ Israel | Parallel-arms, randomized controlled trial | Intended duration: 6 weeks | Age < 30 years, any liver disease, history of CVD, history of insulin treatment, A1c ≤ 8 and ≥ 13%, no T2DM, T1DM, BMI > 35 kg/m^2^, alcohol or drug abuse, responding to glibenclamide therapy, not treated with glibenclamide as the only OA agent for at least 4 weeks | FPG 90 – 144 mg/dL PPG (1 – 3 hours after a meal) < 180 mg/dL
Raz, 2005 ^54^ Canada, Israel, China, Australia, Croatia, Thailand, South Africa, Poland | Parallel-arms, randomized controlled trial | Intended duration: 18 weeks | Age < 18 years, any liver disease, history of CVD, A1c < 7.4 and > 14.7%, no T2DM, BMI > 40kg/m^2^, no treatment with SU within last 3 months, alcohol or drug abuse, any serious disease, pregnant, likely to become pregnant or not using contraception | FPG, preprandial, and nighttime 5–8 mmol/L (90 – 180 mg/dL) for insulin aspart 70/30 PPG 5–8 mmol/L (90 –180 mg/dL) for insulin aspart 70/30
Roach, 1999 ^73^ United Kingdom, Spain, South Africa | Cross-over, randomized controlled trial, no washout period | Intended duration: 13 weeks | Age < 18 and > 75 years, any liver disease, any kidney disease, history of CVD, history of OA agents, retinopathy, A1c > 9.2%, no T2DM, BMI > 35 kg/m^2^, had not received insulin therapy using mixtures of short-acting or rapid-acting insulin and intermediate- or long-acting insulin twice daily for at least 30 days, cancer, anemia, hemoglobinopathy, alcohol or drug abuse, insulin allergy, recurrent severe hypoglycemia, breastfeeding, pregnant, or intending to become pregnant, treated with OA agents, systemic glucocorticoids, or insulin doses > 2.0 U/kg | NR
Roach, 1999 ^10^ United Kingdom, Germany, Hungary, the Netherlands, Switzerland | Cross-over, randomized controlled trial, no washout period | Intended duration: 12 weeks | Age < 18 and > 70 years, any liver disease, any kidney disease, history of CVD, A1c > 9.2%, no type 1 or type 2 diabetes, not treated with commercially available insulin for at least 120 days, cancer, drug or alcohol abuse, insulin allergy, recurrent severe hypoglycemia, anemia, or hemoglobinopathy, treated with OA agents, systemic glucocorticoids, or insulin doses > 2.0 U/kg | FPG ≤ 7.8 mmol/L (140 mg/dL) 2-hr PPG ≤ 10 mmol/L (180 mg/dL)
Roach, 2003 ^69^ India | Cross-over, randomized controlled trial, no washout period | Intended duration: 8 weeks | Age < 25 and > 75 years, A1c > 12%, no T2DM, BMI > 35 kg/m^2^, not taking twice daily insulin therapy with mixtures of short- or rapid-acting and intermediate- or long-acting insulin for at least 6 months, history of recurrent severe hypoglycemia, treated with OA agents, systemic glucocorticoids, or insulin doses > 2.0 U/kg | FPG ≤ 7.8 mmol/L (140 mg/dL) 2-hr PPG ≤ 10 mmol/L (180 mg/dL)
Roach, 2006 ^63^ United States | Cross-over, randomized controlled trial, no washout period | Intended duration: 12 weeks | Age < 21 and > 80 years, any liver disease, any kidney disease, A1c < 7 and > 12%, no T2DM, inadequate glycemic control using single or multiple OA agents or once or twice-daily insulin or a combination of OA agents and insulin for at least 3 months, use of a TZD within 3 months, pregnant, evidence of major systemic illness or organ dysfunction | FPG < 6.0 mmol/L (108 mg/dL)
Robbins, 2007 ^79^ United States, Australia, Greece, the Netherlands, Poland, and Puerto Rico | Parallel-arms, randomized controlled trial | Intended duration: 24 weeks | Age < 35 and > 75 years, any liver disease, any kidney disease, A1c < 6.5 and > 11, no T2DM, had a clinically unacceptable level of LDL cholesterol determined by investigator's opinion, not currently using metformin and/or a sulfonylurea with a stable dose of 0 to 2 daily insulin injections for at least 3 months, receiving continuous SC insulin infusions, ≥ 3 daily insulin injections or a total daily insulin dose > 2.0 U/kg, change in the type or dose of lipid-altering medications or TZD use up to 3 months prior to study start, fasting triglyceride levels > 4.5 mmol/L (81 mg/dL), pregnant women or women not using an effective method of contraception | FPG < 120 mg/dL (6.7 mmol/L) 2-hr PPG < 144 mg/dL (8.0 mmol/L) for insulin lispro 50/50 group only
Rosenstock, 2008 ^80^ United States, Puerto Rico | Parallel-arms, randomized controlled trial | Intended duration: 24 weeks | Age < 30 and > 75 years, any liver disease, any kidney disease, history of CVD, A1c < 7.5 and > 12%, no T2DM, BMI > 45 kg/m^2^, not taking insulin glargine for at least 90 days in combination with OA agents as monotherapy, dual therapy, or triple therapy, history of scheduled mealtime insulin use or more than one episode of severe hypoglycemia within the prior 6 months, total daily insulin dose > 2.0 U/kg | FPG < 110 mg/dL (6.1 mmol/L)
Schernthaner, 2004 ^77^ NR | Cross-over, randomized controlled trial, no washout period | Intended duration: 12 weeks | Diagnosed after 35 years of age, any liver disease, any kidney disease, history of CVD, A1c > 11%, no T2DM, BMI > 40 kg/m^2^, no severe diabetic complications | NR
Schwartz, 2006 ^62^ United States | Cross-over, randomized controlled trial, washout period: clinic visits were at 3–11 day intervals; last dose of usual insulin taken at least 10 hours before test meal | Intended duration: 1-day 1-dose | Age < 30 years, A1c ≥ 2-fold ULN nondiabetic reference range of the local laboratory (4.3% – 6.1%) at screening, no T2DM, BMI > 40 kg/m^2^, not using insulin, excluding insulin glargine, for at least 30 days prior to screening, known allergy to trial products, insulin doses > 2.0 U/kg, any condition interfering with the accurate assessment of the glucodynamic and pharmacokinetic properties of insulin, any condition that precluded a patient from following protocol, pregnant or not using contraception | NR
Sun, 2007 ^75^ United States | Retrospective cohort study | Intended duration: 18 months | History of insulin treatment, no T2DM, no initiation or less than 3-month use of insulin therapy with either once-daily insulin glargine, twice-daily premixed insulin analogue, or twice-daily premixed human insulin, without switching to another insulin regimen during the observation period, multiple A1c records before and after insulin initiation, taking twice-daily premixed insulin aspart 70/30 | NR
Tamemoto, 2007 ^47^ Japan | Parallel-arms, randomized controlled trial | Intended duration: 24 weeks | Age < 40 or > 75 years, A1c < 7.5 or > 12%, FBG < 140 mg/dL, T1DM, duration of diabetes < 1 year, lack of treatment with OA agents (in particular, had to be on a SU—glibenclamide > 5 mg/d or glimepiride > 3 mg/d over 12 weeks), prior use of insulin in last 12 weeks, fasting C-peptide < 0.7 ng/mL | A1c < 7% FPG < 120 mg/dL
Tirgoviste, 2003 ^43^ Roach, 2001 ^42^ Romania and Russia | Parallel-arms, randomized controlled trial | Intended duration: 16 weeks | Age < 30 years, any liver disease, any kidney disease, history of CVD, retinopathy, A1c ≤ 1.4 times ULN, no T2DM, BMI > 32 kg/m^2^, not treated with a 15 mg dose of glibenclamide as their only medication for at least 3 months prior, FBG ≤ 7.8 mmol/L (140 mg/dL), PPG ≤ 10 mmol/L (180 mg/dL), adrenal insufficiency, insulin allergy, treated with systemic glucocorticoids, hemoglobinopathy | FPG < 7 mmol/L or 125 mg/dL 2-hr PPG < 10 mmol/L or <180 mg/dL
Ushakova, 2007 ^59^ Russia | Parallel-arms, randomized controlled trial | Intended duration: 8 weeks titration; 8 weeks maintenance | Age < 40 and > 70 years, any liver disease, any kidney disease, history of CVD, history of insulin treatment, retinopathy, A1c < 8%, no T2DM, BMI > 35.0 kg/m^2^, was not treated with at least 1 OA agents for at least 6 months, recurrent major hypoglycemia, using medication known to interfere with glucose metabolism, pregnant or breastfeeding women | FPG: 79.2 – 126 mg/dL (4.4 – 7.0 mmol/L) PPG: 79.2 – 162 mg/dL (4.4 – 9.0 mmol/L)
Yamada, 2007 ^78^ Japan | Parallel-arms, randomized controlled trial | Intended duration: 4 months | Any liver disease, any kidney disease, history of CVD, retinopathy, A1c ≤ 6.5%, no T2DM, treatment with a twice-daily injection of 70/30 or 50/50 premixed human insulin for < 3 months, patients who were anti-GAD antibody positive, severe hypertension (SBP/DBP 180/100 mmHg) | Self-monitored FPG < 130 mg/dL Clinic-measured PPG < 180 mg/dL

* The study population for Boehm 2002 ^9^ was patients with either type 1 or type 2 diabetes. The type 2 diabetic population was the same study population used for Boehm 2004. ^45^ The study duration was 12 weeks.

A1c = Hemoglobin A1c; BG = blood glucose; BHI = biphasic human insulin; BIAsp = biphasic insulin aspart; BID = twice daily; BMI = body mass index; CRP = C-reactive protein; CVD = cardiovascular disease; DBP = diastolic blood pressure; dl = deciliter; FPG = fasting plasma glucose; g/day = gram per day; GAD = glutamic acid decarboxylase; hr = hours; IU = international unit; kg = kilogram; kg/m2 = kilogram per square meter; L = liter; lbs = pounds; m = meter; mg = milligram; mmHg = millimeter of mercury; mmol = millimole; ng/mL = nanograms per milliliter; nmol = nanomole; NPH = Neutral Protamine Hagedorn; NR = not reported; OA = oral antidiabetic; PPG = postprandial glucose; SBP = systolic blood pressures; SU = sulfonylurea; T1DM = Type 1 diabetes mellitus; T2DM = Type 2 diabetes mellitus; TZD = thiazolidinedione; U = unit; ULN = upper limit of normal

Table 3 Population characteristics of the studies comparing a premixed insulin analogue to other diabetes treatments

Author, year | Group, N | Mean age (age range) in years | Male, n (%) | Race, n (%) | Mean BMI in kg/m2 Mean weight in kg | Mean A1c in % Mean FBG in mg/dL# | Mean duration of diabetes in years | Previous treatment, n (%)
Abrahamian, 2005 ^53^ | Insulin aspart 70/30, 89 | 62.6 | 46* (52) | NR | BMI: 28 | A1c: 9.8 | 12.7 | Insulin naive: No
NPH/regular 70/30, 88 | 62.3 | 31* (35) | NR | BMI: 28.3 | A1c: 9.85 | 9.5 | Insulin naive: No
Bebakar, 2007 ^46^ | Insulin aspart 70/30 + OA agents, 128 | 55 | 48 (92) | NR | BMI: 26.2 | A1c: 8.6 | 4.4 | Insulin naive: Yes OA agents: 128 (100)
OA agents, 63 | 52.7 | 41 (69) | NR | BMI: 25.4 | A1c: 8.5 | 4.3 | Insulin naive: Yes OA agents: 63 (100)
Boehm, 2004 ^45^ Boehm, 2002 ^9^ † | Insulin aspart 70/30, 58 | 62.8 | 32 (55*) | NR | BMI: 29.1 | A1c: 8.11 | 15.5 | Insulin naive: No
NPH/regular 70/30, 67 | 62.6 | 34 (51*) | NR | BMI: 27.2 | A1c: 8.21 | 12.9 | Insulin naive: No
Christiansen, 2003 ^13^ | Insulin aspart 70/30, 201 | 59.3 | 94* (47) | NR | BMI: 28 | A1c: 8.8 | 9.2 | Insulin: 66 (33) OA agents: 78 (39) Insulin and OA agents: 55 (27)
NPH insulin, 202 | 59.6 | 101* (50) | NR | BMI: 28.4 | A1c: 8.8 | 10.5 | Insulin: 66 (33) OA agents: 75 (37) Insulin and OA agents: 59 (29)
Coscelli, 2003 ^67^ | Insulin lispro 75/25, 18 | 59.1 | 7 (39) | NR | BMI: 29.5 Weight: 79 | FBG: 154.2 | 14.9 | Insulin naive: No Insulin: 18 (100)
Coscelli, 2003 ^67^ | NPH/regular 70/30, 15 | 59.2 | 8 (53) | NR | BMI: 30.1 Weight: 80.2 | FBG: 150.9 | 13.8 | Insulin naive: No Insulin: 15 (100)
Total, 33 | 59.1 | 15 (45) | C: 33 (100) | BMI: 29.8 Weight: 79.5 | FBG: 152.5 | 14.4 | Insulin naive: No Insulin: 33 (100)
Cox, 2007 ^74^ | Total, 45 | 52.6 | NR | NR | BMI: 35.08 | NR | 11.9 | Insulin naive: NR OA agents: 45 (100)
Hermansen, 2002 ^58^ | Total, 61 | 60.1 | 40 (66*) | NR | BMI: 27.3 | A1c: 8.3 | 11.6 | Insulin naive: No Insulin: 61* (100)
Herz, 2002 ^71^ | Insulin lispro 75/25, 19 | 56.3 | 12 (63*) | NR | BMI: 27 Weight: 76 | NR | 8.9 | Insulin naive: No Insulin: 19* (100)
NPH/regular 70/30, 18 | 55.3 | 6 (33*) | NR | BMI: 26.3 Weight: 75.8 | NR | 7.5 | Insulin naive: No Insulin: 18* (100)
Herz, 2002 ^72^ | Insulin lispro 75/25, 71 | 68.1 | 37 (52.1) | NR | BMI: 28 | A1c: 9.82 | 11.4 | Insulin naive: No
Glyburide, 72 | 67.7 | 32 (44.4) | NR | BMI: 27.8 | A1c: 9.9 | 12.4 | Insulin naive: No
Herz, 2003 ^12^ | Insulin lispro 75/25, 13 | 54.8 | 10 (77*) | NR | BMI: 29.2 | A1c: 7.81 | NR | Insulin naive: No Insulin: 13* (100)
NPH/regular 70/30, 12 | 53.6 | 7 (58*) | NR | BMI: 29.3 | A1c: 7.6 | NR | Insulin naive: No Insulin: 12* (100)
Hirao, 2008 ^61^ | Insulin aspart 70/30, 80 | 58.5 | 47 (59*) | NR | BMI: 23.7 Weight: 62.5 | A1c: 10.5 | 9.5 | Insulin naive: No OA agents: 41 (51*)
Insulin aspart + NPH insulin, 80 | 57.9 | 49 (61*) | NR | BMI:23.7 Weight: 62.1 | A1c: 10.7 | 12.2 | Insulin naive: No OA agents: 39 (49*)
Holman, 2007 ^32^ | Insulin aspart 70/30+ usual care, 235 | 61.7 | 159 (67.7) | AA: 2 (0.9) C: 221 (94) Asian: 11 (4.7) Mixed: 1 (0.4) Other: 0 (0) | BMI: 30.2 Weight: 86.9 | A1c: 8.6 FBG: 175 | 9 median (IQR: 6 – 12) | Insulin naive: Yes OA agents: 221 (94*)
Holman, 2007 ^32^ | Insulin aspart + usual care, 239 | 61.6 | 152 (63.6) | AA: 5 (2.1) C: 214 (89.5) Asian: 15 (6.3) Mixed: 4 (1.7) Other: 1 (0.4) | BMI: 29.6 Weight: 84.9 | A1c: 8.6 FBG: 173 | 9 median (IQR: 6 – 14) | Insulin naive: Yes OA agents: 227 (95*)
Holman, 2007 ^32^ | Insulin detemir + usual care, 234 | 61.9 | 143 (61.9) | AA: 2 (0.9) C: 218 (93.2) Asian: 9 (3.8) Mixed: 2 (0.9) Other: 3 (1.3) | BMI: 29.7 Weight: 85.5 | A1c: 8.4 FBG: 171 | 9 median (IQR: 6 – 12) | Insulin naive: Yes OA agents: 224 (96*)
Total, 708 | 61.7 | 454 (64.1) | AA: 9 (1.3) C: 653 (92.2) Asian: 35 (4.9) Mixed: 7 (1) Other: 4 (0.6) | BMI: 29.8 Weight: 85.8 | A1c: 8.5 FBG: 173 | 9 median (IQR: 6 – 13) | Insulin naive: Yes OA agents: 672 (95*)
Jacober, 2006 ^64^ | Total, 60 | 54.9 | 34 (56.7) | AA: 3 (5) C: 45 (75) Asian: 3 (5) H: 9 (15) | BMI: 32.9 Weight: 95.1 | A1c: 9.21 | 8.4 | Insulin naive: Yes OA agents: 60 (100)
Joshi, 2005 ^52^ | Insulin aspart 70/30, 114 | 52.41 | 76 (67*) | NR | Weight: 70.4 | A1c: 8.79 FBG: 186.59 | 9.53 | Insulin naive: NR Insulin: 62 (54.39) OA agents: 102 (89.47)
Insulin aspart + insulin glargine, 31 | 51.1 | 24 (77*) | NR | Weight: 69.63 | A1c: 8.53 FBG: 190.23 | 11.98 | Insulin naive: NR Insulin: 21 (67.74) OA agents: 25 (80.65)
Kann, 2006 ^50^ | Insulin aspart 70/30 + metformin, 128 | 61.5 | 69 (54*) | NR | BMI: 29.9 Weight: 84.2 | A1c: 9.21 | 10.3 | Insulin naive: NR
Insulin glargine + glimepiride, 127 | 61 | 62 (49*) | NR | BMI: 30.6 Weight: 86.6 | A1c: 8.9 | 10.2 | Insulin naive: NR
Kapitza, 2004 ^56^ | Total, 31 | 57 | 21 (68*) | NR | BMI: 29 | A1c: 8.7 | 12 | Insulin naive: No Insulin: 31* (100)
Kazda, 2006 ^76^ | Insulin lispro 50/50, 54 | 58.7 | 32 (59*) | NR | BMI: 31 | A1c: 8.1 FBG: 167.4 | 5.9 | Insulin naive: No Insulin: 0 in last 3 months
Kazda, 2006 ^76^ | Insulin lispro, 52 | 60.4 | 32 (62*) | NR | BMI: 31.7 | A1c: 8.2 FBG: 176.4 | 5.3 | Insulin naive: No Insulin: 0 in last 3 months
Insulin glargine, 53 | 59.1 | 23 (43*) | NR | BMI: 30.1 | A1c: 8.1 FBG: 172.8 | 5.5 | Insulin naive: No Insulin: 0 in last 3 months
Kilo, 2003 ^15^ | Insulin aspart 70/30 + metformin, 46 | 57.2 | 25 (54) | AA: 4 (9*) C: 33 (72*) H: 0 (0*) Other: 9 (20*) | BMI: 30.4 | A1c: 9.5 FBG: 241.8 | 10.4 | Insulin naive: Yes Insulin: 0 (0) OA agents: 46 (100) Insulin and OA agents: 0 (0)
Kilo, 2003 ^15^ | NPH insulin + metformin, 47 | 55.1 | 19 (40) | AA: 9 (19*) C: 30 (64*) H: 1 (2*) Other: 7 (15*) | BMI: 30.4 | A1c: 9.5 FBG: 242.7 | 10.7 | Insulin naive: Yes Insulin: 0 (0) OA agents: 47 (100) Insulin and OA agents: 0 (0)
NPH/regular 70/30 + metformin, 47 | 55.4 | 29 (52) | AA: 6 (13*) C: 35 (74*) H: 1 (2*) Other: 5 (11*) | BMI: 30.6 | A1c: 9.3 FBG: 227.2 | 8.4 | Insulin naive: Yes Insulin: 0 (0) OA agents: 47 (100) Insulin and OA agents: 0 (0)
Kvapil, 2006 ^51^ | Insulin aspart 70/30, 107 | 55.2 | 50 (47*) | NR | BMI: 30.9 Weight: 87.3 | A1c: 9.6 | 8.2 | Insulin naive: NR
Kvapil, 2006 ^51^ | Insulin aspart 70/30 + metformin, 108 | 56.4 | 53 (49*) | NR | BMI: 30.4 Weight: 85.1 | A1c: 9.3 | 6.7 | Insulin naive: NR
Metformin + glibenclamide, 114 | 58.1 | 52 (46*) | NR | BMI: 30.5 Weight: 84 | A1c: 9.4 | 8.1 | Insulin naive: NR
Malone, 2000 ^44^ Malone, 2000 ^14^ | Insulin lispro 75/25, 41 | 59.2 | 26 (63*) | NR | BMI: 29.1 | NR | 14 | Insulin naive: No Insulin: 41* (100)
Malone, 2000 ^44^ Malone, 2000 ^14^ | NPH/regular 70/30, 43 | 60.5 | 27 (63*) | NR | BMI: 29.2 | NR | 16.2 | Insulin naive: No Insulin: 43* (100)
Total, 84 | 59.9 | 53 (63*) | NR | BMI: 29.2 | NR | 15.1 | Insulin naive: No Insulin: 84* (100)
Malone, 2003 ^68^ | Insulin lispro 75/25 + metformin, 296 | 58 | 169 (57) | C: 263 (88.9) H: 22 (7.4) Other: 9 (3) African: 2 (0.7) | BMI: 29.8 Weight: 83 | A1c: 9.17 | 8 | Insulin naive: NR OA agents: 296 (100)
Glibenclamide + metformin, 301 | 59 | 146 (49) | C: 268 (89) H: 18 (6) Other: 12 (4) African: 3 (1) | BMI: 29.6 Weight: 81.7 | A1c: 9.27 | 7.4 | Insulin naive: NR OA agents: 301 (100)
Malone, 2004 ^65^ | Insulin lispro 75/25 + metformin, 52 | 54.5 (32.3 – 79.1) | 33 (63.5) | NR | BMI: 30.1 Weight: 88.5 | A1c: 8.7 FBG: 150.2 | 8.1 | Insulin naive: Yes OA agents: 52 (100)
Insulin glargine + metformin, 53 | 55.3 (35.5 – 75.1) | 33 (62.3) | NR | BMI: 31.7 Weight: 94.4 | A1c: 8.7 FBG: 155.3 | 9.8 | Insulin naive: Yes OA agents: 53 (100)
Malone, 2005 ^66^ | Insulin lispro 75/25 + metformin, 50 | 59.18 | 25 (50) | NR | BMI: 29.41 Weight: 77.82 | A1c: 8.5 FBG: 155.34 | 13.52 | Insulin naive: No Insulin: 50* (100) OA agents: 26 (52*)
Insulin glargine + metformin, 47 | 59.63 | 18 (38) | NR | BMI: 29.64 Weight: 77.21 | A1c: 8.48 FBG: 147.78 | 11.9 | Insulin naive: No Insulin: 47* (100) OA agents: 28 (60*)
Mattoo, 2003 ^70^ | Insulin lispro 75/25, 72 | 54 (30–72) | 34 (47.2) | NR | BMI: 26.9 (17.8 – 34.6) Weight: 71 | NR | 13.2 | Insulin naive: No Insulin: 72* (100)
Mattoo, 2003 ^70^ | NPH/regular 70/30, 79 | 52 (32–72) | 35 (44.3) | NR | BMI: 26.5 (17.1 – 34.5) Weight: 71 | NR | 11.8 | Insulin naive: No Insulin: 79* (100)
Total, 151 | 53 (30–72) | 69 (45.7) | NR | BMI: 26.7 (17.1 – 34.6) Weight: 71 | NR | 12.5 | Insulin naive: No Insulin: 151* (100)
McNally, 2007 ^48^ | Insulin aspart 70/30, 80 | 61.8 | 49 (61*) | NR | BMI: 29.7 Weight: 83.3 | A1c: 7.5 | 11.5 | Insulin naive: No Insulin: 80 (100)
McNally, 2007 ^48^ | NPH/regular 70/30, 80 | 62.7 | 63 (79*) | NR | BMI: 30.5 Weight: 89.1 | A1c: 7.5 | 12.1 | Insulin naive: No Insulin: 80 (100)
Total, 160 | 62.3 | 112 (70*) | NR | BMI: 30.1 Weight: 86.2 | A1c: 7.5 | 11.8 | Insulin naive: No Insulin: 160 (100)
McSorley, 2002 ^11^ | Total, 13 | 64 | 8 (62*) | NR | BMI: 28.1 | A1c: 7.7 | 13 | Insulin naive: No Insulin: 13* (100)
Nauck, 2007 ^49^ | Insulin aspart 70/30 + metformin + sulfonylurea, 248 | 58 | 126.5 (51) | NR | BMI: 30.2 Weight: 83.4 | A1c: 8.6 FBG: 203.4 | 10 | Insulin naive: NR OA agents: 248 (100)
Exenatide + metformin + sulfonylurea, 253 | 59 | 118.9 (47) | NR | BMI: 30.6 Weight: 85.5 | A1c: 8.6 FBG: 198 | 9.8 | Insulin naive: NR OA agents: 253 (100)
Niskanen, 2004 ^55^ | Total, 133 | 62.3 | 79 (59*) | NR | BMI: 28.1 | A1c: 8.5 | 12.1 | Insulin naive: No Insulin: 133* (100)
Raskin, 2005 ^39^ Brod, 2007 ^41^ | Insulin aspart 70/30 + metformin, 117 | 52.6 | 62 (53) | AA: 18 (15) C: 64 (55) Asian: 2 (2) H: 32 (27) Other: 2 (2) | BMI: 31.5 Weight: 90.6 | A1c: 9.7 FBG: 252 A1c > 8.5% at baseline, n (%): 10.2 (89) | 9.5 | Insulin naive: Yes OA agents:117 (100)
Insulin glargine + metformin, 116 | 52.3 | 65 (56) | AA: 20 (17) C: 60 (52) Asian: 5 (4) H: 30 (26) Other: 1 (1) | BMI: 31.4 Weight: 89.9 | A1c: 9.8 FBG: 243 A1c > 8.5% at baseline, n (%): 10.1 (99) | 8.9 | Insulin naive: Yes OA agents: 116 (100)
Raskin, 2007 ^40^ ‡ | Insulin aspart 70/30 + metformin, 79 | 52 | 41 (51.9) | AA: 10.3 (13) C: 41.1 (52) Asian: 2.4 (3) H: 25.3 (32) Other: 0.78 (1) | BMI: 31.2 Weight: 88.7 | A1c: 9.9 FBG: 255.6 | NR | Insulin naive: Yes Insulin: 0 (0) OA agents: 79 (100)
Insulin glargine + metformin, 78 | 51.7 | 42 (53.8) | AA: 11.7 (15) C: 36.7 (47) Asian: 3.1 (4) H: 25 (32) | BMI: 30.8 Weight: 86.2 | A1c: 9.9 FBG: 239.4 | NR | Insulin naive: Yes Insulin: 0 (0) OA agents: 78 (100)
Raskin, 2007 ^60^ | Insulin aspart 70/30, 102 | 53.4 | 46 (45*) | AA: 12* (12) C: 53* (52) Asian: 3* (3) H: 34* (33) Other: 0*(0) | BMI: 32.4 | A1c: 8.1 | 9.2 | Insulin naive: Yes Insulin: 0 (0) OA agents: 102 (100)
Metformin and pioglitazone, 98 | 54.2 | 38 (39*) | AA: 10* (10) C: 43* (44) Asian: 4* (4) H: 36* (37) Other: 5*(5) | BMI: 33.4 | A1c: 8.1 | 8.3 | Insulin naive: Yes Insulin: 0 (0) OA agents: 98 (100)
Raz, 2003 ^57^ | Insulin aspart 70/30 + rosiglitazone, 26 | 60.3 (43–77) | 19 (73.1) | C: 22 (84.6) Asian: 1 (3.8) Other: 3 (11.5) | BMI: 27.7 | A1c: 9.9 FBG: 259.8 Serum fructosamine: 398 μmol/L | 10.9 | Insulin naive: NR OA agents: 26 (100%)
Glibenclamide + rosiglitazone, 23 | 57.8 (43–71) | 13 (56.5) | C: 19 (82.6) Asian: 2 (8.7) Other: 2 (8.7) | BMI: 27.6 | A1c: 10.3 FBG: 265.2 Serum fructosamine: 409.2 μmol/L | 10.3 | Insulin naive: NR OA agents: 23 (100%)
Raz, 2005 ^54^ | Insulin aspart 70/30, 97 | 55.2 | 63 (65) | NR | BMI: 29.5 | A1c: 9.5 | 10 | Insulin naive: NR OA agents: 97* (100)
Raz, 2005 ^54^ | Insulin aspart 70/30 + pioglitazone, 93 | 56.7 | 49 (53) | NR | BMI: 29.4 | A1c: 9.6 | 9.2 | Insulin naive: NR OA agents: 93* (100)
Glibenclamide + pioglitazone, 91 | 55.8 | 56 (62) | NR | BMI: 29.5 | A1c: 9.4 | 9.9 | Insulin naive: NR OA agents: 91* (100)
Roach, 1999 ^73^ | Insulin lispro 75/25, 44 | 56.5 | 23 (52*) | NR | BMI: 28.3 | NR | 12.8 | Insulin naive: No Insulin: 44* (100)
NPH/regular 70/30, 45 | 57.4 | 19 (42*) | NR | BMI: 29.4 | NR | 11.5 | Insulin naive: No Insulin: 45* (100)
Roach, 1999 ^10^ | Insulin lispro 50/50 + insulin lispro 75/25, 34 | 58 | 18 (53*) | NR | BMI: 28.4 | NR | 12.2 | Insulin naive: No Insulin: 34* (100)
NPH/regular 50/50 + NPH/ regular 70/30, 29 | 60.2 | 12 (41*) | NR | BMI: 28.4 | NR | 13.1 | Insulin naive: No Insulin: 29* (100)
Roach, 2003 ^69^ | Insulin lispro 75/25, 57 | 53.9 | 21 (40) | Asian: 52 (100) | Weight: 62.8 | NR | 12.4 | Insulin naive: No Insulin: 57* (100)
Insulin lispro 50/50 + insulin lispro 75/25, 58 | 54.2 | 22 (40) | Asian: 55 (100) | Weight: 65.1 | NR | 13.1 | Insulin naive: No Insulin: 58* (100)
Roach, 2006 ^63^ | Total, 20 | 53.5 | 10 (50) | AA: 4* (20) C: 16* (80) | BMI: 36.7 Weight: 108 | A1c: 8.4 | NR | Insulin naive: No
Robbins, 2007 ^79^ | Insulin lispro 50/50 + metformin, 157 | 57.4 | 79 (50.3) | AA: 9 (5.7) C: 102 (65) Asian: 22 (14) H: 24 (15.3) | BMI:32.1 Weight: 89.1 | A1c: 7.8 | 11.3 | Insulin naive: No Insulin: 125 (79.6)
Insulin glargine + metformin, 158 | 58.1 | 78 (49.4) | AA: 9 (5.7) C: 100 (63.3) Asian: 23 (14.6) H: 26 (16.4) | BMI: 32 Weight: 88.1 | A1c: 7.8 | 12.5 | Insulin naive: No Insulin: 123 (77.8)
Rosenstock, 2008 ^80^ | Insulin lispro 50/50, 187 | 55.4 | 99 (53) | AA: 25 (13.4) C: 103 (55.1) H: 49 (26.2) Other: 10 (5.3) | BMI:34.1 Weight: 99.1 | A1c: 8.83 FBG: 171.81 | 10.9 | Insulin naive: No Insulin: 187 (100) Insulin and OA agents: 185 (98.9)
Insulin glargine + insulin lispro, 187 | 54 | 98 (52) | AA: 18 (9.6) C: 102 (54.6) H: 53 (28.3) Other: 14 (7.5) | BMI: 34.8 Weight: 99.8 | A1c: 8.89 FBG: 181.48 | 11.2 | Insulin naive: No Insulin: 187 (100) Insulin and OA agents: 184 (98.5)
Schernthaner, 2004 ^77^ | Insulin lispro 50/50, 18 | 66.1 | 3 (17*) | NR | BMI: 29.5 | A1c: 8.3 | 16.2 | Insulin naive: No Insulin: 18* (100)
Schernthaner, 2004 ^77^ | NPH/regular 70/30, 17 | 67.8 | 5 (29*) | NR | BMI: 28.8 | A1c: 8.5 | 14.2 | Insulin naive: No Insulin: 17* (100)
Total, 35 | 67 | 8 (23*) | NR | BMI: 29.2 | NR | 15.3 | Insulin naive: No Insulin: 35* (100)
Schwartz, 2006 ^62^ | Insulin lispro 75/25, 8 | NR | NR | NR | NR | NR | NR | Insulin naive: No
Schwartz, 2006 ^62^ | Insulin lispro 50/50, 7 | NR | NR | NR | NR | NR | NR | Insulin naive: No
Schwartz, 2006 ^62^ | NPH/regular 70/30, 8 | NR | NR | NR | NR | NR | NR | Insulin naive: No
Total, 23 | 61.3 | 17 (73.9) | AA: 2 (8.7) C: 13 (56.5) H: 8 (34.8) | BMI: 33 Weight: 98.5 | A1c: 8.1 FBG: 158.7 | NR | Insulin naive: No Insulin: 23 (100)
Sun, 2007 ^75^ | Insulin lispro 75/25, 895 | 62.8 | 439* (49.1) | AA: 161* (17.5) C: 268* (30.1) H: 63* (6.8) | Weight: 93.9 | A1c: 8.6 | 20.5 | Insulin naive: Yes
Sun, 2007 ^75^ | Insulin glargine, 3624 | 58.4 | 1740* (48.5) | AA: 362* (10.3) C: 906* (25.2) H: 72* (2.4) | Weight: 93.3 | A1c: 8.6 | 24.7 | Insulin naive: Yes
NPH/regular 70/30, 3647 | 65.7 | 1641* (44.7) | AA: 584* (16.5) C: 1204* (32.6) H: 73* (1.6) | Weight: 92.3 | A1c: 8.4 | 18.3 | Insulin naive: Yes
Tamemoto, 2007 ^47^ | Insulin aspart 70/30, 14 | 55.9 | 6 (54) | NR | BMI: 23.9 | A1c: 9.13 FBG: 183.3 | 9.8 | Insulin naive: NR OA agents: 14 (100)
Insulin glargine, 20 | 61.7 | 13 (68) | NR | BMI: 25.5 | A1c: 8.45 FBG: 184.1 | 10.4 | Insulin naive: NR OA agents: 19 (100)
Tirgoviste, 2003 ^43^ Roach, 2001 ^42^ | Insulin lispro 75/25, 85 | 58.7 | 30 (35*) | NR | BMI: 26.8 Weight: 74.1 | A1c: 9.85 FBG: 208.8 | 10.3 | Insulin naive: Yes OA agents: 85 (100)
Tirgoviste, 2003 ^43^ Roach, 2001 ^42^ | Glibenclamide, 87 | 60.3 | 31 (36*) | NR | BMI: 27.6 Weight: 75.8 | A1c: 10.07 FBG: 219.6 | 10.2 | Insulin naive: Yes OA agents: 87 (100)
Total, 172 | 59.5 | 61 (35*) | NR | Weight: 75 | NR | 10.2 | Insulin naive: Yes OA agents: 172 (100)
Ushakova, 2007 ^59^ | Insulin aspart 70/30 TID, 104 | 58 | 17 (16.3) | NR | BMI: 29.8 Weight: 79.3 | A1c: 10.4 | 9.9 | Insulin naive: Yes OA agents: 104 (100)
Ushakova, 2007 ^59^ | Insulin aspart 70/30 BID + metformin, 100 | 58.4 | 27 (27) | NR | BMI: 29.2 Weight: 78.4 | A1c: 10.4 | 8.4 | Insulin naive: Yes OA agents: 100 (100)
OA agents, 104 | 58.4 | 21 (20.2) | NR | BMI: 29.3 Weight: 78 | A1c: 10.1 | 8.3 | Insulin naive: Yes OA agents: 104 (100)
Yamada, 2007 ^78^ | Insulin lispro 50/50, 15 | 66 | 12 (80*) | NR | BMI: 27 | A1c: 7.59 FBG: 130.3 | 13.7 | Insulin naive: No Insulin: 15 (100)
NPH/regular 70/30 + NPH/regular 50/50, 15 | 66.3 | 11 (73*) | NR | BMI: 23.8 | A1c: 7.33 FBG: 141.8 | 15.9 | Insulin naive: No Insulin: 15 (100)

# All numbers have been converted from mmol/L to mg/dL. To convert from mg/dL to mmol/L, divide by 18.

* Number has been imputed.

† The study population for Boehm 2002 ^9^ was patients with either type 1 or type 2 diabetes. The type 2 diabetic population was the same study population used for Boehm 2004. ^45^

‡ Raskin 2007 ^40^ was conducted among a subpopulation of Raskin 2005 ^39^ who were not using thiazolidinediones.

μmol/L = micromole per liter; A1c = hemoglobinA1c; AA = African American; BMI = body mass index; BID = twice daily; C = Caucasian; dL = deciliter; FPG = fasting blood glucose; H = Hispanic; IQR = interquartile range; kg = kilogram; kg/m2 = kilogram per square meter; mg/dL = milligram per deciliter; NPH = neutral protamine Hagedorn; NR = not reported; OA = oral antidiabetic medication; TID = thrice daily

Table 4 Comparative effectiveness of premixed insulin analogues and other diabetes treatments on intermediate outcomes

Author, year | Intervention | Fasting blood glucose in mg/dL# | 2-hr PPG in mg/dL after breakfast# | Pre-dinner glucose in mg/dL# | 2-hr PPG in mg/dL after dinner# | A1c in %# | Quality of life#
Insulin aspart 70/30 vs. long-acting insulin analogues
Holman, 2007 ^32^ | GP1: Insulin aspart 70/30 (v) Start: 16 median IU/day Range: 10 – 26 IU/day T: bid D: 1 year Usual care D: 1 year GP2: Insulin detemir (v) Start: 16 median IU/day Range: 10 – 24 IU/day T: Bedtime, twice if required D: 1 year Usual care D: 1 year | GP1 F-B: -45 (56) p: <0.001 GP2 F-B: -59 (52) GP1–GP2: 14* | PPG (time not specified) (mg/dL) GP1 F-B: -68 (63) p: <0.001 GP2 F-B: 47 (54) GP1–GP2: -115* | GP1 F: 113.04 Median GP2 F: 115.56 Median | | Total glycated hemoglobin GP1 B: 8.6 (0.8) F: 7.3 (0.9) p: <0.001 vs. GP2 F-B: -1.3 (1.1) GP2 B: 8.4 (0.8) F: 7.6 (1) F-B: -0.8 (1) GP1–GP2: 0* Glycated hemoglobin ≤ 7.0%, n (%) GP1 98 (41.7) p: <0.001 vs. GP2 GP2 65 (27.8) | EQ-5D GP1 F: 0.76 (95% CI: 0.73 – 0.8) p: overall 0.48 GP2 F: 0.78 (95% CI: 0.75 – 0.81)
Kann, 2006 ^50^ | GP1: Insulin aspart 70/30 (v) Start: 0.1 U/kg bid Mean: 0.4 U/kg T: Breakfast, dinner D: 26 weeks Metformin (v) Start: 500 mg bid or current dose T: Breakfast, dinner D: 26 weeks GP2: Insulin glargine (v) Start: 0.2 U/kg qd Mean: 0.39 U/kg T: Preferred time (constant through study) D: 26 weeks Glimepiride (v) Start: 1 mg daily or current dose T: Breakfast D: 26 weeks | GP1 B: 187.2^†^ F: 136.8 (95% CI: 131.58 – 143.46) F-B: -50.4* GP2 B: 190.8^†^ F: 136.8 (95% CI: 129.6 – 145.26) F-B: -54* GP1–GP2: 3.6* Fasting plasma glucose (time not specified) (mg/dL) GP1 F-B: -46.8 (4.32) p: 0.23 vs. GP2 GP2 F-B: -39.6 (4.5) GP1–GP2: -7* | 90-min PPG - after breakfast (mg/dL) GP1 B: 248.4^†^ F: 158.4^†^ F-B: -90* GP2 B: 241.2^†^ F: 187.2^†^ F-B: -54* GP1–GP2: -36* | GP1 B: 187.2^†^ F: 172.8^†^ p: NS F-B: -14.4* GP2 B: 190.8^†^ F: 156.6^†^ F-B: -34.2* GP1–GP2: 19.8 | 90-min PPG - after dinner (mg/dL) GP1 B: 221.4^†^ F: 156.6^†^ F-B: -66.6* GP2 B: 223.2^†^ F: 183.6^†^ F-B: -39.6* GP1–GP2: -27* | GP1 F: 7.5 (1.1) p: 0.01 GP2 F: 7.9 (1.3) GP1–GP2: -0.5 (95% CI: -0.8 – -0.2) p: 0.0002 A1c < 7%, n (%) GP1 42* (33.1) p: 0.2711 GP2 33* (26.2)
Raskin, 2005 ^39^ ^40^ | GP1: Insulin aspart 70/30 (v) Start: 10 or 12 U T: Breakfast, dinner D: Unclear Metformin (v) Range: 1500 – 2550 mg/day T: NR D: Unclear GP2: Insulin glargine (v) Start: 10–12 U T: Bedtime D: Unclear Metformin (v) Range: 1500 – 2550 mg/day T: NR D: Unclear | GP1 F: 118.75^†^ p: <0.05 GP2 F: 112.5^†^ GP1‖ F: 122.4^†^ p: NS GP2‖ F: 117^†^ Fasting plasma glucose (time not specified) (mg/dL) GP1 B: 252 (67.4) F: 127 (40.6) p: NS F-B: 125 (72.9) GP2 B: 243 (68.8) F: 117 (44.3) F-B: 125 (74.4) GP1–GP2: 0* GP1‖ F-B: -128.88 (75.06) p: 0.11 GP2 F-B: -126 (79.02) GP1–GP2: -3* | 90-min PPG - after breakfast (mg/dL) GP1 F: 153.125^†^ p: NS GP2^‖^ F: 168.75^†^ GP1^‖^ F: 154.8^†^ p: NS GP2^‖^ F: 172.8^†^ | GP1 F: 120.31^†^ p: <0.05 GP2 F: 134.38^†^ GP1^‖^ F: 129.6^†^ p: NS GP2^‖^ F: 131.4^†^ | 90-min PPG - after dinner (mg/dL) GP1 F: 135.5^†^ p: <0.05 GP2 F: 171.88^†^ GP1^‖^ F: 127.62 (40.68) p: 0.0008 GP2^‖^ F: 176.22 (59.04) Dinner postprandial glucose increment (mg/dL) GP1–GP2: 19.386^†^ p: 0.003 | GP1 B: 10* F: 6.91 (1.17) p: <0.01 F-B: -2.79 (0.11) p: <0.01 GP2 B: 9* F: 7.41 (1.24) F-B: -2.36 (0.11) GP1–GP2: -1* GP1^‖^ F: 7 (1.3) p: 0.035 F-B: -2.89 (1.6) p: 0.035 GP2^‖^ F: 7.4 (1.3) F-B: -2.46 (1.6) A1c < 7.0%, n (%) GP1 71.3* (66†) p: <0.001 GP2 45.6* (40†) GP1^‖^ (65) p: 0.003 GP2^‖^ (41) A1c ≤ 6.5%, n (%) GP1 43.2* (40†) p: 0.036 GP2 31.9* (28†) GP1^‖^ (40) p: 0.17 GP2^‖^ (29)
Tamemoto, 2007 ^47^ | GP1: Insulin aspart 70/30 (v) Start: 10–16 U/day Mean: 26.7 U T: Breakfast, dinner D: 6 months Continued OA agents (NR) T: NR D: 6 months GP2: Insulin glargine (v) Start: 6–8 U/day T: NR D: 6 months Continued OA agents (NR) T: NR D: 6 months | GP1 B: 183.3 (54.6) p: 0.90 F: 141.4 (59.8) p: 0.79 vs. GP2; <0.01 vs. baseline F-B: -41.9* GP2 B: 184.1 (42.1) F: 136.0 (40.3) F-B: -48.1* GP1–GP2: 6.2 | | | | GP1 F-B: -1.2 (1.06) p: 0.49 GP2 F-B: -0.95 (0.84) GP1–GP2: 0* A1c < 7%, n (%) GP1 1 (9.1) p: NS GP2 6 (31.6)
Insulin aspart 70/30 vs. rapid-acting insulin analogues
Holman, 2007 ^32^ | GP1: Insulin aspart 70/30 (v) Start: 16 median IU/day Range: 10 – 26 IU/day T: bid D: 1 year Usual care D: 1 year GP2: Insulin aspart (v) Start: 18 median IU/day Range: 9 – 24 IU/day T: Breakfast, lunch, dinner D: 1 year Usual care D: 1 year | GP1 F-B: -45 (56) p: <0.001 vs. GP2 GP2 F-B: -23 (49) GP1–GP2: -22* | PPG (time not specified) (mg/dL) GP1 F-B: -68 (63) p: <0.001 vs. GP2 GP2 F-B: -83 (54) GP1–GP2: 15* | GP1 F: 113.04 Median GP2 F: 128.52 Median | | Total glycated hemoglobin GP1 B: 8.6 (0.8) F: 7.3 (0.9) p: 0.08 vs. GP2 F-B: -1.3 (1.1) GP2 B: 8.6 (0.8) F: 7.2 (0.9) F-B: -1.4 (1) GP1–GP2: 0* Glycated hemoglobin ≤ 7.0% GP1 98 (41.7) p: 0.08 vs. GP2 GP2 116 (48.7) | EQ-5D GP1 F: 0.76 (95% CI: 0.73 – 0.8) p: overall 0.48 GP2 F: 0.76 (95% CI: 0.73 – 0.79)
Insulin aspart 70/30 vs. rapid-acting with long-acting insulin analogues
Joshi, 2005 ^52^ | GP1: Insulin aspart 70/30 (v) Mean: 40.19 U/day T: bid D: 12 weeks GP2: Insulin aspart (v) Mean: 28.26 U/day T: Before every meal D: 12 weeks Insulin glargine (v) Mean: 24.52 U/day T: Bedtime D: 12 weeks | GP1 B: 186.59 (47.35) F: 114.83 (18.68) F-B: -72* p: <0.0001 GP2 B: 190.23 (55.63) F: 110.61 (16.79) F-B: -79* p: <0.0001 GP1–GP2: 7* | PPG (time not specified) (mg/dL) GP1 B: 287.29 (58.4) F: 171.54 (28.75) F-B: -115* p: <0.0001 GP2 B: 281.42 (68.76) F: 177.52 (24.72) F-B: -103* p: <0.0001 GP1–GP2: -12* | | | GP1 B: 8.79 (1.13) F: 7.2 (0.83) F-B: -1.58 p: <0.0001 GP2 B: 8.53 (1.22) F: 7.37 (0.83) F-B: -1.16 p: <0.0001 GP1–GP2: -1* p: <0.05 A1c < 7%, n (%) GP1 52* (45.61) GP2 10* (32.26)
Insulin aspart 70/30 vs. premixed human insulins
Abrahamian, 2005 ^53^ | GP1: Insulin aspart 70/30 (v) Mean: 0.49 U/kg (start), 0.61 U/kg (end) T: Breakfast, lunch, dinner D: 24 weeks GP2: NPH/regular 70/30 (v) Mean: 0.46 U/kg (start), 0.59 U/kg (end) T: Breakfast, dinner D: 24 weeks | GP1 F: 151† (SEM 4†) GP2 F: 143† (SEM 4†) | 90-min PPG - after breakfast (mg/dL) GP1 F: 175† (SEM 10†) GP2 F: 189† (SEM 20†) 90-min PPG increment - after breakfast (mg/dL) F: p: 0.0572 vs. GP2 (favoring GP1) | GP1 F: 142 (SEM 7†) p: 0.0069 vs GP2 GP2 F: 166 (SEM 15†) | 90-min PPG - after dinner (mg/dL) GP1 F: 154 (SEM 15†) p: 0.0022 vs GP2 GP2 F: 182 (SEM 7†) 90-min PPG increment - after dinner (mg/dL) F: p: 0.4096 | GP1 B: 9.8 (1.55) F: 7.6 (1.1) F-B: -2* p: <0.0001 GP2 B: 9.85 (1.55) F: 7.7 (1.1) F-B: -2* p: <0.0001 GP1–GP2: 0* p: 0.641 vs GP2
Boehm, 2004 ^9^ ^45^ ^‡^ | GP1: Insulin aspart 70/30 (v) Start: 0.57 U/kg T: Breakfast, dinner D: 24 months GP2: NPH/regular 70/30 (v) Start: 0.57 U/Kg T: Breakfast, dinner D: 24 months | GP1 B: 151.2 F: 160.56 (SE 5.04) F-B: 10* GP2 B: 149.4 F: 148.32 (SE 4.86) F-B: -1* GP1–GP2: 12.06 (95% CI: -0.9 – 25.2) p: NS | 90-min PPG - after breakfast (mg/dL) GP1 B: 212.4 F: 187.2 (SE 6.66) F-B: -25* GP2 B: 212.4 F: 205.2 (SE 6.48) F-B: -7* GP1–GP2: -18.18 (95% CI: -35.46 – -0.9) p: <0.05 | | 90-min PPG - after dinner (mg/dL) GP1 B: 181.8 F: 165.96 (SE 5.94) F-B: -16* GP2 B: 187.2 F: 183.6 (SE 5.76) F-B: -3* GP1–GP2: -18.54 (95% CI: -34.02 – -3.24) p: <0.02 | GP1 F: 8.35 (0.2) GP2 F: 8.13 (0.16) GP1–GP2: 0.03 (90% CI: -0.29 – 0.34) p: 0.89
Hermansen, 2002 ^58^ | GP1: Insulin aspart 70/30 (fix) Start: 0.4 U/kg T: Breakfast D: 1 day GP2: NPH/regular 70/30 (fix) Start: 0.4 U/kg T: Breakfast D: 1 day | | GP1 F: 13.9^†^ GP2 F: 15.0^†^ 2-hr PPG excursion GP1 F: 7.7 (2.7) p: <0.01 Ratio between treatments = 0.81 (95% CI: 0.71 – 0.93) p: <0.01
Kapitza, 2004 ^56^ | GP1: Insulin aspart 70/30 (NA) T: Breakfast (15 min after) D: 1 day GP2: NPH/regular 70/30 (NA) T: Breakfast (15 min before) D: 1 day | | 2-hr PPG increment - after breakfast (mg/dL) GP1 F: 52.2^†^ GP2 F: 91.8^†^
Kapitza, 2004 ^56^ | GP1: Insulin aspart 70/30 (NA) T: Breakfast (15 min after) D: 1 day GP2: NPH/regular 70/30 (NA) T: Breakfast (right before) D: 1 day | | 2-hr PPG increment - after breakfast (mg/dL) GP1 F: 52.2^†^ GP2 F: 81^†^
Kapitza, 2004 ^56^ | GP1: Insulin aspart 70/30 (NA) T: Breakfast (right before) D: 1 day GP2: NPH/regular 70/30 (NA) T: Breakfast (15 min before) D: 1 day | | 2-hr PPG increment - after breakfast (mg/dL) GP1 F: 81^†^ GP2 F: 91.8^†^
Kapitza, 2004 ^56^ | GP1: Insulin aspart 70/30 (NA) T: Breakfast (right before) D: 1 day GP2: NPH/regular 70/30 (NA) T: Breakfast (right before) D: 1 day | | 2-hr PPG increment - after breakfast (mg/dL) GP1 F: 81^†^ GP2 F: 81^†^
Kilo, 2003 ^15^ | GP1: Insulin aspart 70/30 (v) Start: 0.16 U/day Mean: 26 U/day T: Dinner D: 12 weeks Metformin (fix) Mean: about 2200 mg Range: 500 – 2550 mg T: 1–3 times/day D: 4 weeks run-in, then 12 weeks GP2: NPH/regular 70/30 (v) Start: 0.16 U/day Mean: 29 U/day T: Dinner D: 12 weeks Metformin (fix) Mean: about 2200 mg Range: 500 – 2550 mg T: 1–3 times/day D: 4 weeks run-in, then 12 weeks | GP1 F-B: -75 (72.3) GP2 F-B: -63 (86.2) GP1–GP2: -12* | GP1 B: 265† (±SE 5–10†) F: 190† (±SE 5–10†) F-B: -75 GP2 B: 266† (±SE 5–10†) F: 180† (±SE 5–10†) F-B: -86 GP1–GP2: 11 | | GP1 B: 250† (±SE 5–10†) F: 165† (±SE 5–10†) F-B: -85 GP2 B: 235† (±SE 5–10†) F: 168† (±SE 5–10†) F-B: -67 GP1–GP2: -18 | GP1 F-B: -1.3 (SE 0.2†) GP2 F-B: -1.1 (SE 0.2†) GP1–GP2: 0*
McNally, 2007 ^48^ | GP1: Insulin aspart 70/30 (v) Start: 100 U/mL Mean: 68.8 U Range: 6 – 238.7 U T: Breakfast, dinner D: 16 weeks GP2: NPH/regular 70/30 (v) Start: 100 U/mL Mean: 66.6 U Range: 11.3 – 240 U T: Breakfast, dinner D: 16 weeks | | | | | GP1 F: 7.28 GP2 F: 7.22 GP1–GP2: 0.06 (95% CI: -0.04 – 0.17) p: 0.21 | WHO-DTSQ GP1 F: 30.6 (5.84) GP2 F: 30.95 (5.01) GP1–GP2: -0.46 p: 0.25
Insulin aspart 70/30 vs. intermediate-acting human insulins
Christiansen, 2003 ^13^ | GP1: Insulin aspart 70/30 (v) Start: insulin naïve: 8 – 16 U/day; taking NPH prior to trial: pretrial dose T: Breakfast, dinner D: 16 weeks GP2: NPH insulin (v) Start: insulin naïve: 8 – 16 U/day; taking NPH prior to trial: pretrial dose T: Breakfast, dinner D: 16 weeks | GP1 F-B: -25.2 GP2 F-B: -27 GP1–GP2: 2* | | | | GP1 F-B: 0.67 p: <0.0001 vs. baseline GP2 F-B: 0.61 p: <0.0001 vs. baseline GP1–GP2: 0*
Kilo, 2003 ^15^ | GP1: Insulin aspart 70/30 (v) Start: 0.16 U/day Mean: 26 U/day T: Dinner D: 12 weeks Metformin (fix) Mean: about 2200 mg Range: 500 – 2550 mg T: 1–3 times/day D: 4 weeks run-in, then 12 weeks GP2: NPH insulin (v) Start: 0.16 U/day Mean: 28 U/day T: Bedtime D: 12 weeks Metformin (fix) Mean: about 2200 mg Range: 500 – 2550 mg T: 1–3 times/day D: 4 weeks run-in, then 12 weeks | GP1 F-B: -75 (72.3) GP2 F-B: -91 (72) GP1–GP2: 16* | GP1 B: 265† (±SE 5–10†) F: 190† (±SE 5–10†) F-B: -75 GP2 B: 266† (±SE 5–10†) F: 180† (±SE 5–10†) F-B: -86 GP1–GP2: 11 | | GP1 B: 250† (±SE 5–10†) F: 165† (±SE 5–10†) F-B: -85 GP2 B: 240† (±SE 5–10†) F: 190† (±SE 5–10†) F-B: -50 GP1–GP2: -35 | GP1 F-B: -1.3 (SE 0.2†) GP2 F-B: -1.2 (SE 0.2†) GP1–GP2: 0*
Insulin aspart 70/30 vs. oral antidiabetic agents
Bebakar, 2007 ^46^ | GP1: Insulin aspart 70/30 (v) Start: 0.2 U/kg Range: 0.16 U/kg (qd group) – 0.43 U/kg (bid group) T: once or twice daily D: 24 weeks GP2: OA agents (v) T: NR D: 24 weeks | GP1 F-B: -39.6 (54) p: <0.005 vs. GP2 GP2 F-B: -9 (48.24) GP1–GP2: -31* Fasting plasma glucose (time not specified) (mg/dL) GP1 F-B: -34.38 (39.96) p: <0.05 vs. GP2 GP2 F-B: -18.18 (39.6) GP1–GP2: -16* | 90-min PPG - after breakfast (mg/dL) GP1 F-B: -43.38 (84.24) p: <0.05 vs. GP2 GP2 F-B: -14.04 (71.46) GP1–GP2: -18* | GP1 F-B: -36.72 (69.66) p: <0.005 vs. GP2 GP2 F-B: 1.44 (61.92) GP1–GP2: -38* | 90-min PPG - after dinner (mg/dL) GP1 F-B: -68.22 (80.64) p: <0.005 vs. GP2 GP2 F-B: -9.36 (75.24) GP1–GP2: -59* | GP1 F-B: -1.16 (1.01) p: <0.005 vs. GP2 GP2 F-B: -0.58 (0.95) GP1–GP2: 0* A1c < 7%, n (%) GP1 32* (25) GP2 8* (12)
Kvapil, 2006 ^51^ | GP1: Insulin aspart 70/30 (v) Start: 0.3 U/kg Mean: 0.51 U/kg T: Breakfast, dinner D: 16 weeks GP2: Metformin (fix) Mean: 1660 mg daily Range: 500 – 3000 mg T: NR D: 16 weeks Glibenclamide (v) Start: 1.75 mg Mean: 2.33 (start), 6.58 mg daily (end) T: once or twice daily D: 16 weeks | GP1–GP2: -0.18 (SE 4.86) p: NS | 90-min PPG - after breakfast (mg/dL) GP1–GP2: -5.22 (SE 7.2) p: NS | GP1–GP2: 10.26 (SE 6.12) p: NS | 90-min PPG - after dinner (mg/dL) GP1–GP2: 2.7 (SE 6.66) p: NS | GP1–GP2: 0.2 (SE 0.15) p: NS
Kvapil, 2006 ^51^ | GP1: Insulin aspart 70/30 (v) Start: 0.2 U/kg Mean: 0.3 U/kg T: Breakfast, dinner D: 16 weeks Metformin (fix) Mean: 1660 mg daily Range: 500 – 3000 mg T: NR D: 16 weeks GP2: Metformin (fix) Mean: 1660 mg daily Range: 500 – 3000 mg T: NR D: 16 weeks Glibenclamide (v) Start: 1.75 mg Mean: 2.33 (start), 6.58 mg daily (end) T: once or twice daily D: 16 weeks | GP1–GP2: -1.26 (SE 4.86) p: NS | 90-min PPG - after breakfast (mg/dL) GP1–GP2: -5.22 (SE 7.2) p: NS | GP1–GP2: 9.18 (SE 6.12) p: NS | 90-min PPG - after dinner (mg/dL) GP1–GP2: -0.36 (SE 6.66) p: NS | GP1–GP2: -0.20 (SE 0.15) p: NS
Raskin, 2007 ^60^ | GP1: Insulin aspart 70/30 (v) Start: 6 U bid Mean: 0.6 U/kg/day T: Breakfast, dinner D: 34 weeks Metformin (fix) Mean: 2446 mg T: NR D: 34 weeks Pioglitazone (fix) Mean: 32.5 mg T: NR D: 34 weeks GP2: Metformin (fix) Mean: 2439 mg T: NR D: Unclear Pioglitazone (fix) Mean: 31.7 T: NR D: Unclear | GP1 B: 173.16 (39.78) p: NS F: 129.78 (50.04) p: < 0.001 F-B: -44.1 (49.86) p: < 0.001 GP2 B: 163.26 (35.46) F: 162.18 (40.86) F-B: 1.08 (43.56) GP1–GP2: -45* Met target FBG values of 79.2 – 109.8 mg/dL (4.4 – 6.1 mmol/L) GP1 34* (37) GP2 2* (2) | | GP1 B: 167.4† (SE 7.2†) F: 124.2 † (SE 3.6†) p: < 0.05 F-B: 43 GP2 B: 178.2† (SE 7.2 †) F: 156.6 † (SE 7.2 †) F-B: 22 GP1–GP2: 21* | | GP1 B: 8* F: 6.5 (1) p: < 0.0001 F-B: -1.5 (1.1) p: <0.05 vs. baseline; < 0.0001 vs. GP2 GP2 B: 8* F: 7.8 (1.2) F-B: -0.2 (0.9) p: <0.05 vs. baseline GP1–GP2: -2* A1c < 7.0%, n (%) GP1 71* (76) p: < 0.001 GP2 21* (24) A1c ≤ 6.5%, n (%) GP155 (59†) p: < 0.001 GP2 10 (11†)
Raz, 2003 ^57^ | GP1: Insulin aspart 70/30 (v) Start: 6 – 8 U bid T: Breakfast, dinner D: 6 weeks Rosiglitazone (fix) Start: 4 mg T: Breakfast D: 6 weeks GP2: Glibenclamide (fix) Range: 7.5 – 15 mg T: Dinner D: 6 weeks Rosiglitazone (fix) Start: 4 mg T: Breakfast D: 6 weeks | GP1 F-B: 58 p: NS vs. GP2 GP2 F-B: 34.2 GP1–GP2: 24* | PPG (time not specified) (mg/dL) GP1 F-B: 80.6 GP2 F-B: 52.9 GP1–GP2: 28* | GP1 F-B: 36.2 p: NS vs. GP2 GP2 F-B: 43.3 GP1–GP2: -7* | GP1 F-B: 72.8 p: NS vs. GP2 GP2 F-B: 47 GP1–GP2: 26* | GP1 B: 9.9 F: 9.4 F-B: 0.7 p: NS vs. GP2 GP2 B: 10.3 F: 10.1 F-B: 0.2 GP1–GP2: 1*
Raz, 2005 ^54^ | GP1: Insulin aspart 70/30 (v) Start: 0.3 U/kg Mean: 0.7 U/kg T: Breakfast, dinner D: 18 weeks GP2: Glibenclamide (v) Start: 5 to 10 mg Mean: 14 mg T: Breakfast D: 18 weeks Pioglitazone (fix) Start: 30 mg Mean: 30 mg T: Breakfast D: 18 weeks | GP1 B: 178* F: 162^†^ F-B: -16 p: NS GP2 B: 171* F: 169 (65) F-B: -2 p: NS GP1–GP2: -14* | 90-min PPG - after breakfast (mg/dL) GP1 F: 196.2^†^ GP2 F: 223.2^†^ | | 90-min PPG - after dinner (mg/dL) GP1 F: 199.8^†^ GP2 F: 212.4^†^ 90-min PPG increment - after dinner (mg/dL) GP1–GP2: -8.1 (8.46) p: NS | GP1 B: 9.5 (1.3) F: 9 (1.3) F-B: -0.5 p: NS GP2 B: 9.4 (1.4) F: 9 (2.1) F-B: -0.4 p: NS GP1–GP2: -0.9*
Raz, 2005 ^54^ | GP1: Insulin aspart 70/30 (v) Start: 0.2 U/kg Mean: 0.5 U/kg T: Breakfast, dinner D: 18 weeks Pioglitazone (fix) Start: 30 mg Mean: 30 mg T: Breakfast D: 18 weeks GP2: Glibenclamide (v) Start: 5 to 10 mg Mean: 14 mg T: Breakfast D: 18 weeks Pioglitazone (fix) Start: 30 mg Mean: 30 mg T: Breakfast D: 18 weeks | GP1 B: 184* F: 153 (45) p: 0.012 vs GP2 F-B: -31 p: NS GP2 B: 171* F: 169 (65) F-B: -2 p: NS GP1–GP2: -29* | 90-min PPG - after breakfast (mg/dL) GP1 F: 178.2^†^ GP2 F: 223.2^†^ | | 90-min PPG increment - after dinner (mg/dL) F: 178.2^†^ GP2 F: 212.4^†^ GP1–GP2: -12.96 (8.64) p: NS | GP1 B: 9.6 (1.3) F: 8.4 (1.2) F-B: -1.2 p: NS GP2 B: 9.4 (1.4) F: 9 (2.1) F-B: -0.4 p: NS GP1–GP2: -0.64 (0.23) p: 0.005
Ushakova, 2007 ^59^ | GP1: Insulin aspart 70/30 (v) Start: 0.3 – 0.5 U/kg Mean: 55.5 U T: bid for 2 weeks, then tid D: 16 weeks GP2: Continuation of OA agents (v) T: NR D: 16 weeks | GP1 B: 235.8† F: 163.8† F-B: 72 GP2 B: 225† F: 171† F-B: 54 GP1–GP2: 18* | | GP1 B: 261† F: 156.6† F-B: 105 GP2 B: 243† F: 178.2† F-B: 65 GP1–GP2: 40* | | GP1 F-B: -2.9 (1.5) p: < 0.001 vs. GP2 GP2 F-B: -2.1 (1.4) GP1–GP2: -0.65 (95% CI: -0.958 – -0.337) p: <0.001 vs. GP2 A1c ≤ 7.0%, n (%) GP1 42 (42) p: 0.012 GP2 27 (26.2) A1c after 3-month extension GP1 F: 7.2 (1.2) A1c ≤ 7.0% after 3-month extension, n (%) GP1 22 (51.2) | Diabetes Health Profile GP1 F-B: p: <0.001 vs. baseline GP2 F-B: p; <0.001 vs. baseline
Ushakova, 2007 ^59^ | GP1: Insulin aspart 70/30 (v) Start: 0.3 – 0.5 U/kg Mean: 44.8 U T: Breakfast, dinner D: 16 weeks metformin (varied) Start: 500 mg qd or bid or 850 mg qd T: NR D: 14 weeks (started after 2 weeks) GP2: Continuation of OA agents (v) T: NR D: 16 weeks | GP1 B: 234† F: 160.2† F-B: 74 GP2 B: 225† F: 171† F-B: 54 GP1–GP2: 20* | | GP1 B: 252† F: 172.8† F-B: 80 GP2 B: 243† F: 178.2† F-B: 65 GP1–GP2: 15* | | GP1 F-B: -3 (1.6) p: < 0.001 vs. GP2 GP2 F-B: -2.1 (1.4) GP1–GP2: -0.85 vs (95% CI: -1.163 – -0.537) p: <0.001 A1c ≤ 7.0%, n (%) GP1 45 (45) p: 0.002 GP2 27 (26.2) A1c after 3-month extension GP1 F: 7.2 (1.4) A1c ≤ 7.0% after 3-month extension, n (%) GP1 23 (54.8) | Diabetes Health Profile GP1 F-B: p: <0.001 vs. baseline GP2 F-B: p; <0.001 vs. baseline
Insulin aspart 70/30 vs. exenatide
Nauck, 2007 ^49^ | GP1: Insulin aspart 70/30 (v) Start: 15.7 U/day Mean: 24.4 U/day T: Breakfast, dinner D: 52 weeks ‘Optimally’ effective metformin and sulfonylurea therapy (v) T: NR D: 52 weeks GP2: Exenatide (v) Start: 5 μg bid Range: 5 – 10 μg bid T: Breakfast D: 52 weeks ‘Optimally’ effective metformin and sulfonylurea (v) T: NR D: 52 weeks | GP1 B: 177.12^†^ (SE 3.006^†^) F: 147.06^†^ (SE 1.512^†^) p: 0.037 F-B: -30.06* p: <0.001 GP2 B: 173.34^†^ (SE 2.16^†^) F: 153^†^ (SE 2.16^†^) F-B: -20.34* p: <0.001 Fasting plasma glucose (time not specified) (mg/dL) GP1 F-B: -30.6 p: <0.001 GP2 F-B: -32.4 p: <0.001 GP1–GP2: 1.8 (95% CI: -7.2 – 10.8) p: 0.689 | GP1 B: 229.5^†^ (SE 3.6^†^) F: 171^†^ (SE 3.06^†^) F-B: -58.5* p: <0.001 GP2 B: 222.84^†^ (SE 3.06^†^) F: 153^†^ (SE 2.16^†^) p: <0.001 F-B: -69.84* p: <0.001 GP1–GP2: 11.34* PPG excursion - after breakfast (NA) GP1 p: <0.001 | GP1 B: 171.72^†^ (SE 3.42^†^) F: 141.12^†^ (SE 3.06^†^) p: <0.001 vs. baseline F-B: -30.6* GP2 B: 168.84^†^ (SE 3.78^†^) F: 147.24^†^ (SE 3.06^†^) p: <0.001 vs. baseline F-B: -21.6* GP1–GP2: -9* | GP1 B: 210.06^†^ (SE 3.78^†^) F: 165.06^†^ (SE 3.06^†^) p: <0.001 F-B: -45 GP2 B: 203.94^†^ (SE 3.06^†^) F: 147.06^†^ (SE 3.78^†^) p: <0.001 F-B: -57.6 p: <0.001 GP1–GP2: 13* PPG excursion after dinner (NA) GP1 p: <0.001 | GP1 F-B: -0.89 p: <0.001 GP2 F-B: -1.04 p: <0.001 GP1–GP2: 0.15 (95% CI: -0.01 – 0.32) p: 0.067 A1c ≤ 7.0%, n (%) GP1 57 (24) p: 0.038 GP2 72 (32)
Insulin aspart 70/30 vs. insulin lispro 75/25
Hermansen, 2002 ^58^ | GP1: Insulin aspart 70/30 (fix) Start: 0.4 U/kg T: Breakfast D: 1 day GP2: Insulin lispro 75/25 (fix) Start: 0.4 U/kg T: Breakfast D: 1 day | | GP1 F: 13.9^†^ GP2 F: 14.5^†^ 2-hr PPG excursion GP1 F: 7.7 (2.7) p: NS vs. GP2 Ratio between treatments = 0.97 (95% CI: 0.85 – 1.11) p: NS
Niskanen, 2004 ^55^ | GP1: Insulin aspart 70/30 (v) Mean: 0.65 to 0.67 U/kg T: Breakfast, dinner D: 12 weeks GP2: Insulin lispro 75/25 (v) Mean: 0.67 to 0.71 U/kg T: Breakfast, dinner D: 12 weeks | GP1 F: 136.8 GP2 F: 135 GP1–GP2: 3.6 (95% CI: -0.54 – 10.8) p: 0.422 | 90-min PPG after breakfast (mg/dL) GP1 F: 171 GP2 F: 174.6 GP1–GP2: -3.6 (95% CI: -18 – 9) p: 0.524 | GP1 F: 8.7 GP2 F: 8.6 GP1–GP2: 0.1 (95% CI: -0.5 – 0.7) p: 0.824 | 90-min PPG after dinner (mg/dL) GP1 F: 172.8 GP2 F: 180 GP1–GP2: -7.2 (95% CI: -19.8 – 3.6) p: 0.186 | GP1 F: 8.15 GP2 F: 8.01 GP1–GP2: 0.14 (90% CI: 0.008 – 0.275) p: 0.082
Insulin aspart 70/30 vs. insulin aspart 70/30 + oral antidiabetic agents
Kvapil, 2006 ^51^ | GP1: Insulin aspart 70/30 (v) Start: 0.3 U/kg Mean: 0.51 U/kg T: Breakfast, dinner D: 16 weeks GP2: Insulin aspart 70/30 (v) Start: 0.2 U/kg Mean: 0.3 U/kg T: Breakfast, dinner D: 16 weeks Metformin (fix) Mean: 1660 mg daily Range: 500 – 3000 mg T: NR D: 16 weeks | GP1–GP2: 0.9 (SE 4.86) p: NS | 90-min PPG - after breakfast (mg/dL) GP1–GP2: 0 (SE 7.38) p: NS | GP1–GP2: 1.08 (SE 6.3) p: NS | 90-min PPG - after dinner (mg/dL) GP1–GP2: 3.06 (SE 6.66) p: NS | GP1–GP2: 0.39 (SE 0.15) p: <0.01
Raz, 2005 ^54^ | GP1: Insulin aspart 70/30 (v) Start: 0.3 U/kg Mean: 0.7 U/kg T: Breakfast, dinner D: 18 weeks GP2: Insulin aspart 70/30 (v) Start: 0.2 U/kg Mean: 0.5 U/kg T: Breakfast, dinner D: 18 weeks Pioglitazone (fix) Start: 30 mg Mean: 30 mg T: Breakfast D: 18 weeks | GP1 B: 178* F: 162^†^ F-B: -16 p: NS GP2 B: 184* F: 153 (45) F-B: -31 p: NS GP1–GP2: 15* | 90-min PPG - after breakfast (mg/dL) GP1 F: 196.2^†^ GP2 F: 178.2^†^ | | 90-min PPG - after dinner (mg/dL) GP1 F: 199.8^†^ GP2 F: 178.2^†^ 90-min PPG increment - after dinner (mg/dL) GP1–GP2: 4.86 (8.46) p: NS | GP1 B: 9.5 (1.3) F: 9 (1.3) F-B: -0.5 p: NS GP2 B: 9.6 (1.3) F: 8.4 (1.2) F-B: -1.2 p: NS GP1–GP2: 0.60 (0.22) p: 0.008
Ushakova, 2007 ^59^ | GP1: Insulin aspart 70/30 (v) Start: 0.3 – 0.5 U/kg Mean: 55.5 U T: bid for 2 weeks, then tid D: 16 weeks GP2: Insulin aspart 70/30 (v) Start: 0.3 – 0.5 U/kg Mean: 44.8 U T: Breakfast, dinner D: 16 weeks Metformin (v) Start: 500 mg qd or bid or 850 mg qd T: NR D: 14 weeks (started after 2 weeks) | GP1 B: 235.8 † F: 163.8 † F-B: 72 GP2 B: 234 † F: 160.2 † F-B: 74 GP1–GP2: -2* | | GP1 B: 261 † F: 156.6 † F-B: 105 GP2 B: 252 † F: 172.8 † F-B: 80 GP1–GP2: 25* | | GP1 F-B: -2.9 (1.5) GP2 F-B: -3 (1.6) GP1–GP2: 0.20 (95% CI: -0.108–0.514) A1c ≤ 7.0%, n (%) GP1 42 (42) p: 0.012 GP2 45 (45) p: 0.002 A1c after 3-month extension GP1 F: 7.2 (1.2) GP2 F: 7.2 (1.4) A1c ≤ 7.0% after 3-month extension, n (%) GP1 22 (51.2) GP2 23 (54.8) | Diabetes Health Profile GP1 F-B: p: <0.001 vs. baseline GP2 F-B: p; <0.001 vs. baseline
Insulin aspart 70/30 vs. rapid-acting insulin analogues with intermediate-acting human insulin
Hirao, 2008 ^61^ | GP1: Insulin aspart 70/30 (NR) T: BID D: 6 months GP2: Insulin aspart (NR) T: TID D: 6 months NPH insulin (unclear) T: Optional multiple daily injections D: 6 months | | | | | GP1 B: 10.2 (2.1) F: 7.6 (1.3) p: NS F-B: -2.5 GP2 B: 10.4 (2) F: 7.8 (1.8) F-B: -2.5 GP1–GP2: 0* A1c < 7.0%, n (%) GP1 (32.1) p: NS GP2 (32.8) A1c < 6.5%, n (%) GP1 (17.9) GP2 (16.4)
Insulin lispro 75/25 vs. long-acting insulin analogues
Cox, 2007 ^74^ | GP1: Insulin lispro 75/25 (v) T: Breakfast, dinner D: 12 weeks Metformin (NR) T: NR D: 12 weeks GP2: Insulin glargine (v) T: Bedtime D: 12 weeks Metformin (NR) T: NR D: 12 weeks | GP1 F: 8.5 (1.5) p: 0.056 GP2 F: 7.8 (2) | GP1 F: 11 (1.9) p: 0.642 GP2 F: 10.9 (2.1) GP1–GP2: 2.2 (0.7) p: NS | GP1 F: 176.4 (45) p: 0.076 GP2 F: 192.6 (54) | GP1 F: 198 (41.4) p: 0.001 GP2 F: 221.4 (52.2) GP1–GP2: 55.8 (23.4) p: NS | | BDI-II GP1 B: 8.2 (6) p: NS F: 5.5 (3.8) p: 0.115 F-B: -2* p: 0.018 GP2 B: 8.2 (6) F: 6.8 (5.9) F-B: -1* p: NS GP1–GP2: -1*
Jacober, 2006 ^64^ | GP1: Insulin lispro 50/50 (v) Mean: 0.353 IU/kg; 36.73 IU T: Breakfast, lunch D: 4 months Insulin lispro 75/25 (v) T: Dinner D: 4 months Existing OA agents (NR) T: NR D: 4 months GP2: Insulin glargine (v) Mean: 0.276 IU/kg; 27.98 IU T: Bedtime D: 4 months Existing OA agents (NR) T: NR D: 4 months | GP1 F: 130† (25†) p: NS GP2 F: 125† (15†) | GP1 F: 153.5 (35.6) p: 0.0034 GP2 F: 172.1 (35) | GP1 F: 123.1 (36.1) p: 0.0205 GP2 F: 139 (41.9) | GP1 F: 145.4 (38.2) p: 0.0066 GP2 F: 161.9 (42.3) | Overall results GP1 B: 8* F: 7.08 (0.11) p: 0.003 F-B: -1.01 (0.1) p: 0.0068 vs. GP2 GP2 B: 8* F: 7.34 (0.11) F-B: -0.75 (0.1) GP1–GP2: 0* 1^st^ per. results GP1 F: 6.97 (0.62†) GP2 F: 7.32 (0.93†) 2^nd^ per. results GP1 F: 7.22 (0.77†) GP2 F: 7.33 (0.92†) A1c ≤ 7%, n (%) GP1 26* (44) p: 0.1026 GP2 18* (31)
Malone, 2004 ^65^ | GP1: Insulin lispro 75/25 (v) Mean: 0.62 U/kg T: Breakfast, dinner D: 16 weeks Metformin (NR) Mean: 1945 mg Range: 1500 – 2550 mg T: NR D: 16 weeks GP2: Insulin glargine (v) Mean: 0.57 U/kg T: Bedtime D: 16 weeks Metformin (NR) Mean: 1997 mg Range: 1500 – 2550 mg T: NR D: 16 weeks | GP1 B: 150* F: 139.3 (36.6) p: <0.001 F-B: -11.3 (44.5) p: 0.001 vs. GP2 GP2 B: 153* F: 123.9 (34.9) F-B: -29 (47.4) GP1–GP2: 18* Met target FBG of 90 to 126 mg/dL, n (%) GP1 31 (45) p: 0.019 GP2 44 (65) | GP1 F: 156.4 (43.6) p: 0.012 GP2 F: 171.1 (44.9) Met target 2-hr PPG of 144 to 180 mg/dL, n (%) GP1 55 (80) p: 0.036 GP2 43 (63) | | GP1 F: 164.8 (42.5) p: <0.001 GP2 F: 193.8 (51) Met target 2-hr PPG of 144 to 180 mg/dL, n (%) GP1 50 (72) p: <0.001 GP2 29 (43) | GP1 B: 8.7 (1.3) F: 7.4 (1.1) p: 0.002 F-B: -1.32 (1.01) p: 0.003 vs. GP2; <0.001 vs. baseline GP2 B: 8.7 (1.3) F: 7.8 (1.1) F-B: -0.93 (0.89) p: <0.001 vs. baseline GP1–GP2: 0* A1c ≤ 7.0%, n (%) GP1 30 (42) p: <0.001 GP2 13 (18)
Malone, 2005 ^66^ | GP1: Insulin lispro 75/25 (v) Mean: 0.42 U/kg T: Breakfast, dinner D: 16 weeks Metformin (fix) Mean: 2128 mg Range: 1500 – 2550 mg T: NR D: 16 weeks GP2: Insulin glargine (v) Mean: 0.36 U/kg T: Bedtime D: 16 weeks Metformin (fix) Mean: 2146 mg Range: 1500 – 2550 mg T: NR D: 16 weeks | GP1 F: 142.2 (34.56) p: 0.007 GP2 F: 133.02 (35.28) Met target FBG of < 126 mg/dL (7.0 mmol/L), n (%) GP1 33* (34) p: 0.01 GP2 49* (51) | GP1 F: 169.92 (46.08) p: <0.001 GP2 F: 194.94 (49.32) Met target 2-hr PPG of < 180 mg/dL (10 mmol/L), n (%) GP1 64* (66) p: <0.001 GP2 41* (42) | | GP1 F: 172.62 (45) p: <0.001 GP2 F: 200.7 (45.36) Met target 2-hr PPG of < 180 mg/dL (10 mmol/L), n (%) GP1 62* (64) p: <0.001 GP2 39* (40) | GP1 B: 9* F: 7.54 (0.87) p: <0.001 F-B: -1 (0.85) p: <0.001 vs. GP2 GP2 B: 8* F: 8.14 (1.03) F-B: -0.42 (0.92) GP1–GP2: -1* A1c ≤ 7.0%, n (%) GP1 (30) p: 0.002 GP2 (12) A1c ≤ 6.5%, n (%) GP1 p: 0.1
Roach, 2006 ^63^ | GP1: Insulin lispro 75/25 (v) Mean: 23 U (morning) and 37 U (evening) Range: 0 – 72 U (morning); 11 – 88 U (evening) T: Breakfast, dinner D: 12 weeks OA agents (NR) Start: Current dose T: NR D: 12 weeks Metformin (v) Start: 500 mg qd T: NR D: 12 weeks GP2: Insulin glargine (v) Mean: 44 U Range: 14 – 100 U T: Breakfast D: 12 weeks OA agents (NR) Start: Current dose T: NR D: 12 weeks Metformin (v) Start: 500 mg qd T: NR D: 12 weeks | GP1 F: 104.4 (20.16) p: 0.649 GP2 F: 99 (38.52) | GP1 F: 187.2 (43.2) p: 0.551 GP2 F: 180 (37.8) | GP1 F: 91.8 (17.1) p: 0.141 GP2 F: 100.8 (25.38) | GP1 F: 144 (39.24) p: 0.005 GP2 F: 176.4 (36) | GP1 F: 6.9 (0.52) p: 0.035 GP2 F: 7.3 (0.81)
Sun, 2007 ^75^ | GP1: Insulin lispro 75/25 (NR) T: bid D: 18 months GP2: Insulin glargine (NR) T: qd D: 18 months | | | | | GP1 B: 8.6 (3.7) F: 8* F-B: -0.87 GP2 B: 8.6 (3.5) F: 8* F-B: -0.71 GP1–GP2: -0.16 p: <0.05
Insulin lispro 75/25 vs. premixed human insulins
Coscelli, 2003 ^67^ | GP1: Insulin lispro 75/25 (v) Mean: 38.1 Range: 12 – 72 T: Breakfast, dinner D: 12 days Diet/exercise D: 12 days GP2: NPH/regular 70/30 (v) Mean: 37.3 Range: 10 – 72 T: Breakfast, dinner D: 12 days Diet/exercise D: 12 days | | GP1 F: 157 (43.2) p: <0.05 GP2 F: 180 (43.2) 2-hr PPG excursion GP1 F: 2.4 (48.9) p: 0.08 GP2 F: 17.9 (41.43) | | 2-hr PPG excursion GP1 F: 12.2 (48.01) p: <0.05 GP2 F: 35.5 (36.92)
Hermansen, 2002 ^58^ | GP1: Insulin lispro 75/25 (fix) Start: 0.4 U/kg T: Breakfast D: 1 day GP2: NPH/regular 70/30 (fix) Start: 0.4 U/kg T: Breakfast D: 1 day | | GP1 F: 14.5^†^ GP2 F: 15.0^†^ 2-hr PPG excursion GP1 F: 8.5 (3.3) Ratio between treatments = 0.81 (95% CI: 0.72 – 0.94) p: <0.01 GP2 F: 9.4 (2.7) Ratio between treatments = ref
Herz, 2002 ^71^ | GP1: Insulin lispro 75/25 (v) Mean: 26.1 U T: Breakfast, dinner D: 4 weeks GP2: NPH/regular 70/30 (v) Mean: 26.2 U T: Breakfast, dinner D: 4 weeks | | GP1 F: 189 (SE 7.2) p: 0.016 GP2 F: 208.8 (SE 7.2)
Herz, 2003 ^12^ | GP1: Insulin lispro 75/25 (v) Mean: 31.6^¶^ (morning) and 26.8 U (evening) and 32.4 (morning) and 27.6 U (evening) T: Breakfast, dinner D: 4 weeks GP2: NPH/regular 70/30 (v) Mean: 32.3^¶^ (morning), 26.4 U (evening) and 33.3 (morning), 27.5 U (evening) T: Breakfast, dinner D: 4 weeks | GP1 F: 117^†^ GP2 F: 117^†^ | GP1 F: 223.2^†^ GP2 F: 259.2^†^ 2-hr PPG excursion GP1 F: 99 (SE 6.12) p: 0.002 GP2 F: 129.6 (SE 6.12) | GP1 F: 135^†^ GP2 F: 135^†^ | GP1 F: 181.8^†^ GP2 F: 201.6^†^ 2-hr PPG excursion GP1 F: 43.2 (SE 4.86) p: 0.018 GP2 F: 61.2 (SE 4.86)
Malone, 2000 ^44^ | GP1: Insulin lispro 75/25 (fix) Mean: 35.4 U (0.43 U/kg) T: Breakfast D: 2 days GP2: NPH/regular 70/30 (fix) Mean: 35.4 U (0.43 U/kg) T: Breakfast D: 2 days | | GP1 F: 221.4 (52.2) p: 0.066 GP2 F: 230.4 (54) 2-hr PPG excursion GP1 F: 60.3 (41.04) p: <0.001 GP2 F: 74.34 (40.68)
Mattoo, 2003 ^70^ | GP1: Insulin lispro 75/25 (NR) Mean: 20 U (morning), 32 U (evening) T: Breakfast, dinner D: 2 weeks GP2: NPH/regular 70/30 (NR) Mean: 20 U (morning), 32 U (evening) T: Breakfast, dinner D: 2 weeks | GP1 F: 160.2 (54) p: 0.393 GP2 F: 163.8 (57.6) | GP1 F: 208.8 (66.6) p: 0.104 GP2 F: 216 (64.8) 2-hr PPG excursion GP1 F: 48.6 (57.6) p: 0.397 GP2 F: 54 (55.8) | GP1 F: 127.8 (39.6) p: 0.034 GP2 F: 135 (46.8) | GP1 F: 189 (57.6) p: 0.001 GP2 F: 208.8 (61.2) 2-hr PPG excursion GP1 F: 61.2 (52.2) p: 0.007 GP2 F: 72 (57.6)
Roach, 1999 ^73^ | GP1: Insulin lispro 75/25 (v) Mean: 0.37 (morning), 0.28 U/kg (evening) T: Breakfast, dinner D: 13 weeks GP2: NPH/regular 70/30 (v) Mean: 0.36 (morning), 0.27 (evening) T: Breakfast, dinner D: 13 weeks | GP1 F: 154.8^†^ p: NS GP2 F: 157.5^†^ | GP1 F: 161.1 (39.06) p: 0.017 GP2 F: 180 (41.04) | GP1 F: 170.1^†^ p: NS GP2 F: 169.2^†^ | GP1 F: 167.04 (45.18) p: 0.014 GP2 F: 184.86 (49.68) | GP1 F: 7.8 p: 0.408 GP2 F: 8.1
Schwartz, 2006 ^62^ | GP1: Insulin lispro 75/25 (fix) Start: 2/3 of usual daily dose Mean: 44.1 U T: Breakfast D: 1 day GP2: NPH/regular 70/30 (fix) Start: 2/3 of usual daily dose Mean: 44.1 U T: Breakfast D: 1 day | | GP1 F: 198 (67.5) p: <0.05 GP2 F: 213 (47) p: <0.05
Sun, 2007 ^75^ | GP1: Insulin lispro 75/25 (NR) T: bid D: 18 months GP2: NPH/regular 70/30 (unclear) T: bid D: 18 months | | | | | GP1 B: 8.6 (3.7) F: 8* F-B: -0.87 GP2 B: 8.4 (3.9) F: 7* F-B: -0.75 GP1–GP2: -0.16 p: <0.05
Insulin lispro 75/25 vs. oral antidiabetic agents
Herz, 2002 ^72^ | GP1: Insulin lispro 75/25 (v) Start: 0.3 – 0.5 U/kg Mean: 0.46 U/kg T: Breakfast, dinner D: 16 weeks GP2: Glyburide (fix) Start: 15 mg/day T: Breakfast, dinner D: 16 weeks | GP1 B: 199.44 (SE 6.3) p: 0.139 vs. GP2 F: 147.06 (SE 4.14) p: <0.001 vs. GP2 F-B: -52.74 (SE 5.94) p: <0.001 vs. GP2 GP2 B: 187.74 (SE 4.68) F: 176.76 (SE 5.22) F-B: -8.82 (SE 5.04) GP1–GP2: -44* | GP1 B: 255.6 (SE 9) p: 0.621 vs. GP2 F: 174.96 (SE 6.66) p: <0.001 vs. GP2 F-B: -80.82 (SE 9) p: <0.001 vs. GP2 GP2 B: 261.18 (SE 7.02) F: 236.52 (SE 7.02) F-B: -22.5 (SE 7.02) GP1–GP2: -59* | GP1 B: 222.48 (SE 8.82) p: 0.216 vs. GP2 F: 175.68 (SE 5.94) p: 0.120 vs. GP2 F-B: -47.34 (SE 7.92) p: 0.002 vs. GP2 GP2 B: 207.18 (SE 8.64) F: 189.9 (SE 7.02) F-B: -14.76 (SE 6.48) GP1–GP2: -32* | GP1 B: 241.2 (SE 9.54) p: 0.711 vs. GP2 F: 181.98 (SE 6.84) p: <0.001 vs. GP2 F-B: -58.86 (SE 8.82) p: <0.001 vs. GP2 GP2 B: 245.88 (SE 8.28) F: 227.52 (SE 7.56) F-B: -14.94 (SE 7.56) GP1–GP2: -44* | GP1 B: 9.82 (1.51) F: 8.64 (SE 0.17) p: <0.001 vs. GP2 F-B: -1.14 (SE 0.18) p: 0.001 vs. GP2 GP2 B: 9.9 (1.3) F: 9.45 (SE 0.16) F-B: -0.36 (SE 0.15) GP1–GP2: -1* | Treatment acceptance questionnaire (satisfaction rated from 1 (very low) to 5 (very high) GP1 F: 4.35 p: 0.014 vs. GP2 GP2 F: 3.98 Willingness to continue treatment GP1 (92) p: 0.041 GP2 (79)
Malone, 2003 ^68^ | GP1: Insulin lispro 75/25 (v) Mean: 0.19 (morning), 0.14 U/kg (evening) T: Breakfast, dinner D: 16 weeks Metformin (v) Mean: 1813 mg/day Range: 1500 – 2550 mg/day T: 2 to 3 times/day D: 16 weeks GP2: Metformin (v) Mean: 1968 mg/day Range: 1500 – 2550 mg/day T: 2 to 3 times/day D: 16 weeks Glibenclamide (v) Mean: 14.2 mg/day T: NR D: 16 weeks | GP1 B: 239.4 (68.22) F: 156.06 Median (60.48) F-B: -83* GP2 B: 233.82 (68.04) F: 169.74 Median (61.02) F-B: -64* GP1–GP2: -19* p: 0.173 | GP1 B: 252 (+/- SE 246.6 – 257.4) F: 147.6 (+/- SE 145.8 – 151.2) F-B: -104* GP2 B: 259.2 (+/- SE 252 – 273.6) F: 190.8 (+/- SE 185.4 – 199.8) F-B: -68* GP1–GP2: -36* 2-hr PPG (time not specified) (mg/dL) GP1 F-B: -124.02 (84.42) p: 0.007 GP2 F-B: -68.94 (84.96) GP1–GP2: -55* 2-hr PPG excursion (time not specified) (mg/dL) GP1 F-B: -40.86 (69.66) p: 0.009 GP2 F-B: -3.96 (35.82) GP1–GP2: -37* | | | Test meal patients GP1 B: 9.64 (1.6) F: 7.29 (1.12) p: 0.192 vs. GP2 F-B: -3* GP2 B: 9.78 (1.83) F: 7.53 (1.27) F-B: -2* GP1–GP2: -1* All patients GP1 B: 9.17 (1.5) F: 7.29 (1.00) p: 0.661 vs. GP2 F-B: -1.87 (1.35) p: <0.001 GP2 B: 9.27 (1.55) F: 7.33 (1.14) F-B: -1.98 (1.28) p: <0.001 GP1–GP2: 0* A1c < 7.0%, (%) GP1 (40) GP2 (41) A1c < 6.5%, (%) GP1 (18) GP2 (19)
Tirgoviste, 2003 ^43^ | GP1: Insulin lispro 75/25 (v) Start: 0.3 – 0.5 U/kg T: Breakfast, dinner D: 16 weeks GP2: Glibenclamide (v) Start: 15 mg T: Breakfast, dinner D: 16 weeks | GP1 B: 221* F: 171 F-B: -50.4 p: <0.01 GP2 B: 209* F: 189 F-B: -19.8 GP1–GP2: -30* | GP1 B: 279* F: 187.2 F-B: -91.8 p: <0.001 GP2 B: 265* F: 234 F-B: -30.6 GP1–GP2: -61* | GP1 B: 233* F: 192.6 F-B: -39.6 p: <0.05 GP2 B: 219* F: 205.2 F-B: -14.4 GP1–GP2: -26* | GP1 B: 272* F: 192.6 F-B: -79.2 p: <0.001 GP2 B: 261* F: 234 F-B: -27 GP1–GP2: -52* | GP1 B: 9* F: 8.5 (1.3) p: 0.001 F-B: -1.4 p: 0.004 GP2 B: 10* F: 9.4 (1.8) F-B: -0.7 GP1–GP2: 0*
Insulin lispro 75/25 vs. insulin lispro 50/50
Roach, 2003 ^69^ | GP1: Insulin lispro 75/25 (v) Mean: 31.3 (morning), 27.6 U (evening) T: Breakfast, dinner D: 8 weeks GP2: Insulin lispro 50/50 (v) Mean: 31.5 U T: Breakfast D: 8 weeks Insulin lispro 75/25 (v) Mean: 27.9 U T: Dinner D: 8 weeks | GP1 F: 160.2 (SE 5.4) p: 0.129 GP2 F: 171 (SE 5.4) | GP1 F: 223.2 (SE 5.94) p: 0.0012 GP2 F: 196.2 (SE 5.04) 2-hr PPG excursion GP1 F: 63 (SE 5.04) p: <0.001 GP2 F: 25.2 (SE 5.04) | | | GP1 F: 8.14 (SE 1.07) p: 0.919 GP2 F: 8.14 (SE 1.14)
Schwartz, 2006 ^62^ | GP1: Insulin lispro 75/25 (fix) Start: 2/3 of usual daily dose Mean: 44.1 U T: Breakfast D: 1 day GP2: Insulin lispro 50/50 (fix) Start: 2/3 of usual daily dose Mean: 43.8 U T: Breakfast D: 1 day | | GP1 F: 198 (67.5) p: <0.05 GP2 F: 159 (52.3) p: <0.05
Insulin lispro 50/50 vs. long-acting insulin analogues
Kazda, 2006 ^76^ | GP1: Insulin lispro 50/50 (v) Start: 0.30 IU/kg Mean: 0.59 IU/kg T: Breakfast, lunch, dinner D: 24 weeks GP2: Insulin glargine (v) Start: 0.16 IU/kg Mean: 0.43 IU/kg T: Bedtime D: 24 weeks | GP1 B: 167.4 (37.8) F: 151* F-B: -16.2 (32.4) p: <0.001 vs. GP2 GP2 B: 172.8 (43.2) F: 126* F-B: -46.8 (43.2) GP1–GP2: 31* | GP1 B: 214.2 (50.4) F: 164* F-B: -50.4 (52.2) p: 0.43 vs. GP2 GP2 B: 219.6 (55.8) F: 173* F-B: -46.8 (59.4) GP1–GP2: -3* 2-hr PPG excursion GP1 B: 48.6 (32.4) F: 17* F-B: -32.4 (43.2) p: <0.001 vs. GP2 GP2 B: 45 (39.6) F: 43* F-B: -1.8 (39.6) GP1–GP2: -30* | GP1 B: 166.5^†^ (SE 5.4^†^) F: 144^†^ (SE 7.56^†^) F-B: -22.5* GP2 B: 174.06^†^ (SE 5.4^†^) F: 159.12^†^ (SE 7.56^†^) F-B: -14.94* GP1–GP2: -7.56* | GP1 B: 198^†^ (SE 5.94^†^) F: 149.94^†^ (SE 5.94^†^) F-B: -48.06* GP2 B: 208.44^†^ (SE 7.38^†^) F: 207^†^ (SE 7.38^†^) F-B: -1.44* GP1–GP2: -46.62* | GP1 B: 8.1 (1.2) F: 7* F-B: -1.2 (1.1) p: <0.001 vs. GP2 GP2 B: 8.1 (1.3) F: 8* F-B: -0.3 (1.1) GP1–GP2: -1* A1c < 7%, n (%) GP1 29* (59.3) GP2 12* (24.5) | Willing to continue current treatment at end of study GP1 F: 83.3% GP2 F: 77.4% Overall satisfaction based on 5-point Likert scale (non validated): proportion with high or very high treatment satisfaction GP1 B: 18.5% F: 63% GP2 B: 26.4% F: 50.9%
Robbins, 2007 ^79^ | GP1: Insulin lispro 50/50 (v) Mean: 0.7 U/kg T: Breakfast, lunch, dinner D: 24 weeks Metformin (fix) Mean: 1641 mg T: bid D: 24 weeks GP2: Insulin glargine (v) Mean: 0.6 U/kg T: Bedtime D: 24 weeks Metformin (fix) Mean: 1636 mg T: bid D: 24 weeks | GP1 B: 152† (95% CI: 146† – 158†) F: 146 (33) p: < 0.001 vs GP2 F-B: 6 GP2 B: 148† (95% CI: 143† – 153†) F: 118 (29) F-B: 30 GP1–GP2: -24* FBG < 120 mg/dL (6.7 mmol/L), n (%) GP1 37 (24.2) p: < 0.001 vs GP2 GP2 91 (61.1) | GP1 B: 183† (95% CI: 177† – 191†) F: 156 (39) p: 0.03 vs. GP2 F-B: 27 GP2 B: 180† (95% CI: 174† – 186†) F: 166 (46) F-B: 14 GP1–GP2: 13* | GP1 B: 168† (95% CI: 161† – 174†) F: 149 (36) p: 0.04 vs GP2 F-B: 19 GP2 B: 170† (95% CI: 163† – 177†) F: 160 (50) F-B: 10 GP1–GP2: 9* | GP1 B: 183† (95% CI: 174† – 190†) F: 157 (40) p: <0.001 vs GP2 F-B: 26 GP2 B: 183† (95% CI: 176† – 191†) F: 193 (57) F-B: -10 GP1–GP2: 36* 2-hr PPG excursion GP1 F-B: -8 (50) p: < 0.001 vs. GP2 GP2 F-B: 23 (54) GP1–GP2: -31* | GP1 B: 7.8 (0.9) p: F: 7.1 (0.9) p: <0.001 vs. GP2 F-B: -0.7 (0.9) p: <0.001 vs GP2 GP2 B: 7.8 (1) F: 7.5 (1) F-B: -0.4 (0.9) GP1–GP2: -1* A1c ≤ 7.0%, n (%) GP1 85 (56.3) p: 0.005 vs GP2 GP2 58 (39.7) A1c ≤ 6.5%, n (%) GP1 46 (30.5) p: 0.001 vs GP2 GP2 21 (14.4)
Insulin lispro 50/50 vs. rapid-acting insulin analogues
Kazda, 2006 ^76^ | GP1: Insulin lispro 50/50 (v) Start: 0.30 IU/kg mean Mean: 0.59 IU/kg T: Breakfast, lunch, dinner D: 24 weeks GP2: Insulin lispro (v) Start: 0.25 IU/kg mean Mean: 0.50 IU/kg T: Breakfast, lunch, dinner D: 24 weeks | GP1 B: 167.4 (37.8) F: 151* F-B: -16.2 (32.4) GP2 B: 176.4 (50.4) F: 160* F-B: -16.2 (39.6) GP1–GP2: 0* | GP1 B: 214.2 (50.4) F: 164* F-B: -50.4 (52.2) GP2 B: 205.2 (61.2) F: 151* F-B: -54 (63) GP1–GP2: 4* 2-hr PPG excursion GP1 B: 48.6 (32.4) F: 17* F-B: -32.4 (43.2) GP2 B: 28.8 (43.2) F: -9* F-B: -37.8 (52.2) GP1–GP2: 6* | GP1 B: 166.5^†^ (SE 5.4^†^) F: 144^†^ (SE 7.56^†^) F-B: -22.5* GP2 B: 169.38^†^ (SE 5.4^†^) F: 145.44^†^ (SE 7.56^†^) F-B: -23.94* GP1–GP2: -1.44 | GP1 B: 198^†^ (SE 5.94^†^) F: 149.94^†^ (SE 5.94^†^) F-B: -48.06* GP2 B: 205.38^†^ (SE 4.5^†^) F: 141.12^†^ (SE 4.5^†^) F-B: -64.26* GP1–GP2: 16.2 | GP1 B: 8.1 (1.2) F: 7* F-B: -1.2 (1.1) GP2 B: 8.2 (1.2) F: 7* F-B: -1.1 (1.1) GP1–GP2: 0* A1c < 7%, n (%) GP1 29* (59.3) GP2 20* (40.4) | Willing to continue current treatment at end of study GP1 F: 83.3% GP2 F: 88.5% Overall satisfaction based on 5-point Likert scale (nonvalidated): proportion with high or very high treatment satisfaction GP1 B: 18.5% F: 63% GP2 B: 21.2% F: 65.4%
Insulin lispro 50/50 vs. rapid-acting with long-acting insulin analogues
Rosenstock, 2008 ^80^ | GP1: Insulin lispro 50/50 (v) Start: Insulin glargine dose at entry (52.5 U) Mean: 123 U T: Breakfast, lunch, dinner D: 24 weeks Insulin lispro 75/25 (v) Start: Allowed to switch evening dose to insulin lispro 75/25 T: Dinner D: Unclear GP2: Insulin glargine (v) Start: 50% of insulin glargine dose at entry (54.9 U) Mean: 70 U T: Bedtime D: 24 weeks Insulin lispro (v) Start: 50% of insulin glargine dose at entry divided in 3 equal doses (54.9 U) Mean: 76 U T: Breakfast, Lunch, dinner D: 24 weeks | GP1 F: 159 (55) p: 0.013 GP2 F: 147 (43) | GP1 F: 174 (56) p: 0.002 GP2 F: 155 (53) | GP1 B: 208† F: 144† p: > 0.05 vs. GP2 F-B: 64 GP2 B: 212† F: 150† F-B: 62 GP1–GP2: 2* | | GP1 B: 8.8 (1) p: 0.598 F: 6.95 F-B: -1.87 p: 0.021 GP2 B: 8.9 (1.1) F: 6.78 F-B: -2.09 GP1–GP2: 0.22 (90% CI: 0.07 – 0.38) A1c < 7.5%, n (%) GP1 (82) GP2 (83) A1c < 7.0%, n (%) GP1 81 (54) p: < 0.05 GP2 101 (69) A1c < 6.5%, n (%) GP1 53 (35) p: < 0.05 GP2 74 (50) A1c < 6.0%, n (%) GP1 (12.5†) GP2 (12.5†)
Insulin lispro 50/50 vs. premixed human insulins
Roach, 1999 ^10^ | GP1: Insulin lispro 50/50 (v) Mean: 0.31 U/kg T: Breakfast D: 3 months Insulin lispro 75/25 (v) Mean: 0.26 U/kg T: Dinner D: 3 months GP2: NPH/regular 50/50 (v) Mean: 0.32 U/kg T: Breakfast D: 3 months NPH/regular 70/30 (v) Mean: 0.26 U/kg T: Dinner D: 3 months | GP1 F: 160.38 p: NS GP2 F: 162.18 | GP1 F: 150.3 p: <0.001 GP2 F: 182.16 2-hr PPG excursion GP1 F: -10.44 p: <0.001 GP2 F: 21.42 | GP1 F: 171 p: 0.01 GP2 F: 166.68 | GP1 F: 179.28 p: NS GP2 F: 188.64 2-hr PPG excursion GP1 F: 6.48 p: NS GP2 F: 21.96 | GP1 F: 7.73 p: 0.371 GP2 F: 7.66
Schernthaner, 2004 ^77^ | GP1: Insulin lispro 50/50 (v) Mean: 64.6 IU T: Breakfast, lunch, dinner D: 12 weeks Diet/exercise D: 12 weeks GP2: NPH/regular 70/30 (v) Mean: 61.8 IU T: Breakfast, dinner D: 12 weeks Diet/exercise D: 12 weeks | GP1 B: 155* F: 177.7 (SE 9.6) F-B: 23.3 (SE 7.8) p: 0.005 vs. baseline GP2 B: 154* F: 147.4 (SE 6.3) F-B: -7 (SE 8) p: 0.387 vs. baseline GP1–GP2: 30* p: <0.001 | GP1 B: 198* F: 189.8 (SE 10.2) F-B: -8.3 (SE 11) p: 0.456 vs. baseline GP2 B: 198* F: 191.3 (SE 10.5) F-B: -6.9 (SE 7.8) p: 0.384 vs. baseline GP1–GP2: -1* p: 0.836 2-hr PPG increment GP1 F-B: -32.3 (SE 9.7) p: 0.002 vs. baseline GP2 F-B: 1 (SE 7.3) p: NS vs. baseline GP1–GP2: -33* p: <0.001 | GP1 B: 192* F: 174.8 (SE 7.3) F-B: -17.3 (SE 9.6) p: 0.079 vs. baseline GP2 B: 192* F: 187.8 (SE 9.5) F-B: -4.3 (SE 8.5) p: 0.614 vs. baseline GP1–GP2: -13* p: 0.064 | GP1 B: 209* F: 166.3 (SE 7.2) F-B: -42.8 (SE 10) p: <0.001 vs. baseline GP2 B: 209* F: 198.2 (SE 10) F-B: -10.9 (SE 9.7) p: 0.268 vs. baseline GP1–GP2: -32* p: <0.001 2-hr PPG increment GP1 F-B: -21 (SE 9.7) p: 0.037 vs. baseline GP2 F-B: -4.6 (SE 8.2) p: NS vs. baseline GP1–GP2: -16* p: 0.055 | GP1 B: 9* F: 7.6 (SE 1.1) F-B: -0.8 (SE 1.1) p: <0.001 vs. baseline GP2 B: 8* F: 8.1 (SE 1.4) F-B: -0.3 (SE 1.1) p: 0.034 vs. baseline GP1–GP2: -1* p: 0.021
Schwartz, 2006 ^62^ | GP1: Insulin lispro 50/50 (fix) Start: 2/3 of usual daily dose Mean: 43.8 U T: Breakfast D: 1 day GP2: NPH/regular 70/30 (fix) Start: 2/3 of usual daily dose Mean: 44.1 U T: Breakfast D: 1 day | | GP1 F: 159 (52.3) p: <0.05 GP2 F: 213 (47) p: <0.05
Yamada, 2007 ^78^ | GP1: Insulin lispro 50/50 (v) Start: Current dose Mean: 0.37 (start), 0.38 U/kg (end) T: bid D: 4 months GP2: NPH/regular 70/30 (v) Start: current dose Mean: 0.34 (start), 0.37 U/kg (end) T: bid D: 4 months NPH/regular 50/50 (v) Start: current dose Mean: 0.34 (start), 0.37 U/kg (end) T: bid D: 4 months | GP1 B: 130.3 (50.7) F: 158.5 (63.4) F-B: 28* p: NS vs. baseline GP2 B: 141.8 (51.9) F: 136.4 (47.2) F-B: -6* p: NS vs. baseline GP1–GP2: 34* p: NS | | | | GP1 B: 7.59 (0.44) F: 7.24 (0.49) F-B: -1* p: <0.05 vs. baseline GP2 B: 7.33 (0.58) F: 7.29 (0.65) F-B: 0* p: NS vs. baseline GP1–GP2: -1* p: <0.05

# Numbers are mean (SD) unless otherwise specified.

* Number has been imputed.

† Number has been estimated from a figure.

‖ Among those who were not using thiazolidinediones.

‡ One-hundred and four (36%) of the 291 participants of this trial are patients with type 1 diabetes. The remaining population has type 2 diabetes and is the same study population as Boehm 2004. ^45^ Only data for the Boehm 2004 study is presented because it has the longest followup.

¶ Dosing during the outpatient phase.

§ Dosing during the inpatient phase.

μg = microgram; A1c = Hemoglobin A1c; B = baseline; BDI-II = Beck Depression Inventory - Revised; B-F = mean difference from baseline; bid = twice daily; CI = confidence interval; D = duration; dl = deciliter; DM = diabetes mellitus; EQ-5D = EuroQol-5D; F = final; FBG = fasting blood glucose; fix = fixed dosing; GP = group; GP1–GP2 = mean difference between the difference from baseline; hr = hour; IU = international unit; kg = kilogram; l = liter; mg = milligrams; min = minutes; ml = milliliter; mmol = millimole; NA = not applicable; NPH = neutral protamine Hagedorn; NR = not reported; NS = not significant; OA = oral antidiabetic; p = p-value; per = period; PPG = postprandial glucose; qd = once daily; ref = reference group; SE = standard error; SEM = standard error of the mean; T = time of day when insulin taken; tid = thrice daily; U = units; v = dose varied; WHO-DTSQ = World Health Organization-Diabetes Treatment Satisfaction Questionnaire

Table 5 Comparative safety of premixed insulin analogues and other diabetes treatments on hypoglycemia

Author, year | Intervention | Mild hypoglycemia, n (%) | Moderate hypoglycemia, n (%) | Serious hypoglycemia, n (%) | Daytime hypoglycemia, n (%) | Nighttime hypoglycemia, n (%) | Other hypoglycemia, n (%)
Insulin aspart 70/30 vs. long-acting insulin analogues
Holman, 2007 ^32^ | GP1: Insulin aspart 70/30 (v) Start: 16 median IU/day Range: 10 – 26 IU/day T: bid D: 1 year Usual care D: 1 year GP2: Insulin detemir (v) Start: 16 median IU/day Range: 10 – 24 IU/day T: Bedtime, twice if required D: 1 year Usual care D: 1 year | | Grade 2: symptoms and BG < 56 mg/dL GP1 Median number of events/patient-year: 3.9 (IQR 1.0 – 9.0) p: 0.01 GP2 Median number of events/patient-year: 0 (IQR 0 – 2.0) | Grade 3: third party assistance required GP1 11 (4.7) p: overall 0.20 Median number of events/patient-year: 0 p: overall 0.10 GP2 4 (1.7) Median number of events/patient-year: 0 | | | Grades 1, 2, or 3 GP1 216 (91.9) p: overall < 0.001 GP2 173 (73.9)
Kann, 2006 ^50^ | GP1: Insulin aspart 70/30 (v) Start: 0.1 U/kg bid Mean: 0.4 U/kg T: Breakfast, dinner D: 26 weeks Metformin (v) Start: 500 mg bid or current dose T: Breakfast, dinner D: 26 weeks GP2: Insulin glargine (v) Start: 0.2 U/kg qd Mean: 0.3 U/kg T: preferred time (constant through study) D: Glimepiride (v) Start: 1 mg daily or current dose T: Breakfast D: 26 weeks | Treat self, PG < 55.8 mg/dL (3.1 mmol/L) GP1 26* (20.3) p: 0.0124 GP2 11* (9) | | Unable to treat self GP1 1 (1*) GP2 1 (1*) Hypoglycemic coma GP1 2 (1.6) GP2 0 (0) | % mild episodes that occurred in daytime GP1 number (%) of events: 61 (77) GP2 number (%) of events: 25 (71) | | Symptoms only GP1 14* (10.6) GP2 9* (6.6)
Raskin, 2005 ^39^ ^40^ | GP1: Insulin aspart 70/30 (v) Start: 10 or 12 U/day T: Breakfast, dinner D: Unclear Metformin (v) Range: 1500 – 2550 mg/day T: NR D: Unclear GP2: Insulin glargine (v) Start: 10–12 U/day T: Bedtime D: Unclear Metformin (v) Range: 1500 – 2550 mg/day T: NR D: Unclear | PG < 56 mg/dL with or without symptoms, self-treated GP1 46.4* (43) event rate: 3.4/patient-year p: < 0.05 GP2 18.2* (16) event rate: 0.7/patient-year GP1^‖^ 33 (41.8*) number of events: 121 GP2^‖^ 11 (14.1*) number of events: 23 | | Neurological symptoms, required assistance, PG < 56 mg/dL or reversal with treatment GP1 0 (0) GP2 1 (0.88) GP1 0 (0) GP2 0 (0) | | Mild or serious between 11pm and 8am GP1 19.8* (25) p: 0.021 GP2 7.8* (10) | Symptoms but PG ≥ 56 mg/dL GP1 event rate: 9.8/patient-year p: < 0.05 GP2 event rate: 4.7/patient-year Reported hypoglycemic event GP1^‖^ 54 (68) p: 0.0013 GP2^‖^ 33 (42)
Tamemoto, 2007 ^47^ | GP1: Insulin aspart 70/30 (v) Start: 10 – 16 U/day Mean: 26.7 U T: Breakfast, dinner D: 6 months Continued OA agents (NR) T: NR D: 6 months GP2: Insulin glargine (v) Start: 6 – 8 U/day T: NR D: 6 months Continued OA agents (NR) T: NR D: 6 months | | | | | | From self-monitored blood glucose data, < 70 mg/dL GP1 2 (50*) number of events: 11 GP2 4 (57*) number of events: 43 Self-reported events GP1 4 (80*) GP2 6 (55*)
Insulin aspart 70/30 vs. rapid-acting insulin analogues
Holman, 2007 ^32^ | GP1: Insulin aspart 70/30 (v) Start: 16 median IU/day Range: 10 – 26 IU/day T: bid D: 1 year Usual care D: 1 year GP2: Insulin aspart (v) Start: 18 median IU/day Range: 9 – 24 IU/day T: Breakfast, lunch, dinner, D: 1 year Usual care D: 1 year | | Grade 2: symptoms and BG < 56 mg/dL GP1 Median number of events/patient-year: 3.9 (IQR 1.0–9.0) p: 0.002 GP2 Median number of events/patient-year: 8.0 (IQR 2.9–17.7) | Grade 3: third party assistance required GP1 11 (4.7) p: overall 0.20 Median number of events/patient-year: 0 p: overall 0.10 GP2 16 (6.7) Median number of events/patient-year: 0 | | | Grades 1, 2, or 3 GP1 216 (91.9) p: 0.08 GP2 229 (96.2)
Insulin aspart 70/30 vs. rapid-acting with long-acting insulin analogues
Joshi, 2005 ^52^ | GP1: Insulin aspart 70/30 (v) Mean: 40.19 U/day T: bid D: 12 weeks GP2: Insulin aspart (v) Mean: 28.26 U/day at 12 weeks T: tid D: 12 weeks Insulin glargine (v) Mean: 24.52 U/day T: Bedtime D: 12 weeks | BS < 50 mg/dL but self managed GP1 19* (16.7) p: < 0.05 vs GP2 GP2 18* (58.06) | | Requiring 3rd party assistance GP1 0 (0) GP2 0 (0)
Insulin aspart 70/30 vs. premixed human insulin
Abrahamian, 2005 ^53^ | GP1: Insulin aspart 70/30 (v) Mean: 0.49 (start), 0.61 U/kg (end) T: Breakfast, lunch, dinner D: 24 weeks GP2: NPH/regular 70/30 (v) Mean: 0.46 (start), 0.59 U/kg (end) T: Breakfast, dinner D: 24 weeks | Not defined GP1 number of events: 130 GP2 number of events: 185 | | Major GP1 number of events: 2 GP2 number of events: 0 | | Not defined p: NS
Boehm, 2004 ^45^ Boehm, 2002 ^9^ ‡ | GP1: Insulin aspart 70/30 (v) Start: 0.57 U/kg T: Breakfast, dinner D: 24 months GP2: NPH/regular 70/30 (v) Start: 0.57 U/Kg T: Breakfast, dinner D: 24 months | GP1 35 (63) number of events: 398 p: 1 GP2 41 (63) number of events: 555 | | Major hypoglycemia GP1 3 (5) number of events: 3 p: 0.14 GP2 9 (14) number of events: 19
Hermansen, 2002 ^58^ | GP1: Insulin aspart 70/30 (fix) Start: 0.4 U/kg T: Breakfast D: 1 day GP2: NPH/regular 70/30 (fix) Start: 0.4 U/kg T: Breakfast D: 1 day | | | Requiring third-party assistance GP1 number of events: 2 GP2 number of events: 2 | | | Overall hypoglycemia rates (not specified) GP1 number of events: 23 GP2 number of events: 11
Kilo, 2003 ^15^ | GP1: Insulin aspart 70/30 (v) Start: 0.16 U/day Mean: 26 U/day T: Dinner D: 12 weeks Metformin (fix) Mean: about 2200 mg Range: 500 – 2550 mg T: 1–3 times/day D: 4 weeks run-in, then 12 weeks GP2: NPH/regular 70/30 (v) Start: 0.16 U/day Mean: 29 U/day T: Dinner D: 12 weeks Metformin (fix) Mean: about 2200 mg Range: 500 – 2550 mg T: 1–3 times/day D: 4 weeks run-in, then 12 weeks | Symptoms with BS < 50 mg/dL but not requiring third party assistance GP1 11 (24) GP2 9 (19) | | BS < 50 mg/dL with severe CNS symptoms and required third party assistance GP1 0 (0*) GP2 0 (0*) | | Between midnight and 6 am GP1 7 (15) GP2 11 (23) | Symptoms only GP1 13 (28) GP2 11 (23) Any (reported symptoms or BS < 50 mg/dL) GP1 20 (43) p: overall 0.245 GP2 15 (32)
McNally, 2007 ^48^ | GP1: Insulin aspart 70/30 (v) Start: 100 U/mL Mean: 68.8 U Range: 6 – 238.7 U T: Breakfast, dinner D: 16 weeks GP2: NPH/regular 70/30 (v) Start: 100 U/mL Mean: 66.6 U Range: 11.3 – 240 U T: Breakfast, dinner D: 16 weeks | Self reported minor hypoglycemia (patient able to self-treat and blood glucose < 50.4 mg/dL (2.8 mmol/L)) GP1 63* (90) GP2 65* (84) | | Patients unable to self-treat GP1 2 (3*) number of events: 2 GP2 5 (6*) number of events: 7 | < 45 mg/dL (2.5 mmol/L) recorded by CGMS between 0600 – 0000 h GP1 29* (41) p: 0.1 GP2 31* (41) < 63 mg/dL (3.5 mmol/L) recorded by CGMS between 0600 – 0000 h GP1 51* (73) p: 0.6 event rate: 2.58/patient-week p: 0.32 GP2 52* (70) event rate: 2.36/patient-week Daytime self-reported rates p: NS | < 45 mg/dL (2.5 mmol/L) recorded by CGMS between 0000 – 0600 h GP1 18* (25) p: 0.039 GP2 28* (37) < 63 mg/dL (3.5 mmol/L) recorded by CGMS between 0000 – 0600 h GP1 36* (51) p: 0.015 event rate: 1.18/patient-week p: 0.011 GP2 50* (66) event rate: 1.62/patient-week Nighttime self-reported rates GP1 event rate: 1.5/patient-year (SD = 4.54) p: 0.002 GP2 event rate: 3.8/patient-year (SD = 8) | < 45 mg/dL (2.5 mmol/L) recorded by CGMS at any time GP1 32* (46) p: 0.28 GP2 40* (54) < 63 mg/dL (3.5 mmol/L) recorded by CGMS at any time GP1 57* (82) p: 1 event rate: 3.76/patient-week p: 0.62 GP2 62* (82) event rate: 3.93/patient-week Total self-reported rates p: NS
McSorley, 2002 ^11^ | GP1: Insulin aspart 70/30 (NR) T: Breakfast, dinner D: 2 weeks GP2: NPH/regular 70/30 (NR) T: Breakfast, dinner D: 2 weeks | | | Required third party assistance or injection of glucose or glucagon GP1 0 (0*) GP2 0 (0*) | | | Experienced symptoms, but did not require assistance GP1 4 (31*) number of events: 7 GP2 3 (23*) number of events: 5
Insulin aspart 70/30 vs. intermediate-acting human insulins
Christiansen, 2003 ^13^ | GP1: Insulin aspart 70/30 (v) Start: insulin naive = 8 – 16 U/day; taking NPH prior to trial = started at pretrial dose T: Breakfast, dinner D: 16 weeks GP2: NPH insulin (v) Start: insulin naive = 8 – 16 U/day; taking NPH prior to trial = started at pretrial dose T: Breakfast, dinner D: 16 weeks | Not requiring third party assistance or glucagon injection GP1 77 (38*) number of events: 341 RR = 1.21 (95% CI: 0.77 – 1.9) p: 0.4 GP2 68 (34*) number of events: 285 | | Requiring third party assistance or use of glucagon GP1 NR (<2) GP2 NR (<2) | | Minor (not requiring assistance) and nocturnal (midnight to 6 am) GP1 22* (10.9) p: NS GP2 22* (11.4) p: NS
Kilo, 2003 ^15^ | GP1: Insulin aspart 70/30 (v) Start: 0.16 U/day Mean: 26 U/day T: Dinner D: 12 weeks Metformin (fix) Mean: about 2200 mg Range: 500 – 2550 mg T: 1–3 times/day D: 4 weeks run-in, then 12 weeks GP2: NPH insulin (v) Start: 0.16 U/day Mean: 28 U/day T: Bedtime D: 12 weeks Metformin (fix) Mean: about 2200 mg Range: 500 mg – 2550 mg T: 1–3 times/day D: 4 weeks run-in, then 12 weeks | Symptoms with BS < 50 mg/dL but not requiring third party assistance GP1 11 (24) GP2 6 (13) | | BS < 50 mg/dL with severe CNS symptoms and required third party assistance GP1 0 (0*) GP2 0 (0*) | | Between midnight and 6 am GP1 7 (15) GP2 11 (23) | Symptoms only GP1 13 (28) GP2 10 (21) Any (reported symptoms or BS < 50 mg/dL) GP1 20 (43) p: overall 0.245 GP2 13 (28)
Insulin aspart 70/30 vs. oral antidiabetic agents
Bebakar, 2007 ^46^ | GP1: Insulin aspart 70/30 (v) Start: 0.2 U/kg/day Range: 0.16 U/kg (qd) – 0.43 U/kg (bid) T: once or twice daily D: 24 weeks GP2: OA agents (v) T: NR D: 24 weeks | Symptoms and PG < 56 mg/dL and handled by self or PG < 56 mg/dL GP1 number of events: 177 GP2 number of events: 45 | | Severe CNS symptoms and unable to treat self + PG < 56 mg/dL or reversal of symptoms with treatment GP1 number of events: 1 GP2 number of events: 1 | | | Mild and severe GP1 178 (54) p: < 0.005 GP2 46 (30)
Kvapil, 2006 ^51^ | GP1: Insulin aspart 70/30 (v) Start: 0.3 U/kg Mean: 0.51 U/kg T: Breakfast, dinner D: 16 weeks GP2: Metformin (fix) Mean: 1660 mg daily Range: 500 – 3000 mg qd T: NR D: 16 weeks Glibenclamide (v) Start: 1.75 mg Mean: 2.33 (start), 6.58 mg (end) T: once or twice daily | Symptoms confirmed by BG < 50.4 mg/dL (2.8 mmol/l), handled by patient; asymptomatic BG < 50.4 mg/dL GP1 10 (9*) number of events: 20 GP2 9 (8*) number of events: 28 | | Required assistance, BG < 50.4 mg/dL (2.8 mmol/)l, need for food or IV glucose GP1 0 (0*) GP2 0 (0*) | | | Total hypoglycemic events (includes minor and symptomatic only) GP1 event rate: 0.037/patient-week GP2 event rate: 0.04/patient-week Symptoms without confirmatory BG GP1 22 (21*) number of events: 44 GP2 23 (20*) number of events: 43
Kvapil, 2006 ^51^ | GP1: Insulin aspart 70/30 (v) Start: 0.2 U/kg Mean: 0.3 U/kg T: Breakfast, dinner D: 16 weeks Metformin (fix) Mean: 1660 mg daily Range: 500 – 3000 mg qd T: NR D: 16 weeks GP2: Metformin (fix) Mean: 1660 mg daily Range: 500 – 3000 mg qd T: NR D: 16 weeks Glibenclamide (v) Start: 1.75 mg Mean: 2.33 (start), 6.58 mg daily (end) T: once or twice daily D: 16 weeks | Symptoms confirmed by BG < 50.4 mg/dL (2.8 mmol/l), handled by patient; asymptomatic BG < 50.4 mg/dL GP1 13 (12*) number of events: 23 GP2 9 (8*) number of events: 28 | | Required assistance, BG < 50.4 mg/dL (2.8 mmol/l), need for food or IV glucose GP1 0 (0*) GP2 0 (0*) | | | Symptoms without confirmatory BG GP1 22 (20*) number of events: 44 GP2 23 (20*) number of events: 43 Total hypoglycemic events (includes minor and symptomatic only) GP1 event rate: 0.039/patient-week GP2 event rate: 0.04/patient-week
Raz, 2003 ^57^ | GP1: Insulin aspart 70/30 (v) Start: 6–8 U bid T: Breakfast, dinner D: 6 weeks Rosiglitazone (fix) Start: 4 mg T: Breakfast D: 6 weeks GP2: Glibenclamide (fix) Range: 7.5 – 15 mg T: Dinner D: 6 weeks Rosiglitazone (fix) Start: 4 mg T: Breakfast D: 6 weeks | BG < 50 mg/dL handled by self GP1 event rate: 1.8/year p: 0.03 GP2 event rate: 0/year | | | | | Minor episodes with symptoms but no blood sugars GP1 event rate: 5.3/year p: <0.01 vs. GP2 GP2 event rate: 0/year
Raz, 2005 ^54^ | GP1: Insulin aspart 70/30 (v) Start: 0.3 U/kg Mean: 0.7 U/kg T: Breakfast, dinner D: 18 weeks GP2: Glibenclamide (v) Start: 5 to 10 mg Mean: 14 mg T: Breakfast D: 18 weeks Pioglitazone (fix) Start: 30 mg Mean: 30 mg T: Breakfast D: 18 weeks | BG < 50 mg/dL but did not require third party assistance GP1 15 (15) number of events: 47 GP2 3 (3) number of events: 3 | | BG < 50 mg/dL or requiring third party assistance GP1 0 (0*) GP2 0 (0*) | | Midnight to 6 am GP1 number of events: 8 GP2 number of events: 0 | All hypoglycemic episodes - symptoms or BG < 50 mg/dL GP1 event rate: 0.132/patient-week GP2 event rate: 0.032/patient-week
Raz, 2005 ^54^ | GP1: Insulin aspart 70/30 (v) Start: 0.2 U/kg Mean: 0.5 U/kg T: Breakfast, dinner D: 18 weeks Pioglitazone (fix) Start: 30 mg Mean: 30 mg T: Breakfast D: 18 weeks GP2: Glibenclamide (v) Start: 5 to 10 mg Mean: 14 mg T: Breakfast D: 18 weeks Pioglitazone (fix) Start: 30 mg Mean: 30 mg T: Breakfast D: 18 weeks | BG < 50 mg/dL but did not require third party assistance GP1 11 (12) number of events: 15 GP2 3 (3) number of events: 3 | | BG < 50 mg/dL or requiring third party assistance GP1 0 (0*) GP2 0 (0*) | | Midnight to 6 am GP1 number of events: 0 GP2 number of events: 0 | All hypoglycemic episodes - symptoms or BG < 50 mg/dL GP1 event rate: 0.083/patient-week GP2 event rate: 0.032/patient-week
Ushakova, 2007 ^59^ | GP1: Insulin aspart 70/30 (v) Start: 0.3 – 0.5 U/kg Mean: 55.5 U T: bid for 2 weeks, then tid D: 16 weeks GP2: Continuation of OA agents (v) T: NR D: 16 weeks | BG < 55.8 mg/dL (3.1 mmol/L), with or without symptoms, and handled by patient GP1 4 (4*) GP2 1 (1*) | | BG < 55.8 mg/dL (3.1 mmol/L) and required 3rd party help or symptoms reversed after intake of food, glucagon, or IV glucose GP1 0 (0*) GP2 0 (0*) | | | Symptoms only GP1 28 (27.5) GP2 4 (3.8) Overall hypoglycemia GP1 Event rate: 0.73/person-year GP2 Event rate: 0.69/person-year
Insulin aspart 70/30 vs. exenatide
Nauck, 2007 ^49^ | GP1: Insulin aspart 70/30 (v) Start: 15.7 U/day Mean: 24.4 U/day T: Breakfast, dinner D: 52 weeks ‘Optimally’ effective metformin and sulfonylurea therapy (v) T: NR D: 52 weeks GP2: exenatide (v) Start: 5 μg bid Range: 5 – 10 μg bid T: Breakfast D: 52 weeks ‘Optimally’ effective metformin and sulfonylurea therapy (v) T: NR D: 52 weeks | | | Severe, not further defined GP1 0 (0) GP2 0 (0) | Not further defined GP1 Event rate: 4.4/patient-year p: NS GP2 Event rate: 4.1/patient-year | Nocturnal, not further defined GP1 25 (62) event rate: 1.1/patient-year p: NS GP2 44 (17) Event rate: 0.6/patient-year | Symptoms or PG < 61.2 mg/dL (3.4 mmol/L) GP1 Event rate: 5.6/patient-year p: NS GP2 Event rate: 4.7/patient-year
Insulin aspart 70/30 vs. insulin lispro 75/25
Hermansen, 2002 ^58^ | GP1: Insulin aspart 70/30 (fix) Start: 0.4 U/kg T: Breakfast D: 1 day GP2: Insulin lispro 75/25 (fix) Start: 0.4 U/kg T: Breakfast D: 1 day | | | Requiring third-party assistance GP1 number of events: 2 GP2 number of events: 5 | | | Overall hypoglycemia rates (not specified) GP1 number of events: 23 GP2 number of events: 19
Niskanen, 2004 ^55^ | GP1: Insulin aspart 70/30 (v) Mean: 0.65 to 0.67 U/kg T: Breakfast, dinner D: 12 weeks GP2: Insulin lispro 75/25 (v) Mean: 0.67 to 0.71 U/kg T: Breakfast, dinner D: 12 weeks | BG < 50.4 mg/dL (2.8 mmol/L) with or without symptoms or symptoms not confirmed by BG reading GP1 57 (43*) number of events: 269 GP2 53 (40*) number of events: 233 | | Required third party assistance GP1 1 (1*) GP2 1 (1*)
Insulin aspart 70/30 vs. insulin aspart 70/30 + oral antidiabetic agents
Kvapil, 2006 ^51^ | GP1: Insulin aspart 70/30 (v) Start: 0.3 U/kg Mean: 0.51 U/kg T: Breakfast, dinner D: 16 weeks GP2: Insulin aspart 70/30 (v) Start: 0.2 U/kg Mean: 0.3 U/kg T: Breakfast, dinner D: 16 weeks Metformin (fix) Mean: 1660 mg daily Range: 500 – 3000 mg qd T: NR D: 16 weeks | Symptoms confirmed by BG < 50.4 mg/dL (2.8 mmol/l), handled by patient; asymptomatic BG < 50.4 mg/dL GP1 10 (9*) number of events: 20 GP2 13 (12*) number of events: 23 | | Required assistance, BG < 50.4 mg/dL (2.8 mmol/l), need for food or IV glucose GP1 0 (0*) GP2 0 (0*) | | | Symptoms without confirmatory BG GP1 22 (21*) number of events: 44 GP2 22 (20*) number of events: 44 Total hypoglycemic events (includes minor and symptomatic only) GP1 Event rate: 0.037/patient-week GP2 Event rate: 0.039/patient-week
Raz, 2005 ^54^ | GP1: Insulin aspart 70/30 (v) Start: 0.3 U/kg Mean: 0.7 U/kg T: Breakfast, dinner D: 18 weeks GP2: Insulin aspart 70/30 (v) Start: 0.2 U/kg Mean: 0.5 U/kg T: Breakfast, dinner D: 18 weeks Pioglitazone (fix) Start: 30 mg Mean: 30 mg T: Breakfast D: 18 weeks | BG < 50 mg/dL but did not require third party assistance GP1 15 (15) number of events: 47 GP2 11 (12) number of events: 15 | | BG < 50 mg/dL or requiring third party assistance GP1 0 (0*) GP2 0 (0*) | | Midnight to 6 am GP1 number of events: 8 GP2 number of events: 0 | All hypoglycemic episodes - symptoms or BG < 50 mg/dL GP1 Event rate: 0.132/patient-week GP2 Event rate: 0.083/patient-week
Ushakova, 2007 ^59^ | GP1: Insulin aspart 70/30 (v) Start: 0.3 – 0.5 U/kg Mean: 55.5 U T: bid for 2 weeks, then tid D: 16 weeks GP2: Insulin aspart 70/30 (v) Start: 0.3 – 0.5 U/kg Mean: 44.8 U T: Breakfast, dinner D: 16 weeks Metformin (v) Start: 500 mg qd or bid or 850 mg qd T: NR D: 14 weeks (started after 2 weeks) | BG < 55.8 mg/dL (3.1 mmol/L), with or without symptoms, and handled by patient GP1 4 (4*) GP2 9 (9*) | | BG < 55.8 mg/dL (3.1 mmol/L) and required 3rd party help or symptoms reversed after intake of food, glucagon, or IV glucose GP1 0 (0*) GP2 0 (0*) | | | Symptoms only GP1 28 (27.5) p: NS vs. GP2 GP2 28 (28) Overall hypoglycemia GP1 event rate: 0.73/person-year p: NS vs. GP2 GP2 event rate: 0.69/person-year
Insulin aspart 70/30 vs. rapid-acting insulin analogues with intermediate-acting human insulin
Hirao, 2008 ^61^ | GP1: Insulin aspart 70/30 (NR) T: bid D: 6 months GP2: Insulin aspart (NR) T: tid D: 6 months NPH insulin (NR) T: Optional multiple daily injections D: 6 months | | | Major hypoglycemia, not further defined GP1^‖^ 0 (0) GP2^‖^ 0 (0)
Insulin lispro 75/25 vs. long-acting insulin analogues
Cox, 2007 ^74^ | GP1: Insulin lispro 75/25 (v) T: Breakfast, dinner D: 12 weeks Metformin (NR) T: NR D: 12 weeks GP2: Insulin glargine (v) T: Bedtime D: 12 weeks Metformin (NR) T: NR D: 12 weeks | | | Severe, not defined GP1 0 (0*) GP2 0 (0*) | | | Symptoms or BG < 63 md/dL (3.5 mmol/L) GP1 p: NS
Jacober, 2006 ^64^ | GP1: Insulin lispro 50/50 (v) Mean: 0.353 IU/kg; 36.73 IU T: Breakfast, lunch D: 4 months Insulin lispro 75/25 (v) T: Dinner D: 4 months Existing oral therapy (NR) T: NR D: 4 months GP2: Insulin glargine (v) Mean: 0.276 IU/kg; 27.98 IU T: Bedtime D: 4 months Existing oral therapy (NR) T: NR D: 4 months | | | Self reported GP1 0 (0) GP2 0 (0) | | Self reported symptoms or PG ≤ 72 mg/dL GP1 Event rate: 0.8/patient/30 days (SD: 2.12) p: 0.3604 GP2 Event rate: 1.05/patient/30 days (SD: 1.59) | Self reported symptoms or PG ≤ 72 mg/dL GP1 42* (72.2) p: 0.033 Event rate: 3.98/patient/30 days (SD: 4.74) p: 0.0013 GP2 56* (94.8) Event rate: 2.57/patient/30 days (SD: 3.22)
Malone, 2004 ^65^ | GP1: Insulin lispro 75/25 (v) Mean: 0.62 U/kg T: Breakfast, dinner D: 16 weeks Metformin (NR) Mean: 1945 mg Range: 1500 – 2550 mg T: NR D: 16 weeks GP2: Insulin glargine (v) Mean: 0.57 U/kg T: Bedtime D: 16 weeks Metformin (NR) Mean: 1997 mg Range: 1500 – 2550 mg T: NR D: 16 weeks | | | Requiring third-party assistance due to disabling hypoglycemia GP1 0 (0) GP2 0 (0) | | BG < 63 mg/dL or symptoms occurring between bedtime and before breakfast GP1 30 (30) number of events: 39 GP2 28 (28) number of events: 63 | BG < 63 mg/dL or symptoms GP1 57 (57) number of events: 181 Event rate: 0.68/patient/30 days (SD: 1.38) p: 0.041 GP2 40 (40) number of events: 87 Event rate: 0.39/patient/30 days (SD: 1.24)
Malone, 2005 ^66^ | GP1: Insulin lispro 75/25 (v) Mean: 0.42 U/kg T: Breakfast, dinner D: 16 weeks Metformin (fix) Mean: 2128 mg Range: 1500 – 2550 mg T: NR D: 16 weeks GP2: Insulin glargine (v) Mean: 0.36 U/kg T: Bedtime D: 16 weeks Metformin (fix) Mean: 2146 mg Range: 1500 – 2550 mg T: NR D: 16 weeks | | | Not defined GP1 0 (0*) GP2 0 (0*) | BG < 63 mg/dL (3.5 mmol/L) or symptoms GP1 Event rate: 0.46/patient/30 days (SD: 1.28) p: 0.003 GP2 Event rate: 0.1/patient/30 days (SD: 0.51) | BG < 63 mg/dL (3.5 mmol/L) or symptoms occurring between bedtime and breakfast for the patient GP1 Event rate: 0.14//patient/30 days (SD: 0.49) p: 0.002 GP2 Event rate: 0.34/patient/30 days (SD: 0.85) | Overall rate of BG < 63 mg/dL (3.5 mmol/L) or symptoms GP1 Event rate: 0.61/patient/30 days (SD: 1.41) p: 0.477 GP2 Event rate: 0.44/patient/30 days (SD: 1.07)
Roach, 2006 ^63^ | GP1: Insulin lispro 75/25 (v) Mean: 23 U (morning) and 37 U (evening) Range: 0 – 72 U (morning); 11 – 88 U (evening) T: Breakfast, dinner D: 12 weeks OA agents (NR) Start: current dose T: NR D: 12 weeks Metformin (v) Start: 500 mg qd T: NR D: 12 weeks GP2: Insulin glargine (v) Mean: 44 U Range: 14 U – 100 U T: Breakfast D: 12 weeks OA agents (NR) Start: current dose T: NR D: 12 weeks Metformin (v) Start: 500 mg qd T: NR D: 12 weeks | Self reported BG < 63 mg/dL (3.5 mmol/L) or symptoms GP1 3 (15*) GP2 2 (10*) | | Not defined GP1 0 (0*) GP2 0 (0*) | PG < 63 mg/dL (3.5 mmol/L) GP1 0 (0*) GP2 1 (5*) | PG < 63 mg/dL (3.5 mmol/L) GP1 8 (40*) GP2 2 (10*) | PG < 63 mg/dL (3.5 mmol/L) GP1 8 (40*) GP2 3 (15*)
Insulin lispro 75/25 vs. premixed human insulins
Coscelli, 2003 ^67^ | GP1: Insulin lispro 75/25 (v) Mean: 38.1 Range: 12 – 72 T: Breakfast, dinner D: 12 days Diet/exercise D: 12 days GP2: NPH/regular 70/30 (v) Mean: 37.3 Range: 10 – 72 T: Breakfast, dinner D: 12 days Diet/exercise D: 12 days | | | | | | Not defined GP1 p: NS vs. GP2
Hermansen, 2002 ^58^ | GP1: Insulin lispro 75/25 (fix) Start: 0.4 U/kg T: Breakfast D: 1 day GP2: NPH/regular 70/30 (fix) Start: 0.4 U/kg T: Breakfast D: 1 day | | | Requiring third-party assistance GP1 number of events: 5 GP2 number of events: 2 | | | Overall hypoglycemia (not specified) GP1 number of events: 19 GP2 number of events: 11
Herz, 2002 ^71^ | GP1: Insulin lispro 75/25 (v) Mean: 26.1 U T: Breakfast, dinner D: 4 weeks GP2: NPH/regular 70/30 (v) Mean: 26.2 U T: Breakfast, dinner D: 4 weeks | | | | | | Symptoms or BG < 54 mg/dL (3.0 mmol/L)¶ GP1 Event rate: 0.7/patient/30 days (SE = 0.2) p: 0.042 GP2 Event rate: 1.2/patient/30 days (SE = 0.3) Symptoms or BG < 54 mg/dL (3.0 mmol/L)§ GP1 Event rate: 0.9/patient/30 days (SE = 0.2) p: 0.569 GP2 Event rate: 0.9/patient/30 days (SE = 0.1)
Herz, 2003 ^12^ | GP1: Insulin lispro 75/25 (v) Mean: 31.6^¶^ (morning)¶ and 26.8 U (evening)¶ and 32.4 (morning)§ and 27.6 U (evening)§ T: Breakfast, dinner D: 4 weeks GP2: NPH/regular 70/30 (v) Mean: 32.3^¶^ (morning)¶ and 26.4 U (evening)¶ and 33.3 (morning)§ and 27.5 U (evening)§ T: Breakfast, dinner D: 4 weeks | | | | | | Symptoms or any spontaneous BG < 54 mg/dL (3.0 mmol/L)¶ GP1 Event rate: 0.049/patient/30 days (SE = 0.018) p: 0.586 GP2 Event rate: 0.1/patient/30 days (SE = 0.018) Symptoms or any spontaneous BG < 54 mg/dL (3.0 mmol/L)§ GP1 Event rate: 0.241/patient/30 days (SE = 0.053) p: 0.524 GP2 Event rate: 0.222/patient/30 days (SE = 0.053)
Malone, 2000 ^44^ | GP1: Insulin lispro 75/25 (fix) Mean: 35.4 U (0.43 U/kg) T: Breakfast D: 2 days GP2: NPH/regular 70/30 (fix) Mean: 35.4 U (0.43 U/kg) T: Breakfast D: 2 days | | | | | | BG < 63 mg/dL (3.5 mmol/L) or symptoms occurring between lunch and dinner GP1 number of events: 3 GP2 number of events: 5 BG < 63 mg/dL (3.5 mmol/L) or symptoms GP1 number of events: 7 GP2 number of events: 10 BG < 63 mg/dL (3.5 mmol/L) or symptoms occurring within 4 hours of test meal GP1 number of events: 5 GP2 number of events: 8
Mattoo, 2003 ^70^ | GP1: Insulin lispro 75/25 (NR) Mean: 20 (morning), 32 U (evening) T: Breakfast, dinner D: 2 weeks GP2: NPH/regular 70/30 (NR) Mean: 20 (morning), 32 U (evening) T: Breakfast, dinner D: 2 weeks | | | | | | Symptoms or BG < 63 mg/dL (3.5 mmol/L) GP1 event rate: 0.4/patient/14 days (SD = 0.9) p: 0.725 GP2 event rate: 0.4/patient/14 days (SD = 0.8)
Roach, 1999 ^73^ | GP1: Insulin lispro 75/25 (v) Mean: 0.37 (morning), 0.28 (evening) U/kg T: Breakfast, dinner D: 13 weeks GP2: NPH/regular 70/30 (v) Mean: 0.36 (morning), 0.27 (evening) U/kg T: Breakfast, dinner D: 13 weeks | | | Required third party assistance GP1 1 (1*) GP2 1 (1*) | | Symptoms or BG < 54 mg/dL (3.0 mmol/L) occurring between mean reported bedtime and mean reported breakfast time for each country GP1 13 (15) p: 0.266 GP2 8 (9) | Symptoms or BG < 54 mg/dL (3.0 mmol/L) GP1 34* (42) p: 0.398 GP2 28* (35)
Schwartz, 2006 ^62^ | GP1: Insulin lispro 75/25 (fix) Start: 2/3 of usual daily dose Mean: 44.1 U T: Breakfast D: 1 day GP2: NPH/regular 70/30 (fix) Start: 2/3 of usual daily dose Mean: 44.1 U T: Breakfast D: 1 day | GP1 0 (0*) GP2 1 (5*)
Insulin lispro 75/25 vs. oral antidiabetic agents
Herz, 2002 ^72^ | GP1: Insulin lispro 75/25 (v) Start: 0.3 – 0.5 U/kg Mean: 0.46 U/kg T: Breakfast, dinner D: 16 weeks GP2: Glyburide (fix) Start: 15 mg/day T: Breakfast, dinner D: 16 weeks | | | Requiring assistance of third party GP1 0 (0*) GP2 0 (0*) | | | Any (BG < 54 mg/dL (3 mmol/L) or symptoms) GP1 B: 0.14 episodes/patient/30 days (SE 0.14) p: 0.361 vs GP2 F: 0.31 episodes/patient/30 days (SE 0.21) p: 0.028 vs GP2 F-B: 0.17 episodes/patient/30 days (SE 0.02) p: 0.077 vs GP2
Malone, 2003 ^68^ | GP1: Insulin lispro 75/25 (v) Mean: 0.19 U/kg (morning) and 0.14 U/kg (evening) T: Breakfast, dinner D: 16 weeks Metformin (v) Mean: 1813 mg/day Range: 1500 – 2550 mg/day T: 2 to 3 times/day D: 16 weeks GP2: Metformin (v) Mean: 1968 mg/day Range: 1500 – 2550 mg/day T: 2 to 3 times/day D: 16 weeks Glibenclamide (v) Mean: 14.2 mg/day T: NR D: 16 weeks | | | Unable to treat self or BG < 36 mg/dL (2.0 mmol/L) (events/patient/30 days) GP1 B: 0.01 Median (0.09) F: 0.01 Median (0.11) F-B: 0* (1) GP2 B: 0 Median (0) F: 0.02 Median (0.15) F-B: 0* (1.3) GP1–GP2: 0* | | Symptoms or BG < 63 mg/dL (3.5 mmol/L) occurring after bedtime (events/patient/30 days) GP1 B: 0.03 (0.23) F: 0.01 (0.11) F-B: 0* GP2 B: 0 (0) F: 0.08 (0.4) F-B: 0* GP1–GP2: 0* Symptoms or BG < 63 mg/dL (3.5 mmol/L) occurring after bedtime GP1 (1) GP2 (5) | Overall events/patient/30 days GP1 B: 0.08 (0.59) F: 0.31 (1.07) F-B: 0* GP2 B: 0.07 (0.57) F: 0.48 (1.17) F-B: 0* GP1–GP2: 0*
Tirgoviste, 2003 ^43^ | GP1: Insulin lispro 75/25 (v) Start: 0.3 – 0.5 U/kg T: Breakfast, dinner D: 16 weeks GP2: Glibenclamide (v) Start: 15 mg T: Breakfast, dinner D: 16 weeks | | | | | | Symptoms and/or BG < 54 mg/dL (3.0 mmol/L) GP1 38 (44.7) p: 0.001 GP2 9 (10.3)
Insulin lispro 75/25 vs. insulin lispro 50/50
Roach, 2003 ^69^ | GP1: Insulin lispro 75/25 (v) Mean: 31.3 (morning), 27.6 U (evening) T: Breakfast, dinner D: 8 weeks GP2: Insulin lispro 50/50 (v) Mean: 31.5 U T: Breakfast D: 8 weeks Insulin lispro 75/25 (v) Mean: 27.9 U T: Dinner D: 8 weeks | | | Required third party assistance GP1 0* (0) GP2 0* (0) | | | Symptoms GP1 28* (26.1) p: 0.078 number of events: 65 p: 0.681 GP2 34* (32.4) number of events: 68
Schwartz, 2006 ^62^ | GP1: Insulin lispro 75/25 (fix) Start: 2/3 of usual daily dose Mean: 44.1 U T: Breakfast D: 1 day GP2: Insulin lispro 50/50 (fix) Start: 2/3 of usual daily dose Mean: 43.8 U T: Breakfast D: 1 day | GP1 0 (0*) GP2 0 (0*)
Insulin lispro 50/50 vs. long-acting insulin analogues
Kazda, 2006 ^76^ | GP1: Insulin lispro 50/50 (v) Start: 0.30 IU/kg mean Mean: 0.59 IU/kg T: Breakfast, lunch, dinner D: 24 weeks GP2: Insulin glargine (v) Start: 0.16 IU/kg mean Mean: 0.43 IU/kg T: Bedtime D: 24 weeks | | | Not defined GP1 0 (0) GP2 0 (0) | | | Symptoms or PG < 54 mg/dL (3.0 mmol/L) GP1 24* (44.4) Event rate: 1.5/100 patient-days GP2 17* (32.1) Event rate: 1/ 100 patient-days
Robbins, 2007 ^79^ | GP1: Insulin lispro 50/50 (v) Mean: 0.7 U/kg T: Breakfast, lunch, dinner D: 24 weeks Metformin (fix) Mean : 1641 mg T: bid D: 24 weeks GP2: Insulin glargine (v) Mean : 0.6 U/kg T: Bedtime D: 24 weeks Metformin (fix) Mean: 1636 mg T: bid D: 24 weeks | | | Required 3rd party assistance and BG < 50 mg/dL (2.9 mmol/L) or prompt recovery GP1 3 (1.9) number of events: 8 p: NS GP2 2 (1.3) number of events: 4 | | Episodes occurring after bedtime and before awakening GP1 Event rate: 0.2/30 patient-days (SD = 0.7) p: 0.30 vs GP2 GP2 Event rate: 0.3/30 patient-days (SD = 0.6) s | Overall (signs or symptoms or BG < 63 mg/dL (3.5 mmol/L)) GP1 81 (51.9) Event rate: 0.8/30 patient-days (SD = 1.4) p: 0.07 for event rate vs GP2 GP2 77 (48.4) Event rate: 0.5/30 patient-days (SD = 1.0)
Insulin lispro 50/50 vs. rapid-acting insulin analogues
Kazda, 2006 ^76^ | GP1: Insulin lispro 50/50 (v) Start: 0.30 IU/kg mean Mean: 0.59 IU/kg T: Breakfast, lunch, dinner D: 24 weeks GP2: Insulin lispro (v) Start: 0.25 IU/kg mean Mean: 0.50 IU/kg T: Breakfast, lunch, dinner D: 24 weeks | | | Not defined GP1 0 (0) GP2 0 (0) | | | Symptoms or PG < 54 mg/dL (3.0 mmol/L) GP1 24* (44.4) Event rate: 1.5/100 patient-days GP2 28* (53.8) Event rate: 1.4/100 patient-days
Insulin lispro 50/50 vs. rapid-acting with long-acting insulin analogues
Rosenstock, 2008 ^80^ | GP1: Insulin lispro 50/50 (v) Start: Insulin glargine dose at entry (52.5 U) Mean: 123 U T: Breakfast, lunch, dinner D: 24 weeks Insulin lispro 75/25 (v) Start: allowed to switch evening dose to insulin lispro 75/25 T: Dinner D: Unclear GP2: Insulin glargine (v) Start: 50% of insulin glargine dose at entry (54.9 U) Mean: 70 U T: Bedtime D: 24 weeks Insulin lispro (v) Start: 50% of insulin glargine dose at entry divided in 3 equal doses (54.9 U) Mean: 76 U T: Breakfast, lunch, dinner D: 24 weeks | | | Required 3rd party assistance GP1 6 (3.21) p: 0.751 Event rate: 0.1/patient-year (SD = 0.65) p: 0.266 GP2 4 (2.14) Event rate: 0.05/patient-year (SD = 0.31) | | Nocturnal (not further defined) GP1 109 (58.29) p: 1 Event rate: 4.78/patient-year (SD = 7.15) p: 0.139 GP2 110 (58.82) Event rate: 6.17/patient-year (SD = 10.68) | BG < 72 mg/dL (4.0 mmol/L) GP1 165 (88.24) p: 1 Event rate: 46.5/patient-year (SD = 48) p: 0.747 GP2 165 (88.24) Event rate: 44.95/patient-year (SD = 46.8) BG < 60 mg/dL (3.3 mmol/L) GP1 148 (79.14) p: 0.898 Event rate: 20.75/patient-year (SD = 26.86) p: 0.574 GP2 150 (80.21) Event rate: 19.26/patient-year (SD = 24.51) BG < 50 mg/dL (2.8 mmol/L) GP1 104 (55.61) p: 0.294 Event rate: 7.34/patient-year (SD = 12.88) p: 0.23 GP2 115 (61.5) Event rate: 5.93/patient-year (SD = 9.92)
Insulin lispro 50/50 vs. premixed human insulin
Roach, 1999 ^10^ | GP1: Insulin lispro 50/50 (v) Mean: 0.31 U/kg T: Breakfast D: 3 months Insulin lispro 75/25 (v) Mean: 0.26 U/kg T: Dinner D: 3 months GP2: NPH/regular 50/50 (v) Mean: 0.32 U/kg T: Breakfast D: 3 months NPH/regular 70/30 (v) Mean: 0.26 U/kg T: Dinner D: 3 months | | | Occurrence of coma or requirement for intravenous glucose, glucagon, or both GP1 0 (0*) GP2 0 (0*) | | Symptoms or BG < 54 mg/dL (3.0 mmol/L) occurring between median bedtime (10:30pm) and median breakfast (7:45am) GP1 Event rate: 0.3/3 patient-months (SD: 1.0) p: 0.199 GP2 Event rate: 0.6/3 patient-months (SD: 1.4) | Symptoms or BG < 54 mg/dL (3.0 mmol/L) GP1 25* (40) p: NS GP2 23* (37)
Schernthaner, 2004 ^77^ | GP1: Insulin lispro 50/50 (v) Mean: 64.6 IU T: Breakfast, lunch, dinner D: 12 weeks Diet/exercise D: 12 weeks GP2: NPH/regular 70/30 (v) Mean: 61.8 IU T: Breakfast, dinner D: 12 weeks Diet/exercise D: 12 weeks | | | BG < 36 mg/dL, coma, or treatment with glucagon or intravenous glucose GP1 0 GP2 1 | | | BG < 65 mg/dL or symptoms GP1 14 (41.2) p: NS GP2 10 (29.4)
Schwartz, 2006 ^62^ | GP1: Insulin lispro 50/50 (fix) Start: 2/3 of usual daily dose Mean: 43.8 U T: Breakfast D: 1 day GP2: NPH/regular 70/30 (fix) Start: 2/3 of usual daily dose Mean: 44.1 U T: Breakfast D: 1 day | GP1 0 (0*) GP2 1 (5*)
Yamada, 2007 ^78^ | GP1: Insulin lispro 50/50 (v) Start: current dose Mean: 0.37 (start), 0.38 U/kg (end) T: twice daily D: 4 months GP2: NPH/regular 70/30 (v) Start: current dose Mean: 0.34 (start), 0.37 U/kg (end) T: twice daily D: 4 months NPH/regular 50/50 (v) Start: current dose Mean: 0.34 U/kg (start), 0.37 U/kg (end) T: twice daily D: 4 months | | | Requiring third party assistance GP1 0 (0*) GP2 0 (0*)

* Number has been imputed.

‖ Among those not using thiazolidinediones.

‡ One-hundred and four (36%) of the 291 participants of this trial are patients with type 1 diabetes. The remaining population has type 2 diabetes and is the same study population as Boehm 2004. ^45^ Only data for the Boehm 2004 study is presented because it has the longest followup.

¶ Results occurring during the outpatient phase.

§ Results occurring during the inpatient phase.

μg = microgram; B = baseline; BG = blood glucose; bid = twice daily ; BS = blood sugar; CGMS = Continuous Glucose Monitoring System; CI = confidence interval; CNS = central nervous system; D = duration; dl = deciliter; F = final; F-B = mean difference from baseline; fix = fixed dosing; GP = group; GP1–GP2 = mean difference between the difference from baseline; h = hour; IQR = interquartile range; IU = international unit; kg = kilogram; L = liter; mg = milligram; ml = milliliter; mmol = millimole; NPH = neutral protamine Hagedorn; NR = not reported; NS = not significant; OA = oral antidiabetic; p = p-value; PG = plasma glucose; qd = once daily; RR = relative risk; SD = standard deviation; SE = standard error; T = time of day when insulin taken; tid = thrice daily; U = unit; v = dosing varied

Table 6 Comparative effectiveness of premixed insulin analogues and other diabetes treatments on adverse events

Author, year | Intervention | Weight in kg, mean (SD) | Injection site reaction, n (%) | Total serious adverse events, n (%) | Withdrawn due to adverse events, n (%) | Other serious adverse events, n (%)
Insulin aspart 70/30 vs. long-acting insulin analogues
Holman, 2007 ^32^ | GP1: Insulin aspart 70/30 (v) Start: 16 median IU/day Range: 10 – 26 IU/day T: bid D: 1 year Usual care D: 1 year GP2: Insulin detemir (v) Start: 16 median IU/day Range: 10 – 24 IU/day T: Bedtime, twice if required D: 1 year Usual care D: 1 year | GP1 F-B: 4.7 (4) p: < 0.001 GP2 F-B: 1.9 (4.2) GP1–GP2: 3* | | GP1 41 (17.4) p: overall 0.25 GP2 30 (12.8) | GP1 2 (1*) GP2 4 (2*) | Gastrointestinal and abdominal pain GP1 3 (1.3) p: overall 0.21 GP2 2 (0.9) Lower respiratory tract and lung infection GP1 4 (1.7) p: overall 0.02 GP2 0 (0)
Kann, 2006 ^50^ | GP1: Insulin aspart 70/30 (v) Start: 0.1 U/kg bid Mean: 0.4 U/kg T: Breakfast, dinner D: 26 weeks Metformin (v) Start: 500 mg bid or current dose T: Breakfast, dinner D: 26 weeks GP2: Insulin glargine (v) Start: 0.2 U/kg qd Mean: 0.39 U/kg T: Preferred time (constant through study) D: 26 weeks Glimepiride (v) Start: 1 mg daily or current dose T: Breakfast D: 26 weeks | GP1 B: 84* F: 84.8 (17.2) F-B: 0.7 p: NS vs. baseline GP2 B: 86* F: 88.1 (14.6) F-B: 1.5 (95% CI: 0.84 – 2.19) p: < 0.0001 vs. baseline GP1–GP2: -1* | | GP1 10 (7.8) GP2 11 (8.7) | GP1 5 (4*) GP2 2 (2*)
Raskin, 2005 ^39^ Raskin, 2007 ^40^ | GP1: Insulin aspart 70/30 (v) Start: 10 or 12 U T: Breakfast, dinner D: Unclear Metformin (v) Range: 1500 – 2550 mg/day T: NR D: Unclear GP2: Insulin glargine (v) Start: 10–12 U/day T: Bedtime D: Unclear Metformin (v) Range: 1500 – 2550 mg/day T: NR D: Unclear | GP1 F-B: 5.4 (4.8) p: < 0.01 GP2 F-B: 3.5 (4.5) GP1–GP2: 1* GP1^‖^ F-B: 5.6 (4.6) p: 0.0004 GP2^‖^ F-B: 3 (4.3) GP1–GP2: 3* | | GP1^‖^ 4 (5) GP2 5 (6) | GP1 4 (3*) GP2 1 (1*) GP1^‖^ 3 (4*) GP2 0 (0*)
Tamemoto, 2007 ^47^ | GP1: Insulin aspart 70/30 (v) Start: 10 – 16 U/day Mean: 26.7 U T: Breakfast, dinner D: 6 months Continued OA agents (NR) T: NR D: 6 months GP2: Insulin glargine (v) Start: 6 – 8 U/day T: NR D: 6 (expected) months Continued OA agents (NR) T: NR D: 6 months | GP1 F-B: 0.42 p: NS GP2 F-B: 0.51 GP1–GP2: -1* | | | GP1 0 (0*) GP2 0 (0*)
Insulin aspart 70/30 vs. rapid-acting insulin analogues
Holman, 2007 ^32^ | GP1: Insulin aspart 70/30 (v) Start: 16 median IU/day Range: 10 – 26 IU/day T: bid D: 1 year Usual care D: 1 year GP2: Insulin aspart (v) Start: 18 median IU/day Range: 9 – 24 IU/day T: Breakfast, lunch, dinner D: 1 year Usual care D: 1 year | GP1 F-B: 4.7 (4) p: 0.005 vs. GP2 GP2 F-B: 5.7 (4.6) GP1–GP2: -1* | | GP1 41 (17.4) p: overall 0.25 GP2 30 (12.6) | GP1 2 (1*) GP2 0 (0*) | Gastrointestinal and abdominal pain GP1 3 (1.3) p: overall 0.21 GP2 0 (0) Lower respiratory tract and lung infection GP1 4 (1.7) p: overall 0.02 GP2 0 (0)
Insulin aspart 70/30 vs. rapid-acting with long-acting insulin analogues
Joshi, 2005 ^52^ | GP1: Insulin aspart 70/30 (v) Mean: 40.19 U/day T: bid D: 12 weeks GP2: Insulin aspart (v) Mean: 28.26 U/day T: before every meal D: 12 weeks Insulin glargine (v) Mean: 24.52 U/day T: Bedtime D: 12 weeks | GP1 B: 70.4 (12.18) F: 70.61 (11.23) F-B: 1* p: NS vs. baseline GP2 B: 69.63 (10.31) F: 69.68 (9.58) F-B: 0* p: NS vs. baseline GP1–GP2: 1* | | GP1 0 (0*) GP2 0 (0*) | GP1 0 (0*) GP2 0 (0*)
Insulin aspart 70/30 vs. premixed human insulins
Abrahamian, 2005 ^53^ | GP1: Insulin aspart 70/30 (v) Mean: 0.49 (start), 0.61 U/kg (end) T: Breakfast, lunch, dinner D: 24 weeks GP2: NPH/regular 70/30 (v) Mean: 0.46 (start), 0.59 U/kg (end) T: Breakfast, dinner D: 24 weeks | | | GP1 number of events: 16 GP2 number of events: 15 | GP1 3 (3*) GP2 0 (0*)
Boehm, 2004 ^45^ Boehm, 2002 ^9^ ‡ | GP1: Insulin aspart 70/30 (v) Start: 0.57 U/kg T: Breakfast, dinner D: 24 months GP2: NPH/regular 70/30 (v) Start: 0.57 U/kg T: Breakfast, dinner D: 24 months | GP1 F-B: 0.05 (SE 0.81) p: 0.07 vs. GP2 GP2 F-B: 2 (SE 0.69) GP1–GP2: -2* | | | GP1 5 (6*) GP2 6 (6*)
Hermansen, 2002 ^58^ | GP1: Insulin aspart 70/30 (fix) Start: 0.4 U/kg T: Breakfast D: 1 day GP2: NPH/regular 70/30 (fix) Start: 0.4 U/kg T: Breakfast D: 1 day | | | | GP1 1 (2*) GP2 0 (0*) | GP1 number of events: 1 GP2 number of events: 0
Kapitza, 2004 ^56^ | GP1: Insulin aspart 70/30 (NA) T: Breakfast D: 1 day GP2: NPH/regular 70/30 (NA) T: Breakfast D: 1 day | | | | GP1 0 (0*) GP2 0 (0*)
Kilo, 2003 ^15^ | GP1: Insulin aspart 70/30 (v) Start: 0.16 U/day Mean: 26 U/day T: Dinner D: 12 weeks Metformin (fix) Mean: about 2200 mg Range: 500 – 2550 mg T: 1–3 times/day D: 4 Weeks run-in, then 12 weeks GP2: NPH/regular 70/30 (v) Start: 0.16 U/day Mean: 29 U/day T: Dinner D: 12 weeks Metformin (fix) Mean: about 2200 mg Range: 500 – 2550 mg T: 1–3 times/day D: 4 Weeks run-in, then 12 weeks | GP1 F-B: 0.7 p: 0.251 vs. GP2 GP2 F-B: 1 GP1–GP2: 0* | | | GP1 2 (4*) GP2 0 (0*) | Blurred vision and pain in the extremities GP1 1 (2*) GP2 0 (0*)
McNally, 2007 ^48^ | GP1: Insulin aspart 70/30 (v) Start: 100 U/mL Mean: 68.8 U Range: 6 – 238.7 T: Breakfast, dinner D: 16 weeks GP2: NPH/regular 70/30 (v) Start: 100 U/mL Mean: 66.6 U Range: 11.3 – 240 U T: Breakfast, dinner D: 16 weeks | | | Resulted in death, was life-threatening or caused (or prolonged) hospitalization GP1 3* (4) GP2 5* (6) | GP1 2 (1*) GP2 1 (1*)
McSorley, 2002 ^11^ | GP1: Insulin aspart 70/30 (NR) T: Breakfast, dinner D: 2 weeks GP2: NPH/regular 70/30 (NR) T: Breakfast, dinner D: 2 weeks | | | | GP1 0 (0*) GP2 0 (0*) | GP1 0 (0*) GP2 0 (0*)
Insulin aspart 70/30 vs. intermediate-acting human insulin
Christiansen, 2003 ^13^ | GP1: Insulin aspart 70/30 (v) Start: insulin naïve: 8 – 16 U/day; taking NPH prior to trial: pretrial dose T: Breakfast, dinner D: 16 weeks GP2: NPH insulin (v) Start: insulin naïve: 8 – 16 U/day; taking NPH prior to trial: pretrial dose T: Breakfast, dinner D: 16 weeks | GP1 1 (0*) GP2 1 (0*) | | GP1 5 (2*) number of events: 5 GP2 7 (3*) number of events: 8 | GP1 2 (1*) GP2 2 (1*) | Allergic reaction to protamine GP1 1 (0*) GP2 0 (0*)
Kilo, 2003 ^15^ | GP1: Insulin aspart 70/30 (v) Start: 0.16 U/day Mean: 26 U/day T: Dinner D: 12 weeks Metformin (fix) Mean: about 2200 mg Range: 500 – 2550 mg T: 1–3 times/day D: 4 weeks run-in, then 12 weeks GP2: NPH insulin (v) Start: 0.16 U/day Mean: 28 U/day T: Bedtime D: 12 weeks Metformin (fix) Mean: about 2200 mg Range: 500 – 2550 mg T: 1–3 times/day D: 4 weeks run-in, then 12 weeks | GP1 F-B: 0.7 p: 0.251 overall GP2 F-B: 0.1 GP1–GP2: 1* | | | GP1 2 (4*) GP2 0 (0*) | Blurred vision and pain in the extremities GP1 1 (2*) GP2 0 (0*)
Insulin aspart 70/30 vs. oral antidiabetic agents
Bebakar, 2007 ^46^ | GP1: Insulin aspart 70/30 (v) Start: 0.2 U/kg/day Range: 0.16 U/kg (qd) – 0.43 U/kg (bid) T: Once or twice daily D: 24 weeks GP2: OA agents (v) T: NR D: 24 weeks | GP1 F-B: 0.98 p: < 0.005 vs. GP2 GP2 F-B: 0 GP1–GP2: 1* | | GP1 number of events: 5 GP2 number of events: 0 | GP1 6 (5*) GP2 0 (0*)
Kvapil, 2006 ^51^ | GP1: Insulin aspart 70/30 (v) Start: 0.3 U/kg/day Mean: 0.51 U/kg/day T: Breakfast, dinner D: 16 weeks GP2: Metformin (fix) Mean: 1660 mg Range: 500 – 3000 mg qd T: NR D: 16 weeks Glibenclamide (v) Start: 1.75 mg Mean: 2.33 (start), 6.58 mg (end) T: once or twice daily D: 16 weeks | GP1 F-B: 1.6 GP2 F-B: 0.1 GP1–GP2: 1.46 (SE 00.41) p: < 0.001 | | GP1 total events for all groups: 5 GP2 total events for all groups: 5 | GP1 1 (1*) GP2 0 (0*)
Kvapil, 2006 ^51^ | GP1: Insulin aspart 70/30 (v) Start: 0.2 U/kg/day Mean: 0.3 U/kg/day T: Breakfast, dinner D: 16 weeks Metformin (fix) Mean: 1660 mg daily Range: 500 – 3000 mg qd T: NR D: 16 weeks GP2: Metformin (fix) Mean: 1660 mg daily Range: 500 – 3000 mg qd T: NR D: 16 weeks Glibenclamide (v) Start: 1.75 mg Mean: 2.33 (start), 6.58 mg (end) T: once or twice daily D: 16 weeks | GP1 F-B: 0.8 GP2 F-B: 0.1 GP1–GP2: 0.66 (SE 0.41) p: NS | | GP1 total events for all groups: 5 GP2 total events for all groups: 5 | GP1 2 (2*) GP2 0 (0*)
Raz, 2003 ^57^ | GP1: Insulin aspart 70/30 (v) Start: 6–8 U bid T: Breakfast, dinner D: 6 weeks Rosiglitazone (fix) Start: 4 mg T: Breakfast D: 6 weeks GP2: Glibenclamide (fix) Range: 7.5 – 15 mg T: Dinner D: 6 weeks Rosiglitazone (fix) Start: 4 mg T: Breakfast D: 6 weeks | GP1 F-B: 0.23 p: NS vs. GP2 GP2 F-B: 0.03 GP1–GP2: 0* | | | GP1 0 (0*) GP2 0 (0*)
Raz, 2005 ^54^ | GP1: Insulin aspart 70/30 (v) Start: 0.3 U/kg/day Mean: 0.7 U/kg/day T: Breakfast, dinner D: 18 weeks GP2: Glibenclamide (v) Start: 5 to 10 mg Mean: 14 mg T: Breakfast D: 18 weeks Pioglitazone (fix) Start: 30 mg Mean: 30 mg T: Breakfast D: 18 weeks | GP1 F-B: 2.2 GP2 F-B: 2.2 GP1–GP2: 0* Experienced weight gain GP1 3* (3) p: < 0.05 overall GP2 2* (2) | | GP1 2 (2*) GP2 0 (0*) | GP1 3 (3*) GP2 2 (2*) | Cellulitis GP1 1 (1*) GP2 0 (0*) Peripheral edema GP1 0* (0) GP2 1* (1)
Raz, 2005 ^54^ | GP1: Insulin aspart 70/30 (v) Start: 0.2 U/kg/day Mean: 0.5 U/kg/day T: Breakfast, dinner D: 18 weeks Pioglitazone (fix) Start: 30 mg Mean: 30 mg T: Breakfast D: 18 weeks GP2: Glibenclamide (v) Start: 5 to 10 mg Mean: 14 mg T: Breakfast D: 18 weeks Pioglitazone (fix) Start: 30 mg Mean: 30 mg T: Breakfast D: 18 weeks | GP1 F-B: 4 GP2 F-B: 2.2 GP1–GP2: 2* Experienced weight gain GP1 7* (8) p: < 0.05 overall GP2 2* (2) | | GP1 0 (0*) GP2 0 (0*) | GP1 1 (1*) GP2 2 (2*) | Cellulitis GP1 0 (0*) GP2 0 (0*) Peripheral edema GP1 6* (6) GP2 1* (1)
Raskin, 2007 ^60^ | GP1: Insulin aspart 70/30 (v) Start: 6 U bid Mean: 0.6 U/kg/day T: Breakfast, dinner D: 34 weeks Metformin (fixed) Mean: 2446 mg T: NR D: 34 weeks Pioglitazone (fixed) Mean: 32.5 mg T: NR D: 34 weeks GP2: Metformin (fixed) Mean: 2439 mg T: NR D: Unclear Pioglitazone (fixed) Mean: 31.7 T: NR D: Unclear | | | | GP1 3 (2.9) GP2 4 (4.1) | Peripheral edema GP1 8* (9) GP2 11* (12)
Ushakova, 2007 ^59^ | GP1: Insulin aspart 70/30 (v) Start: 0.3 – 0.5 U/kg Mean: 55.5 U T: bid for 2 weeks, then tid D: 16 weeks GP2: Continuation of OA agents (v) T: NR D: 16 weeks | | | GP1 0 (0*) GP2 0 (0*) | GP1 1 (1*) GP2 1 (1*)
Ushakova, 2007 ^59^ | GP1: Insulin aspart 70/30 (v) Start: 0.3 – 0.5 U/kg Mean: 44.8 U T: Breakfast, dinner D: 16 weeks Metformin (v) Start: 500 mg qd or bid or 850 mg qd T: NR D: 14 weeks (started after 2 weeks) GP2: Continuation of OA agents (v) T: NR D: 16 weeks | | | GP1 0 (0*) GP2 0 (0*) | GP1 1 (1*) GP2 1 (1*)
Insulin aspart 70/30 vs. exenatide
Nauck, 2007 ^49^ | GP1: Insulin aspart 70/30 (v) Start: 15.7 U/day Mean: 24.4 U/day T: Breakfast, dinner D: 52 weeks ‘Optimally’ effective metformin and sulfonylurea (v) T: NR D: 52 weeks GP2: Exenatide (v) Start: 5 μg bid Range: 5 – 10 μg bid T: Breakfast D: 52 weeks ‘Optimally’ effective metformin and sulfonylurea therapy (v) T: NR D: 52 weeks | GP1 F-B: 2.9 p: < 0.001 GP2 F-B: -2.5 p: < 0.001 GP1–GP2: 5.4 (95% CI: 5 – 5.9) p: < 0.001 | | GP1 11 (4.4) GP2 19 (7.5) | GP1 0 (0*) GP2 20 (8*)
Insulin aspart 70/30 vs. insulin lispro 75/25
Hermansen, 2002 ^58^ | GP1: Insulin aspart 70/30 (fix) Start: 0.4 U/kg T: Breakfast D: 1 day GP2: Insulin lispro 75/25 (fix) Start: 0.4 U/kg T: Breakfast D: 1 day | | | | GP1 1 (2*) GP2 0 (0*) | GP1 number of events: 1 GP2 number of events: 0
Niskanen, 2004 ^55^ | GP1: Insulin aspart 70/30 (v) Mean: 0.65 to 0.67 U/kg T: Breakfast, dinner D: 12 weeks GP2: Insulin lispro 75/25 (v) Mean: 0.67 to 0.71 U/kg T: Breakfast, dinner D: 12 weeks | | GP1 1 (1*) GP2 2 (2*) | | GP1 1 (1*) GP2 1 (1*) | Resulted in death, life-threatening experience, inpatient hospitalization, persistent or significant disability/incapacity, or congenital anomaly/birth defect GP1 11 (8*) GP2 3 (2*)
Insulin aspart 70/30 vs. insulin aspart 70/30 + oral antidiabetic agents
Kvapil, 2006 ^51^ | GP1: Insulin aspart 70/30 (v) Start: 0.3 U/kg/day Mean: 0.51 U/kg/day T: Breakfast, dinner D: 16 weeks GP2: Insulin aspart 70/30 (v) Start: 0.2 U/kg/day Mean: 0.3 U/kg/day T: Breakfast, dinner D: 16 weeks Metformin (fix) Mean: 1660 mg daily Range: 500 – 3000 mg qd T: NR D: 16 weeks | GP1 F-B: 1.6 GP2 F-B: 0.8 GP1–GP2: 0.8 (SE 0.41) p: NS vs. GP2 | | GP1 total events for all groups: 5 GP2 total events for all groups: 5 | GP1 1 (1*) GP2 2 (2*)
Raz, 2005 ^54^ | GP1: Insulin aspart 70/30 (v) Start: 0.3 U/kg/day Mean: 0.7 U/kg/day T: Breakfast, dinner D: 18 weeks GP2: Insulin aspart 70/30 (v) Start: 0.2 U/kg/day Mean: 0.5 U/kg/day T: Breakfast, dinner D: 18 weeks Pioglitazone (fix) Start: 30 mg Mean: 30 mg T: Breakfast D: 18 weeks | GP1 F-B: 2.2 GP2 F-B: 4 GP1–GP2: -2* Experienced weight gain GP1 3* (3) p: < 0.05 overall GP2 7* (8) | | GP1 2 (2*) GP2 0 (0*) | GP1 3 (3*) GP2 1 (1*) | Cellulitis GP1 1 (1*) GP2 0 (0*) Peripheral edema GP1 0* (0) GP2 6* (6)
Ushakova, 2007 ^59^ | GP1: Insulin aspart 70/30 (v) Start: 0.3 – 0.5 U/kg Mean: 55.5 U T: bid for 2 weeks, then tid D: 16 weeks GP2: Insulin aspart 70/30 (v) Start: 0.3 – 0.5 U/kg Mean: 44.8 U T: Breakfast, dinner D: 16 weeks Metformin (varied) Start: 500 mg qd or bid or 850 mg qd T: NR D: 14 weeks (started after 2 weeks) | | | GP1 0 (0*) GP2 0 (0*) | GP1 1 (1*) GP2 1 (1*)
Insulin lispro 70/30 vs. rapid-acting insulin analogue with intermediate-acting human insulin
Hirao, 2008 ^61^ | GP1: Insulin aspart 70/30 (NR) T: bid D: 6 months GP2: Insulin aspart (NR) T: tid D: 6 months NPH insulin (NR) T: Optional multiple daily injections D: 6 months | GP1 B: 23.8 (4.1) p: NS F: 25.2 (4) p: < 0.0001 vs. baseline; NS vs. GP2 F-B: 1.47 (1.82) p: 0.013 vs. GP2 GP2 B: 24 (4.2) F: 24.8 (4.5) p: < 0.0001 vs. baseline F-B: 0.69 (1.04) GP1–GP2: 0*
Insulin lispro 75/25 vs. long-acting insulin analogues
Cox, 2007 ^74^ | GP1: Insulin lispro 75/25 (v) T: Breakfast, dinner D: 12 weeks Metformin (NR) T: NR D: 12 weeks GP2: Insulin glargine (v) T: Bedtime D: 12 weeks Metformin (NR) T: NR D: 12 weeks | | | | GP1 0 (0*) GP2 0 (0*)
Jacober, 2006 ^64^ | GP1: Insulin lispro 75/25 (v) Mean: 0.353 IU/kg; 36.73 IU T: Breakfast, lunch D: 4 months Insulin lispro 75/25 (v) T: Dinner D: 4 months Existing OA agents (NR) T: NR D: 4 months GP2: Insulin glargine (v) Mean: 0.276 IU/kg; 27.98 IU T: Bedtime D: 4 months Existing OA agents (NR) T: NR D: 4 months | GP1 B: 98* F: 99.7 (18.6) p: 0.9106 F-B: 1.98 (0.44) p: < 0.0001 vs. baseline GP2 B: 97* F: 99 (19.1) F-B: 1.52 (0.46) p: 0.0015 vs. baseline GP1–GP2: 0* p: 0.457 vs. GP2 | | | GP1 0 (0*) GP2 0 (0*)
Malone, 2004 ^65^ | GP1: Insulin lispro 75/25 (v) Mean: 0.62 U/kg T: Breakfast, dinner D: 16 weeks Metformin (NR) Mean: 1945 mg Range: 1500 – 2550 mg T: NR D: 16 weeks GP2: Insulin glargine (v) Mean: 0.57 U/kg T: Bedtime D: 16 weeks Metformin (NR) Mean: 1997 mg Range: 1500 – 2550 mg T: NR D: 16 weeks | GP1 B: 91* F: 93 (18.8) p: 0.006 F-B: 2.3 (4) p: 0.006 GP2 B: 91* F: 93.1 (19.3) F-B: 1.6 (4) GP1–GP2: 0* | | | GP1 0 (0*) GP2 1 (1*) | Required hospitalization GP1 4 (4*) GP2 1 (1*)
Malone, 2005 ^66^ | GP1: Insulin lispro 75/25 (v) Mean: 0.42 U/kg T: Breakfast, dinner D: 16 weeks Metformin (fix) Mean: 2128 mg Range: 1500 – 2550 mg T: NR D: 16 weeks GP2: Insulin glargine (v) Mean: 0.36 U/kg T: Bedtime D: 16 weeks Metformin (fix) Mean: 2146 mg Range: 1500 – 2550 mg T: NR D: 16 weeks | GP1 B: 77* F: 78.31 (15.13) p: 0.001 F-B: 0.82 (2.56) p: 0.001 vs. GP2 GP2 B: 77* F: 77.05 (14.38) F-B: 0.06 (2.49) GP1–GP2: 1* | | | GP1 1 (1*) GP2 0 (0*) | GP1 3 GP2 3
Roach, 2006 ^63^ | GP1: Insulin lispro 75/25 (v) Mean: 23 U (morning) and 37 U (evening) Range: 0 – 72 U (morning); 11 – 88 U (evening) T: Breakfast, dinner D: 12 weeks OA agents (NR) Start: Current dose T: NR D: 12 weeks Metformin (v) Start: 500 mg qd T: NR D: 12 weeks GP2: Insulin glargine (v) Mean: 44 U Range: 14 U – 100 U T: Breakfast D: 12 weeks OA agents (NR) Start: Current dose T: NR D: 12 weeks Metformin (v) Start: 500 mg qd T: NR D: 12 weeks | GP1 F: 103.9 (17.8) p: 0.068 GP2 F: 102.5 (17.9) | | | GP1 1 (3*) GP2 0 (0*)
Insulin lispro 75/25 vs. premixed human insulins
Coscelli, 2003 ^67^ | GP1: Insulin lispro 75/25 (v) Mean: 38.1 U/l Range: 12 – 72 U/l T: Breakfast, dinner D: 12 days Diet/exercise D: 12 days GP2: NPH/regular 70/30 (v) Mean: 37.3 U/l Range: 10 – 72 U/l T: Breakfast, dinner D: 12 days Diet/exercise D: 12 days | GP1 B: 79 (13.1) F: 79.4 (12.9) p: NS vs. baseline F-B: 0* GP2 B: 80.2 (11.8) F: 80.4 (12.8) p: NS vs. baseline F-B: 0* GP1–GP2: 0* | | | GP1 0 (0*) GP2 0 (0*) | GP1 1 GP2 2
Hermansen, 2002 ^58^ | GP1: Insulin lispro 75/25 (fix) Start: 0.4 U/kg T: Breakfast D: 1 day GP2: NPH/regular 70/30 (fix) Start: 0.4 U/kg T: Breakfast D: 1 day | | | | GP1 0 (0*) GP2 0 (0*) | GP1 number of events: 0 GP2 number of events: 0
Herz, 2002 ^71^ | GP1: Insulin lispro 75/25 (v) Mean: 26.1 U T: Breakfast, dinner D: 4 weeks GP2: NPH/regular 70/30 (v) Mean: 26.2 U T: Breakfast, dinner D: 4 weeks | | | | GP1 0 (0*) GP2 0 (0*)
Herz, 2003 ^12^ | GP1: Insulin lispro 75/25 (v) Mean: Mean: 31.6 (morning) and 26.8 U (evening) and 32.4 (morning) and 27.6 U (evening) T: Breakfast, dinner D: 4 weeks GP2: NPH/regular 70/30 (v) Mean: 32.3 (morning) and 26.4 U (evening) and 33.3 (morning) and 27.5 U (evening) T: Breakfast, dinner D: 4 weeks | | | | GP1 0 (0*) GP2 0 (0*)
Malone, 2000 ^44^ | GP1: Insulin lispro 75/25 (fix) Mean: 35.4 U (0.43 U/kg) T: Breakfast D: 2 days GP2: NPH/regular 70/30 (fix) Mean: 35.4 U (0.43 U/kg) T: Breakfast D: 2 days | | | | GP1 0 (0*) GP2 0 (0*)
Mattoo, 2003 ^70^ | GP1: Insulin lispro 75/25 (NR) Mean: 20 U (morning), 32 U (evening) T: Breakfast, dinner D: 2 weeks GP2: NPH/regular 70/30 (NR) Mean: 20 U (morning), 32 U (evening) T: Breakfast, dinner D: 2 weeks | GP1 p: NS vs. baseline for all patients | | | GP1 0 (0*) GP2 0 (0*)
Roach, 1999 ^73^ | GP1: Insulin lispro 75/25 (v) Mean: 0.37 (morning), 0.28 U/kg (evening) T: Breakfast, dinner D: 13 weeks GP2: NPH/regular 70/30 (v) Mean: 0.36 (morning), 0.27 U/kg (evening) T: Breakfast, dinner D: 13 weeks | GP1 p: NS vs. GP2 | | | GP1 0 (0*) GP2 0 (0*)
Schwartz, 2006 ^62^ | GP1: Insulin lispro 75/25 (fix) Start: 2/3 of usual daily dose Mean: 44.1 U T: Breakfast D: 1 day GP2: NPH/regular 70/30 (fix) Start: 2/3 of usual daily dose Mean: 44.1 U T: Breakfast D: 1 day | | GP1 1 (5*) GP2 0 (0*) | GP1 0 (0*) GP2 0 (0*) | GP1 0 (0*) GP2 0 (0*)
Insulin lispro 75/25 vs. oral antidiabetic agents
Herz, 2002 ^72^ | GP1: Insulin lispro 75/25 (v) Start: 0.3 – 0.5 U/kg Mean: 0.46 U/kg T: Breakfast, dinner D: 16 weeks GP2: Glyburide (fix) Start: 15 mg/day T: Breakfast, dinner D: 16 weeks | GP1 B: 78.65 (SE 1.36) p: 0.519 vs GP2 F: 79.7 (SE 1.47) p: 0.151 vs GP2 F-B: 1.02 (SE 0.35) p: < 0.001 vs GP2 GP2 B: 77.34 (SE 1.53) F: 76.61 (SE 1.55) F-B: -0.85 (SE 0.18) GP1–GP2: 2* | | | GP1 2 (3*) GP2 1 (1*) | Liver carcinoma GP1 1 (1*) GP2 0 (0*)
Malone, 2003 ^68^ | GP1: Insulin lispro 75/25 (v) Mean: 0.19 (morning), 0.14 U/kg (evening) T: Breakfast, dinner D: 16 weeks Metformin (v) Mean: 1813 mg/day Range: 1500 – 2550 mg/day T: 2 to 3 times/day D: 16 weeks GP2: Metformin (v) Mean: 1968 mg/day Range: 1500 – 2550 mg/day T: 2 to 3 times/day D: 16 weeks Glibenclamide (v) Mean: 14.2 mg/day T: NR D: 16 weeks | GP1 B: 83 (15.2) F: 84 (15.1) F-B: 1* GP2 B: 81.7 (15.7) F: 82.2 (15.4) F-B: 0* GP1–GP2: 1* p: 0.33 | | | GP1 1 (0*) GP2 2 (1*) | Treatment-emergent adverse events GP1 number of events: 7 GP2 number of events: 5
Tirgoviste, 2003 ^43^ | GP1: Insulin lispro 75/25 (v) Start: 0.3 – 0.5 U/kg T: Breakfast, dinner D: 16 weeks GP2: Glibenclamide (v) Start: 15 mg T: Breakfast, dinner D: 16 weeks | GP1 F-B: 1.32 (2.4) p: < 0.001 GP2 F-B: -0.7 (2.6) GP1–GP2: 2*
Insulin lispro 75/25 vs. insulin lispro 50/50
Schwartz, 2006 ^62^ | GP1: Insulin lispro 75/25 (fix) Start: 2/3 of usual daily dose Mean: 44.1 U T: Breakfast D: 1 day GP2: Insulin lispro 50/50 (fix) Start: 2/3 of usual daily dose Mean: 43.8 U T: Breakfast D: 1 day | | GP1 1 (5*) GP2 1 (4*) | NR GP1 0 (0*) GP2 0 (0*) | GP1 0 (0*) GP2 0 (0*)
Insulin lispro 50/50 vs. long-acting insulin analogues
Kazda, 2006 ^76^ | GP1: Insulin lispro 50/50 (v) Start: 0.30 IU/kg/day—mean Mean: 0.59 IU/kg/day T: Breakfast, lunch, dinner D: 24 weeks GP2: Insulin glargine (v) Start: 0.16 IU/kg/day—mean Mean: 0.43 IU/kg/day T: Bedtime D: 24 weeks | GP1 F-B: 1.8 (3.4) GP2 F-B: 0.7 (3.8) GP1–GP2: 1* BMI (in kg/m2) GP1 F-B: 0.6 (1.1) p: 0.19 vs GP2 GP2 F-B: 0.2 (1.3) GP1–GP2: 1* | | | GP1 0 (0*) GP2 0 (0*)
Robbins, 2007 ^79^ | GP1: Insulin lispro 50/50 (v) Mean: 0.7 U/kg T: Breakfast, lunch, dinner D: 24 weeks Metformin (fixed) Mean: 1641 mg T: bid D: 24 weeks GP2: Insulin glargine (v) Mean: 0.6 U/kg T: Bedtime D: 24 weeks Metformin (fixed) Mean: 1636 mg T: bid D: 24 weeks | GP1 B: 89.1 (20.4) F: 90 (20.5) p: < 0.001 vs. GP2 F-B: 1.2 (3.2) p: < 0.001 vs. GP2 GP2 B: 88.1 (19) F: 87.6 (19.3) F-B: -0.5 (2.8) GP1–GP2: 1* | | GP1 N and % of events: 11 (7%) p: NS GP2 N and % of events: 5 (3.2%) | GP1 5 (3.2) GP2 1 (0.6)
Insulin lispro 50/50 vs. rapid-acting insulin analogues
Kazda, 2006 ^76^ | GP1: Insulin lispro 50/50 (v) Start: 0.30 IU/kg/day—mean Mean: 0.59 IU/kg/day T: Breakfast, lunch, dinner D: 24 weeks GP2: Insulin lispro (v) Start: 0.25 IU/kg/day-mean Mean: 0.50 IU/kg/day T: Breakfast, lunch, dinner D: 24 weeks | GP1 F-B: 1.8 (3.4) GP2 F-B: 2.3 (4.3) GP1–GP2: 0* BMI (in kg/m2) GP1 F-B: 0.6 (1.1) GP2 F-B: 0.9 (1.5) GP1–GP2: 0* | | | GP1 0 (0*) GP2 0 (0*)
Insulin lispro 50/50 vs. rapid-acting with long-acting insulin analogues
Rosenstock, 2008 ^80^ | GP1: Insulin lispro 50/50 (v) Start: Insulin glargine dose at entry (52.5 U) Mean: 123 U T: Breakfast, lunch, dinner D: 24 weeks Insulin lispro 75/25 (v) Start: Allowed to switch evening dose to insulin lispro 75/25 T: Dinner D: Unclear GP2: Insulin glargine (v) Start: 50% of insulin glargine dose at entry (54.9 U) Mean: 70 U T: Bedtime D: 24 weeks Insulin lispro (v) Start: 50% of insulin glargine dose at entry divided in 3 equal doses (54.9 U) Mean: 76 U T: Breakfast, Lunch, dinner D: 24 weeks | | | GP1 6 (3.2) number of events: 9 p: 0.600 for incidence GP2 9 (4.8) number of events: 13
Insulin lispro 50/50 vs. premixed human insulins
Roach, 1999 ^10^ | GP1: Insulin lispro 50/50 (v) Mean: 0.31 U/kg T: Breakfast D: 3 months Insulin lispro 75/25 (v) Mean: 0.26 U/kg T: Dinner D: 3 months GP2: NPH/regular 50/50 (v) Mean: 0.32 U/kg T: Breakfast D: 3 months NPH/regular 70/30 (v) Mean: 0.26 U/kg T: Dinner D: 3 months | GP1 p: NS vs. GP2 | | | GP1 0 (0*) GP2 0 (0*)
Schernthaner, 2004 ^77^ | GP1: Insulin lispro 50/50 (v) Mean: 64.6 IU T: Breakfast, lunch, dinner D: 12 weeks Diet/exercise D: 12 weeks GP2: NPH/regular 70/30 (v) Mean: 61.8 IU T: Breakfast, dinner D: 12 weeks Diet/exercise D: 12 weeks | | | | GP1 0 (0*) GP2 0 (0*) | GP1 0 (0*) GP2 5 (12*)
Schwartz, 2006 ^62^ | GP1: Insulin lispro 50/50 (fix) Start: 2/3 of usual daily dose Mean: 43.8 U T: Breakfast D: 1 day GP2: NPH/regular 70/30 (fix) Start: 2/3 of usual daily dose Mean: 44.1 U T: Breakfast D: 1 day | | GP1 1 (4*) GP2 0 (0*) | NR GP1 0 (0*) GP2 0 (0*) | GP1 0 (0*) GP2 0 (0*)
Yamada, 2007 ^78^ | GP1: Insulin lispro 50/50 (v) Start: current dose Mean: 0.37 (start), 0.38 U/kg (end) T: bid D: 4 months GP2: NPH/regular 70/30 (v) Start: current dose Mean: 0.34 (start), 0.37 U/kg (end) T: bid D: 4 months NPH/regular 50/50 (v) Start: current dose Mean: 0.34 (start), 0.37 U/kg (end) T: bid D: 4 months | BMI (in kg/m2) GP1 B: 27 (5.8) F: 27.3 (5.9) F-B: 0* p: NS vs. baseline GP2 B: 23.8 (3.4) F: 23.6 (3.6) F-B: 0* p: NS vs. baseline GP1–GP2: 0* p: NS vs. baseline | | | GP1 0 (0*) GP2 0 (0*)

* Number has been imputed.

‖ Among those who were not using thiazolidinediones.

‡ One-hundred and four (36%) of the 291 participants of this trial are patients with type 1 diabetes. The remaining population has type 2 diabetes and is the same study population as Boehm 2004. ^45^ Only data for the Boehm 2004 study is presented because it has the longest followup.

¶ Dosing during the outpatient phase.

§ Dosing during the inpatient phase.

μg = microgram; B = baseline; bid = twice daily; BMI = body mass index; Cl = confidence interval; D = duration; F = final; F-B = mean difference from baseline; GP = group; GP1–GP2 = mean difference between the difference from baseline; IU = international unit; kg = kilogram; kg/m2 = kilogram per square meter; mg = milligram; ml = milliliter; NA = not applicable; NPH = neutral protamine Hagedorn; NR = not reported; NS = not significant; OA = oral antidiabetic; p = p-value; qd = once daily; SD = standard deviation; SE = standard error; T = time of day when insulin taken; tid = thrice daily; U = unit; U/l = units per liter; v = dosing varied

Table 7 Quality of studies comparing a premixed insulin analogue to other diabetes treatments

Author, year | Clear quest | Rand# / Rand app# | Comp gp* / Exp asc* / Out not present* | Blind | Out assess | FU long enough | Lost to FU / Desc of WD | Conc | Fund / COI | Overall quality†
Abrahamian, 2005 ^53^ | Yes | Yes / NR | NA | No | Indep blind | Yes | < 10% / No | Partially | Pharmaceutical / Yes | Fair
Bebakar, 2007 ^46^ | Yes | Yes / NR | NA | No | Indep blind | Yes | < 10% / Yes | Yes | Pharmaceutical / NR | Good
Boehm, 2004 ^45^ Boehm, 2002 ^9^ | Yes | Yes / Yes | NA | Outcome assessors | Indep blind, self report | Yes | < 10% / Yes | Yes | Pharmaceutical / Yes | Good
Christiansen, 2003 ^13^ | No | Yes / NR | NA | Patients, providers | Indep blind | Yes | < 10% / Yes | Partially | Pharmaceutical / Yes | Fair
Coscelli, 2003 ^67^ | Yes | Yes / NR | NA | No | Indep blind | Yes | NR / No | Yes | Pharmaceutical / NR | Fair
Cox, 2007 ^74^ | Yes | Yes / NR | NA | No | Indep blind, self report | Yes | > 10% / No | Yes | Pharmaceutical / NR | Fair
Hermansen, 2002 ^58^ | Yes | Yes / Yes | NA | No | Indep blind | No | < 10% / Yes | Yes | Pharmaceutical / NR | Fair
Herz, 2002 ^71^ | Yes | Yes / NR | NA | No | Indep blind | Yes | < 10% / Yes | Yes | NR / NR | Fair
Herz, 2002 ^72^ | Yes | Yes / NR | NA | No | Indep blind, self report | Yes | < 10% / Yes | Partially | Pharmaceutical / Yes | Poor
Herz, 2003 ^12^ | Yes | Yes / NR | NA | No | Indep blind | Yes | > 10% / No | Yes | Pharmaceutical / NR | Fair
Hirao, 2008 ^61^ | Yes | Yes / NR | NA | No | Indep blind | Yes | > 10% / Yes | Yes | Non-pharmaceutical / No | Fair
Holman, 2007 ^32^ | Yes | Yes / Yes | NA | Outcome assessors | Indep blind, self report | Yes | < 10% / Yes | Yes | Pharmaceutical / Yes | Good
Jacober, 2006 ^64^ | Yes | Yes / NR | NA | No | Indep blind, self report | Yes | > 10% / Yes | Partially | Pharmaceutical / NR | Fair
Joshi, 2005 ^52^ | No | NA | Drawn from same community / other / NA | No | Indep blind | Yes | Complete FU / Yes | Partially | Pharmaceutical / Yes | Poor
Kann, 2006 ^50^ | Yes | Yes / Yes | NA | No | Indep blind | Yes | < 10% / Yes | Yes | Pharmaceutical / Yes | Good
Kapitza, 2004 ^56^ | Yes | Yes / NR | NA | No | Indep blind | No | Complete FU / No | Yes | Pharmaceutical / NR | Fair
Kazda, 2006 ^76^ | Yes | Yes / NR | NA | No | Indep blind, self report | Yes | < 10% / Yes | Yes | Pharmaceutical / Yes | Good
Kilo, 2003 ^15^ | Yes | Yes / NR | NA | No | Indep blind, self report | Yes | < 10% / Yes | Yes | Pharmaceutical / NR | Good
Kvapil, 2006 ^51^ | Yes | Yes / Yes | NA | No | Indep blind | Yes | < 10% / Yes | Yes | Pharmaceutical / NR | Good
Ligthelm, 2006 ^83^ | Yes | Yes / Yes | NA | No | Indep blind, self report | Yes | < 10% / Yes | Yes | Pharmaceutical / NR | Good
Malone, 2000 ^44^ Malone, 2000 ^14^ | Yes | Yes / NR | NA | Patients, providers | Indep blind | No | < 10% / Yes | Yes | NR / NR | Fair
Malone, 2003 ^68^ | Yes | Yes / NR | NA | No | Indep blind, self report | Yes | Complete FU / Yes | Yes | Pharmaceutical / NR | Good
Malone, 2004 ^65^ | Yes | Yes / Yes | NA | No | Indep blind, self report | Yes | < 10% / Yes | Yes | NR / NR | Poor
Malone, 2005 ^66^ | Yes | Yes / NR | NA | No | Indep blind, self report | Yes | < 10% / Yes | Yes | NR / Yes | Fair
Mattoo, 2003 ^70^ | Yes | Yes / NR | NA | No | Indep blind, self report | Yes | < 10% / No | Yes | Pharmaceutical / NR | Fair
McNally, 2007 ^48^ | Yes | Yes / Yes | NA | Patients, providers | Indep blind, self report | Yes | < 10% / Yes | Yes | NR / Yes | Good
McSorley, 2002 ^11^ | Yes | Yes / NR | NA | Patients, providers | Indep blind | Yes | NR / No | Yes | Pharmaceutical / NR | Fair
Nauck, 2007 ^49^ | Yes | Yes / Yes | NA | No | Indep blind | Yes | < 10% / Yes | Yes | Pharmaceutical / Yes | Good
Niskanen, 2004 ^55^ | Yes | Yes / Yes | NA | No | Indep blind, self report | Yes | < 10% / Yes | Yes | Pharmaceutical / NR | Good
Raskin, 2005 ^39^ Raskin, 2007 ^40^ Brod, 2007 ^41^ | Yes | Yes / Yes | NA | No | Indep blind | Yes | < 10% / Yes | Yes | Pharmaceutical / Yes | Good
Raskin, 2007 ^60^ | No | Yes / NR | NA | No | Indep blind | Yes | < 10% / Yes | Yes | NR / No | Fair
Raz, 2003 ^57^ | Yes | Yes / Yes | NA | No | Indep blind, medical record review, self report | No | < 10% / Yes | Yes | Pharmaceutical / NR | Fair
Raz, 2005 ^54^ | Yes | Yes / NR | NA | No | Indep blind | Yes | > 10% / Yes | Yes | Pharmaceutical / Yes | Fair
Roach, 1999 ^73^ | Yes | Yes / NR | NA | No | Indep blind, self report | Yes | < 10% / Yes | Yes | Pharmaceutical / Yes | Fair
Roach, 1999 ^10^ | Yes | Yes / NR | NA | No | Indep blind | Yes | Complete FU / Yes | Yes | Pharmaceutical / NR | Fair
Roach, 2003 ^69^ | Yes | Yes / NR | NA | Patients, providers | Indep blind | No | < 10% / Yes | Yes | Pharmaceutical / NR | Good
Roach, 2006 ^63^ | Yes | Yes / NR | NA | No | Indep blind | Yes | > 10% / Yes | Yes | Pharmaceutical / Yes | Fair
Robbins, 2007 ^79^ | Yes | Yes / Yes | NA | No | Indep blind | Yes | < 10% / Yes | Yes | Pharmaceutical / Yes | Good
Schernthaner, 2004 ^77^ | Yes | Yes / NR | NA | No | Indep blind | Yes | < 10% / Yes | Yes | Pharmaceutical / NR | Fair
Rosenstock, 2008 ^80^ | Yes | Yes / Yes | NA | No | Indep blind | Yes | > 10% / Yes | Yes | Pharmaceutical / Yes | Good
Schwartz, 2006 ^62^ | Yes | Yes / NR | NA | Patients, providers | Indep blind | No | < 10% / Yes | Yes | Pharmaceutical / Yes | Fair
Tamemoto, 2007 ^47^ | Yes | Yes / No | NA | No | No description | Yes | < 10% / Yes | Yes | NR / NR | Poor
Tirgoviste, 2003 ^43^ Roach, 2001 ^42^ | Yes | Yes / Yes | NA | No | Indep blind, self report | Yes | Complete FU / Yes | Yes | NR / NR | Good
Sun, 2007 ^75^ | Yes | NA | Drawn from the same community / secure record / NA | No | Medical record review | Yes | > 10% / No | Yes | Pharmaceutical / Yes | Fair
Ushakova, 2007 ^59^ | Yes | Yes / Yes | NA | No | Indep blind | Yes | < 10% / Yes | Yes | Pharmaceutical / No | Good
Yamada, 2007 ^78^ | Yes | Yes / Yes | NA | No | Indep blind | Yes | NR / No | Partially | NR / NR | Fair

# Questions only rated for trials.

* Questions only rated for non-randomized studies.

† Overall quality ratings were good, fair, or poor, which were defined as:

- Good (low risk of bias). These studies have the least bias and results are considered valid. A study that adheres mostly to the commonly held concepts of high quality including the following: a formal randomized controlled study; clear description of the population, setting, interventions, and comparison groups; appropriate measurement of outcomes; appropriate statistical and analytic methods and reporting; no reporting errors; low dropout rate; and clear reporting of dropouts.
- Fair. These studies are susceptible to some bias, but it is not sufficient to invalidate the results. They do not meet all the criteria required for a rating of good quality because they have some deficiencies, but no flaw is likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems.
- Poor (high risk of bias). These studies have significant flaws that imply biases of various types that may invalidate the results. They have serious errors in design, analysis or reporting; large amounts of missing information; or discrepancies in reporting.

Blind = blinding; Clear quest = clearly stated study questions or objectives; COI = conflict of interest; Comp gp = selection of comparison group; Conc = conclusions reflective of results; Desc of WD = description of withdrawals; Exp asc = ascertainment of exposure; FU = followup; Fund = funding source; Indep blind = independent blind assessment; NA = not applicable; NR = not reported; Out assess = outcome assessment; Out not present = demonstration that outcome was not present at study start; Rand = randomized; Rand app = randomization scheme appropriate

Table 8 Applicability of studies comparing a premixed insulin analogue to other diabetes treatments

Author, year | Pop source / % enrolled / Run-in periods excluding >10% | Demographically representative | Illness severity representative | Dose, schedule, or route of administration reflective of current practice | Interventions or monitoring reflective of current practice | Comparison best alternative / Adequate dose, interval, schedule | Clinical outcomes measured / adverse events reported | Standards of care different from US
Abrahamian, 2005 ^53^ | NR / ≥50% / No | Sex: Yes Age: Yes Race/ethnicity: No: assumed mostly Caucasian | Yes | Yes for only 2 of the 3 | No: monitoring of blood glucose occurred 7 times/day | Yes / Yes | No / No | No
Bebakar, 2007 ^46^ | NR / ≥50% / Yes | Sex: Yes Age: NR Race/ethnicity: No: Western Pacific countries | No: insulin naive | Yes for all 3 | Yes | Yes / NR | Yes / No | Yes
Boehm, 2004 ^45^ Boehm, 2002 ^9^ | NR / ≥50% / No | Sex: Yes Age: Yes Race/ethnicity: NR | Yes | Yes for all 3 | Yes | Yes / Yes | Yes / Yes | No
Christiansen, 2003 ^13^ | NR / NR / No | Sex: Yes Age: Yes Race/ethnicity: No: different from US racial and ethnic make-up | Yes | Yes for all 3 | No: monitoring too frequent | Yes / Yes | No / Yes | Yes
Coscelli, 2003 ^67^ | Subspecialty clinics / NR / No | Sex: Yes Age: Yes Race/ethnicity: No: 100% Caucasian | No: excluded patients with diabetic complications; must have been taking insulin; average duration of diabetes was 14 years | Yes for all 3 | Yes | Yes / Yes | No / Yes | No
Cox, 2007 ^74^ | NR / ≥50% / NA | Sex: NR Age: Yes Race/ethnicity: No: | No: no early diabetics | Yes for all 3 | NA | Yes / Yes | No / Adverse outcomes not reported | No
Hermansen, 2002 ^58^ | NR / ≥50% / NA | Sex: Yes Age: Yes Race/ethnicity: NR | No: subjects needed to have been on insulin and insulin dose < 1.4 U/kg, excluded those with diabetes complications | Yes for all 3 | No: patients were given a single dose of insulin and a standard meal and then monitored for 5 hours afterwards | Yes / Yes | No / Yes | No
Herz, 2002 ^71^ | NR / NR / No | Sex: Yes Age: Yes Race/ethnicity: NR | No: all participants were currently taking insulin | Yes for all 3 | No: patients were hospitalized for a few days while they performed an exercise test | Yes / Yes | No / Yes | No
Herz, 2002 ^72^ | Subspecialty clinics / ≥50% / No | Sex: Yes Age: No: subjects 60 to 80 years old Race/ethnicity: NR | No: excluded those with new diagnosis of type 2 diabetes | Yes for all 3 | Yes | No: compared to glyburide when patients were already on maximum dose of glyburide / Yes | No / No | No
Herz, 2003 ^12^ | NR / NR / No | Sex: Yes Age: Yes Race/ethnicity: NR | No: all respondents have been taking insulins, none were currently taking an OA agent | Yes for all 3 | No: investigators telephoned patients at least once weekly | Yes / Yes | No / Yes | No
Hirao, 2008 ^61^ | Clinics and hospitals affiliated with JDDM / NR / NA | Sex: Yes Age: NR Race/ethnicity: No: Japanese study | Yes | Yes for all 3 | Yes | Yes / Yes | Yes / Yes | Yes
Holman, 2007 ^32^ | Clinical centers / ≥50% / NA | Sex: Yes Age: Yes Race/ethnicity: No: over 90% Caucasian | No: patients were insulin naive | Yes for all 3 | Yes | Yes / Yes | No / Yes | No
Jacober, 2006 ^64^ | NR / ≥50% / NA | Sex: Yes Age: Yes Race/ethnicity: No: study contained more Caucasians and fewer African Americans and Mexican Americans | No: study likely excluded newly diagnosed and those with comorbidities | Yes for all 3 | Yes | Yes / Yes | No / Yes | No
Joshi, 2005 ^52^ | Outpatient clinics, subspecialty clinics / ≥50% / NA | Sex: No: 67 to 77% male per group Age: Yes Race/ethnicity: No: all from India | Yes | Yes for all 3 | Yes | Yes / Yes | No / Yes | No
Kann, 2006 ^50^ | NR / NR / No | Sex: Yes Age: NR Race/ethnicity: NR | No: male and female insulin-naive patients | Yes for all 3 | Yes | Yes / Yes | Yes / Yes | Yes
Kapitza, 2004 ^56^ | NR / NR / NA | Sex: Yes Age: Yes Race/ethnicity: NR | No: participants had to have been on insulin for at least 6 months | Yes for only 1 of the 3 | NA | Yes / Yes | No / Adverse outcomes not reported | No
Kazda, 2006 ^76^ | NR / ≥50% / No | Sex: Yes Age: Yes Race/ethnicity: No: assumed mostly Caucasian | No: included those who have a longer duration of diabetes | Yes for all 3 | Yes | No: would usually add glargine to OA agents as opposed to give it alone / Yes | No / Yes | No
Kilo, 2003 ^15^ | NR / ≥50% / No | Sex: Yes Age: Yes Race/ethnicity: Yes | Yes | Yes for all 3 | No: 8-point glucose profile measurement is not used in clinical practice | Yes / Yes | No / Yes | No
Kvapil, 2006 ^51^ | NR / ≥50% / No | Sex: Yes Age: Yes Race/ethnicity: No: assumed mostly Caucasian | No: treatment naive patients not included | Yes for all 3 | Yes | Yes / Yes | No / Yes | No
Ligthelm, 2006 ^83^ | NR / ≥50% / No | Sex: Yes Age: Yes Race/ethnicity: No: predominantly Caucasian with an Asian minority | No: only patients who previously used insulin | Yes for all 3 | No: interventions and monitoring likely too frequent | No: better alternatives are available / Yes | No / Yes | No
Malone, 2000 ^44^ Malone, 2000 ^14^ | NR / NR / No | Sex: Yes Age: Yes Race/ethnicity: NR | No: all patients needed to be on insulin | Yes for all 3 | No: patients were monitored in house and had frequent blood glucose measurements | Yes / Yes | No / Yes | No
Malone, 2003 ^68^ | NR / ≥50% / No | Sex: Yes Age: NR Race/ethnicity: No: 90% Caucasian, 2% African American, 7% Hispanic | No | Yes for all 3 | No: there was intense titration of dosing and patient visits every 4 weeks for 16 weeks | Yes / Yes | No / Yes | No
Malone, 2004 ^65^ | NR / ≥50% / No | Sex: Yes Age: Yes Race/ethnicity: NR | No: patients were insulin naive and had to be poorly controlled on an OA agent for at least 30 days | Yes for all 3 | Yes | Yes / Yes | No / Yes | No
Malone, 2005 ^66^ | NR / NR / Yes | Sex: Yes Age: Yes Race/ethnicity: NR | No: all had previously taken insulin | Yes for all 3 | Yes | Yes / Yes | No / Yes | No
Mattoo, 2003 ^70^ | NR / NR / No | Sex: Yes Age: Yes Race/ethnicity: NR | No: participants had to be taking insulin for at least 6 months | Yes for only 1 of the 3 | Yes | Yes / Yes | No / Yes | No
McNally, 2007 ^48^ | NR / ≥50% / No | Sex: Yes Age: No: mean age of population is 62 with a standard deviation of 9 years. Study is unlikely capturing the younger (<44 years) diabetic population Race/ethnicity: NR | No: all respondents have been pretreated on insulin for at least 6 months | Yes for all 3 | Yes | Yes / Yes | No / No | No
McSorley, 2002 ^11^ | NR / NR / No | Sex: Yes Age: Yes Race/ethnicity: NR | No: participants had to be diagnosed with diabetes for at least 1 year | Yes for all 3 | No: there was a sampling period where standard meals were provided for the participants | Yes / Yes | No / Yes | No
Nauck, 2007 ^49^ | Outpatient clinics / ≥50% / No | Sex: Yes Age: Yes Race/ethnicity: NR | No: suboptimal blood sugar control | Yes for all 3 | Yes | No: comparator is a new drug that is not being used often / Yes | Yes / Yes | Yes
Niskanen, 2004 ^55^ | NR / ≥50% / No | Sex: Yes Age: Yes Race/ethnicity: NR | No: included only patients who had been receiving insulin | Yes for all 3 | Yes | Yes / Yes | No / Yes | No
Raskin, 2005 ^39^ Raskin, 2007 ^40^ Brod, 2007 ^41^ | NR / NR / Yes | Sex: Yes Age: NR Race/ethnicity: Yes | No: insulin naive patients | Yes for all 3 | Yes | Yes / Yes | No / Yes | No
Raskin, 2007 ^60^ | NR / >=50% / Yes | Sex: Yes Age: Yes Race/ethnicity: Yes | No: insulin naive patients were enrolled | Yes for all 3 | Yes | No: comaprison is placebo, technically / No: comparison is technically placebo | No / Yes | No
Raz, 2003 ^57^ | Outpatient clinics / NR / No | Sex: Yes Age: Yes Race/ethnicity: No: 82% Caucasian | No: insulin naive patients | Yes for all 3 | Yes | No / No: insulin dose was adjusted while gliben-clamide and rosiglitazone doses were not adjusted | No / Yes | No
Raz, 2005 ^54^ | NR / ≥50% / No | Sex: Yes Age: Yes Race/ethnicity: NR | No: excluded those with serious complications or disease | Yes for all 3 | Yes | Yes / Yes | No / Yes | No
Roach, 1999 ^73^ | NR / NR / No | Sex: Yes Age: Yes Race/ethnicity: NR | No: excluded those not taking insulin and those with diabetic complications | Yes for all 3 | Yes | Yes / Yes | No / Yes | No
Roach, 1999 ^10^ | NR / NR / No | Sex: Yes Age: Yes Race/ethnicity: NR | No: participants must have been on insulin and could not have had any diabetes complications | Yes for all 3 | Yes | Yes / Yes | No / Yes | No
Roach, 2003 ^69^ | NR / NR / No | Sex: Yes Age: Yes Race/ethnicity: No: 100% Western Asian (Indian) | No: all had to have been taking insulin; excluded respondents taking OA agents | Yes for all 3 | Yes | Yes / Yes | No / Yes | Yes
Roach, 2006 ^63^ | NR / NR / No | Sex: Yes Age: Yes Race/ethnicity: No: 80% Caucasian and 20% African American; no Hispanics were included | No: needed to be on an OA agent or insulin for at least 3 months | Yes for all 3 | Yes | Yes / Yes | No / Yes | No
Robbins, 2007 ^79^ | NR / >=50% / No | Sex: Yes Age: Yes Race/ethnicity: No: only 6% African American and 22% were Asian but rest were representative (i.e. Caucasian and Hispanic numbers representative) | No: did not include those with renal or liver complications | Yes for all 3 | Yes | Yes / Yes | No / Yes | No
Rosenstock, 2008 ^80^ | NR / >=50% / NA | Sex: Yes Age: NR Race/ethnicity: Yes | No: only those already receiving insulin | Yes for all 3 | No: blood glucose was checked much more often: patients met with physicians much more often | Yes / Yes | No / Yes | No
Schernthaner, 2004 ^77^ | NR / NR / No | Sex: No: there were fewer males (23%) enrolled in the study Age: No: average age is 67 with standard deviation of 8.4 years. Unlikely capturing younger diabetics (e.g., <50 years of age) Race/ethnicity: NR | No: excluded respondents with severe diabetic complications; average time on insulin was over 5 years | Yes for all 3 | Yes | Yes / Yes | No / Yes | No
Schwartz, 2006 ^62^ | Subspecialty clinics / ≥50% / NA | Sex: No: 74% of the population was male Age: No: mean age of the population was 61 with a standard deviation of 10; study unlikely captured younger diabetics Race/ethnicity: No: the study population had fewer blacks and more Hispanics | No: only diabetics already on insulin were enrolled | No for all three | NA | Yes / Yes | No / No | Yes
Sun, 2007 ^75^ | NR / NR / NA | Sex: Yes Age: Yes Race/ethnicity: Yes | No: insulin naive | Yes for all 3 | Yes | Yes / Yes | No / Adverse outcomes not reported | No
Tamemoto, 2007 ^47^ | Outpatient clinics / NR / No | Sex: Yes Age: Yes Race/ethnicity: No: assumed 100% Japanese | No: had diabetes for at least 1 year | Yes for all 3 | Yes | Yes / Yes | No / Yes | No
Tirgoviste, 2003 ^43^ Roach, 2001 ^42^ | NR / NR / No | Sex: Yes Age: NR Race/ethnicity: NR | No: only patients needing 1 OA agent | Yes for all 3 | No: there were 5 visits in 12 weeks. Dose adjustments for insulin were made every 2–3 days. | No: OA agent dose could not increase / No: could not increase the OA agent dose | No / Yes | Yes
Ushakova, 2007 ^59^ | NR / >=50% / NR | Sex: No: majority of respondents were female Age: Yes Race/ethnicity: No: likely majority Caucasian | No: those treated with insulin or with diabetes-related complications were excluded | Yes for all 3 | Yes | Yes / Yes | No / Yes | Yes
Yamada, 2007 ^78^ | NR / NR / NA | Sex: No: mostly male Age: Yes Race/ethnicity: No: assumed mostly Japanese | No: excluded insulin naive patients and those with severe comorbidity | Yes for all 3 | Yes | Yes / Yes | No / Yes | No

kg = kilogram; NA = not applicable; NR = not reported; OA = oral antidiabetic; Pop source = population source; U = units; US = United States

Table 9 Comparative effectiveness of premixed insulin analogues and other diabetes treatments on clinical outcomes

Author, year | Intervention | Overall mortality, n (%) | CVD mortality, n (%) | CVD morbidity, n (%) | Nephropathy, n (%)
Insulin aspart 70/30 vs. long-acting insulin analogues
Holman, 2007 ^32^ | GP1: Insulin aspart 70/30 (v) Start: 16 median IU/day Range: 10 – 26 IU/day T: bid D: 1 year Usual care D: 1 year GP2: Insulin detemir (v) Start: 16 median IU/day Range: 10 – 24 IU/day T: Bedtime, twice if required D: 1 years Usual care D: 1 year | GP1 3 (1*) GP2 0 (0*) | Myocardial infarction GP1 3 (1*) GP2 0 (0*) | | Change in plasma creatinine, mean (SD) GP1 F-B: 0.05 (0.09) p: 0.008 vs. GP2 GP2 F-B: 0.02 (0.11) GP1–GP2: 0* Change in ratio of albumin to creatinine, median (IQR) GP1 F-B: -0.9 (-8 – 9.7) p: overall 0.07 GP2 F-B: -1.8 (-10.6 – 2.7) GP1–GP2: 1*
Kann, 2006 ^50^ | GP1: Insulin aspart 70/30 (v) Start: 0.1 U/kg bid Mean: 0.4 U/kg T: Breakfast, dinner D: 26 weeks Metformin (v) Start: 500 mg bid or current dose T: Breakfast, dinner D: 26 weeks GP2: Insulin glargine (v) Start: 0.2 U/kg qday Mean: 0.39 U/kg T: preferred time D: 26 weeks Glimepiride (v) Start: 1 mg daily or current dose T: Breakfast D: 26 weeks | | | Peripheral vascular disorder GP1 1 (0.8) GP2 0 (0) Cardiac failure GP1 0 (0) GP2 1 (0.8)
Insulin aspart 70/30 vs. rapid-acting insulin analogues
Holman, 2007 ^32^ | GP1: Insulin aspart 70/30 (v) Start: 16 median IU/day Range: 10 – 26 IU/day T: bid D: 1 year Usual care D: 1 year GP2: Insulin aspart (v) Start: 18 median IU/day Range: 9 – 24 IU/day T: Breakfast, lunch, dinner D: 1 year Usual care D: 1 year | GP1 3 (1*) GP2 1 (0*) | Myocardial infarction GP1 3 (1*) GP2 1 (0*) | | Change in plasma creatinine, mean (SD) GP1 F-B: 0.05 (0.09) p: 0.62 vs. GP2 GP2 F-B: 0.05 (0.12) GP1–GP2: 0* Change in ratio of albumin to creatinine, median (IQR) GP1 F-B: -0.9 (-8 – 9.7) p: overall 0.07 GP2 F-B: -0.9 (-12.4 – 6.2) GP1–GP2: 0*
Insulin aspart 70/30 vs. premixed human insulins
Boehm, 2004 ^45^ | GP1: Insulin aspart 70/30 (v) Start: 0.57 U/kg T: Breakfast, dinner D: 24 months GP2: NPH/regular 70/30 (v) Start: 0.57 U/Kg T: Breakfast, dinner D: 24 months | GP1 3 (5*) GP2 1 (2*) | Cardiac failure GP1 1 (2*) GP2 0 (0*) | Cardiovascular adverse events GP1 15 (26) events: 19 GP2 17 (25) events: 19
Hermansen, 2002 ^58^ | GP1: Insulin aspart 70/30 (fix) Start: 0.4 U/kg T: Breakfast D: 1 day GP2: NPH/regular 70/30 (fix) Start: 0.4 U/kg T: Breakfast D: 1 day | | | Transient ischemic attack GP1 1 (2*) GP2 0 (0)
Insulin aspart 70/30 vs. oral antidiabetic agents
Kvapil, 2006 ^51^ | GP1: Insulin aspart 70/30 (v) Start: 0.3 U/kg/day Mean: 0.51 U/kg/day T: Breakfast, dinner D: 16 weeks GP2: Metformin (fix) Mean: 1660 mg daily Range: 500 – 3000 mg qd T: NR D: 16 weeks Glibenclamide (v) Start: 1.75 mg Mean: 2.33 (start), 6.58 mg (end) T: once or twice daily D: 16 weeks | GP1 0 (0*) GP2 0 (0*) | Myocardial infarction GP1 0 (0*) GP2 0 (0*)
Kvapil, 2006 ^51^ | GP1: Insulin aspart 70/30 (v) Start: 0.2 U/kg/day Mean: 0.3 U/kg/day T: Breakfast, dinner D: 16 weeks Metformin (fix) Mean: 1660 mg daily Range: 500 – 3000 mg qd T: NR D: 16 weeks GP2: metformin (fix) Mean: 1660 mg daily Range: 500 – 3000 mg qd T: NR D: 16 weeks Glibenclamide (v) Start: 1.75 mg Mean: 2.33 (start), 6.58 mg (end) T: once or twice daily D: 16 weeks | GP1 1 (1*) GP2 0 (0*) | Myocardial infarction GP1 1 (1*) GP2 0 (0*)
Raskin, 2007 ^60^ | GP1: Insulin aspart 70/30 (v) Start: 6 U bid Mean: 0.6 U/kg/day T: Breakfast, dinner D: 34 weeks Metformin (fix) Mean: 2446 mg T: NR D: 34 weeks Pioglitazone (fix) Mean: 32.5 mg T: NR D: 34 weeks GP2: metformin (fix) Mean: 2439 mg T: NR D: Unclear Pioglitazone (fix) Mean: 31.7 T: NR D: Unclear | | | Withdrawn due to arrhythmia, angina pectoris, and coronary artery disease GP1 1 (1*) GP2 2 (2*) | Withdrawn due to increased blood creatinine GP1 1 (1*) GP2 0 (0*)
Raz, 2003 ^57^ | GP1: Insulin aspart 70/30 (v) Start: 6 – 8 U bid T: Breakfast, dinner D: 6 weeks Rosiglitazone (fix) Start: 4 mg T: Breakfast D: 6 weeks GP2: Glibenclamide (fix) Range: 7.5 – 15 mg T: Dinner D: 6 weeks Rosiglitazone (fix) Start: 4 mg T: Breakfast D: 6 weeks | | | Non-fatal myocardial infarction GP1 1 (4*) GP2 0 (0*)
Raz, 2005 ^54^ | GP1: Insulin aspart 70/30 (v) Start: 0.3 U/kg/day Mean: 0.7 U/kg/day T: Breakfast, dinner D: 18 weeks GP2: Glibenclamide (v) Start: 5 to 10 mg Mean: 14 mg T: Breakfast D: 18 weeks Pioglitazone (fix) Start: 30 mg Mean: 30 mg T: Breakfast D: 18 weeks | | | Non-fatal myocardial infarction GP1 1 (1*) GP2 0 (0*)
Raz, 2005 ^54^ | GP1: Insulin aspart 70/30 (v) Start: 0.2 U/kg/day Mean: 0.5 U/kg/day T: Breakfast, dinner D: 18 weeks Pioglitazone (fix) Start: 30 mg Mean: 30 mg T: Breakfast D: 18 weeks GP2: Glibenclamide (v) Start: 5 to 10 mg Mean: 14 mg T: Breakfast D: 18 weeks Pioglitazone (fix) Start: 30 mg Mean: 30 mg T: Breakfast D: 18 weeks | | | Non-fatal myocardial infarction GP1 0 (0*) GP2 0 (0*)
Insulin aspart 70/30 vs. exenatide
Nauck, 2007 ^49^ | GP1: Insulin aspart 70/30 (v) Start: 15.7 U/day Mean: 24.4 U/day T: Breakfast, dinner D: 52 weeks ‘Optimally’ effective metformin and sulfonylurea therapy (v) T: NR D: 52 weeks GP2: Exenatide (v) Start: 5 μg bid Range: 5 – 10 μg bid T: Breakfast D: 52 weeks ‘Optimally’ effective metformin and sulfonylurea therapy (v) T: NR D: 52 weeks | GP1 1 (0.4) GP2 2 (0.8) | | Unspecified cardiac disorder adverse events GP1 5 (2*) GP2 10 (4*)
Insulin aspart 70/30 vs. insulin lispro 75/25
Hermansen, 2002 ^58^ | GP1: Insulin aspart 70/30 (fix) Start: 0.4 U/kg T: Breakfast D: 1 day GP2: Insulin lispro 75/25 (fix) Start: 0.4 U/kg T: Breakfast D: 1 day | | | Transient ischemic attack GP1 1 (2*) GP2 0 (0)
Niskanen, 2004 ^55^ | GP1: Insulin aspart 70/30 (v) Mean: 0.65 U/kg to 0.67 U/kg T: Breakfast, dinner D: 12 weeks GP2: Insulin lispro 75/25 (v) Mean: 0.67 U/kg to 0.71 U/kg T: Breakfast, dinner D: 12 weeks | GP1 0 (0*) GP2 1 (1*) | Myocardial infarction GP1 0 (0*) GP2 1 (1*)
Insulin aspart 70/30 vs. insulin aspart 70/30 + oral antidiabetic agents
Kvapil, 2006 ^51^ | GP1: Insulin aspart 70/30 (v) Start: 0.3 U/kg/day Mean: 0.51 U/kg/day T: Breakfast, dinner D: 16 weeks GP2: Insulin aspart 70/30 (v) Start: 0.2 U/kg/day Mean: 0.3 U/kg/day T: Breakfast, dinner D: 16 weeks Metformin (fix) Mean: 1660 mg daily Range: 500 – 3000 mg qd T: NR D: 16 weeks | GP1 0 (0*) GP2 1 (1*) | Myocardial infarction GP1 0 (0*) GP2 1 (1*)
Raz, 2005 ^54^ | GP1: Insulin aspart 70/30 (v) Start: 0.3 U/kg/day Mean: 0.7 U/kg/day T: Breakfast, dinner D: 18 weeks GP2: Insulin aspart 70/30 (v) Start: 0.2 U/kg/day Mean: 0.5 U/kg/day T: Breakfast, dinner D: 18 weeks Pioglitazone (fix) Start: 30 mg Mean: 30 mg T: Breakfast D: 18 weeks | | | Non-fatal myocardial infarction GP1 1 (1*) GP2 0 (0*)
Insulin aspart 70/30 vs. rapid-acting insulin analogue with intermediate-acting human insulin
Hirao, 2008 ^61^ | GP1: Insulin aspart 70/30 (NR) T: bid D: 6 months GP2: Insulin aspart (NR) T: tid D: 6 months NPH insulin (NR) T: Optional multiple daily injections D: 6 months | GP1 1 (1*) GP2 0 (0*)
Insulin lispro 75/25 vs. long-acting insulin analogues
Malone, 2004 ^65^ | GP1: Insulin lispro 75/25 (v) Mean: 0.62 U/kg T: Breakfast, dinner D: 16 weeks Metformin (NR) Mean: 1945 mg Range: 1500 – 2550 mg T: NR D: 16 weeks GP2: Insulin glargine (v) Mean: 0.57 U/kg T: Bedtime D: 16 weeks Metformin (NR) Mean: 1997 mg Range: 1500 – 2550 mg T: NR D: 16 weeks | | | Congestive heart failure GP1 1 (1*) GP2 0 (0*)
Malone, 2005 ^66^ | GP1: Insulin lispro 75/25 (v) Mean: 0.42 U/kg T: Breakfast, dinner D: 16 weeks Metformin (fix) Mean: 2128 mg Range: 1500 – 2550 mg T: NR D: 16 weeks GP2: Insulin glargine (v) Mean: 0.36 U/kg T: Bedtime D: 16 weeks Metformin (fix) Mean: 2146 mg Range: 1500 – 2550 mg T: NR D: 16 weeks | GP1 1 (1*) GP2 1 (1*) | Myocardial infarction GP1 1 (1*) GP2 0 (0*)
Insulin lispro 75/25 vs. premixed human insulins
Hermansen, 2002 ^58^ | GP1: Insulin lispro 75/25 (fix) Start: 0.4 U/kg T: Breakfast D: 1 day GP2: NPH/regular 70/30 (fix) Start: 0.4 U/kg T: Breakfast D: 1 day | | | Transient ischemic attack GP1 0 (0) GP2 0 (0)
Insulin lispro 75/25 vs. oral antidiabetic agents
Malone, 2003 ^68^ | GP1: Insulin lispro 75/25 (v) Mean: 0.19 (morning), 0.14 U/kg (evening) T: Breakfast, dinner D: 16 weeks Metformin (v) Mean: 1813 mg/day Range: 1500 – 2550 mg/day T: 2 to 3 divided doses with meals D: 16 weeks GP2: Metformin (v) Mean: 1968 mg/day Range: 1500 – 2550 mg/day T: 2 to 3 divided doses with meals D: 16 weeks Glibenclamide (v) Mean: 14.2 mg/day T: NR D: 16 weeks | GP1 1 (0*) GP2 0 (0*)
Insulin lispro 50/50 vs. premixed human insulins
Schernthaner, 2004 ^77^ | GP1: Insulin lispro 50/50 (v) Mean: 64.6 IU T: Breakfast, lunch, dinner D: 12 weeks Diet/exercise D: 12 weeks GP2: NPH/regular 70/30 (v) Mean: 61.8 IU T: Breakfast, dinner D: 12 weeks Diet/exercise D: 12 weeks | GP1 0 (0*) GP2 1 (2*)
Insulin lispro 50/50 vs. long-acting insulin analogues
Robbins, 2007 ^79^ | GP1: Insulin lispro 50/50 (v) Mean: 0.7 U/kg T: Breakfast, lunch, dinner D: 24 weeks Metformin (fixed) Mean : 1641 mg T: bid D: 24 weeks GP2: Insulin glargine (v) Mean: 0.6 U/kg T: Bedtime D: 24 weeks Metformin (fixed) Mean: 1636 mg T: bid D: 24 weeks | | | | Withdrew due to renal insufficiency GP1 0 (0) GP2 1 (0.6)

μg = microgram; bid = twice daily; CVD = cardiovascular disease; D = duration; F-B = mean difference from baseline; fix = fixed dosing; GP = group; GP1–GP2 = mean difference between the difference from baseline; IQR = interquartile range; IU = international unit; kg = kilogram; mg = milligram; NPH = neutral protamine Hagedorn; NR = not reported; p = p-value; qd = once daily; T = time of day when insulin taken; tid = thrice daily; U = unit; v = dose varied

Table 10 Pooled estimates of effect for clinical outcomes using different meta-analytic techniques

Outcomes and meta-analytic methods | Pooled estimates (odds ratio) | 95% CI
All-cause mortality (n = 6 studies)
Bayesian | 6.00 | 0.32 to 237.4
Mantel-Haenszel (0.5 cont corr) | 2.39 | 0.87 to 6.59
Mantel-Haenszel (0.1 cont corr) | 2.93 | 0.95 to 9.05
Mantel-Haenszel (0.01 cont corr) | 3.10 | 0.97 to 9.91
Peto | 3.05 | 1.04 to 8.93
Cardiovascular disease mortality (n = 3 studies)
Bayesian | -* | -*
Mantel-Haenszel (0.5 cont corr) | 3.80 | 0.76 to 18.98
Mantel-Haenszel (0.1 cont corr) | 6.80 | 0.87 to 53.12
Mantel-Haenszel (0.01 cont corr) | 8.56 | 0.92 to 79.55
Peto | 6.60 | 1.23 to 35.47
Cardiovascular disease morbidity (n = 6 studies)
Bayesian | 0.89 | 0.33 to 3.05
Mantel-Haenszel (0.5 cont corr) | 0.85 | 0.49 to 1.49
Mantel-Haenszel (0.1 cont corr) | 0.86 | 0.49 to 1.52
Mantel-Haenszel (0.01 cont corr) | 0.86 | 0.49 to 1.52
Peto | 0.86 | 0.49 to 1.52
Combined outcome of mortality and cardiovascular disease morbidity (n = 10 studies)
Bayesian | 3.36 | 0.96 to 16.82
Mantel-Haenszel (0.5 cont corr) | 1.78 | 0.80 to 3.96
Mantel-Haenszel (0.1 cont corr) | 2.10 | 0.87 to 5.10
Mantel-Haenszel (0.01 cont corr) | 2.21 | 0.89 to 5.49
Peto | 2.20 | 0.92 to 5.27

* Unable to calculate due to scarcity of data (i.e., no convergence of the Markov Chain Monte Carlo model or confidence intervals were so wide, results did not make sense to report).

CI = confidence interval, cont corr = continuity correction, n = number

Table 11 Grading of the body of evidence of the effects of premixed insulin analogues in patients taking oral antidiabetic agents

| Intermediate outcomes
| A1c | Fasting glucose | Pre-dinner glucose | 2-hour postprandial glucose after breakfast | 2-hour postprandial glucose after dinner | Quality of life
[underlined: Quantity of evidence:] Number of studies | 3 | 3 | 3 | 3 | 3 | 1
Range of sample sizes | 281–329 | 281–329 | 281–329 | 281–329 | 281–329 | 308
[underlined: Quality and consistency of evidence:] Were study designs mostly RCTs (high quality), non-RCTs (medium quality), observational studies (low quality), or about a 50:50 mix of experimental and observational (medium quality)? | High | High | High | High | High | High
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | 0 | 0 | 0 | 0 | 0 | 0
Did the studies have important inconsistency? (-1) | 0 | 0 | 0 | 0 | 0 | 0
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest)? | -1 | -1 | -1 | -1 | -1 | -1
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | -1 | -1 | -1 | -1 | -1 | -1
Did the studies have high probability of reporting bias? (-1) | 0 | 0 | 0 | 0 | 0 | 0
Did the studies show strong evidence of association between intervention and outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2)) [underlined: - use your clinical judgment for absolute differences.] | 0 | 0 | 0 | 0 | 0 | 0
Did the studies have evidence of a dose-response gradient? (+1) | 0 | 0 | 0 | 0 | 0 | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0 | 0 | 0 | 0 | 0
Overall grade of evidence (high, moderate, low) | Low | Low | Low | Low | Low | Low
| Safety/adverse events and clinical outcomes
| Hypoglycemia | Weight change | All-cause mortality | CVD mortality | CVD morbidity | Nephropathy
[underlined: Quantity of evidence:] Number of studies | 3 | 3 | 1 | 1 | 2 | 0
Range of sample sizes | 281–329 | 281–329 | 329 | 329 | 281–329 | 0
[underlined: Quality and consistency of evidence:] Were study designs mostly RCTs (high quality), non-RCTs (medium quality), observational studies (low quality), or about a 50:50 mix of experimental and observational (medium quality)? | High | High | High | High | High | 0
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | 0 | 0 | -1 | -1 | -1 | 0
Did the studies have important inconsistency? (-1) | 0 | -1 | 0 | 0 | -1 | 0
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest)? | -1 | -1 | -1 | -1 | -1 | 0
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | -1 | -1 | -1 | -1 | -1 | 0
Did the studies have high probability of reporting bias? (-1) | 0 | 0 | 0 | 0 | 0 | 0
Did the studies show strong evidence of association between intervention and outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2)) [underlined: - use your clinical judgment for absolute differences.] | 0 | 0 | 0 | 0 | 0 | 0
Did the studies have evidence of a dose-response gradient? (+1) | 0 | 0 | 0 | 0 | 0 | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0 | 0 | 0 | 0 | 0
Overall grade of evidence (high, moderate, low) | Low | Low | Insufficient | Insufficient | Insufficient | Insufficient

High = further research is very unlikely to change our confidence in the estimates; moderate = further research is likely to have an important impact on our confidence in the estimate of effect and [underlined: may] change the estimate; low = further research is likely to have an important impact on our confidence in the estimate of effect and [underlined: is likely to] change the estimate; very low = any estimate of effect is very uncertain.