# Hand Searched Journals

## All Journals Hand Searched

### June 2007 – September 2007

Acta Diabetologica

Annals of Internal Medicine

Clinical Therapeutics

Diabetes Care

Diabetes, Obesity & Metabolism

Diabetic Medicine

Diabetologia

European Journal of Internal Medicine

Experimental and Clinical Endocrinology and Diabetes

Hormone and Metabolic Research

JAMA

Journal of Diabetes and its Complications

New England Journal of Medicine