# Detailed Electronic Database Search Strategies

## MEDLINE Strategy

Terms | Returns
((“diabetes mellitus, type 2”[mh] OR “type 2 diabetes”[tiab] OR ((diabetes[tiab] OR diabetics[tiab] OR diabetic[tiab]) AND (“non-insulin dependent”[tiab] OR “type 2”[tiab] or type-2[tiab] OR “type II”[tiab]))) AND (“insulin/analogs and derivatives”[mh] OR “BIAsp 30”[tiab] OR “BIAsp30”[tiab] OR (Humalog[tiab] AND (Mix[tiab] OR 25[tiab] OR 50[tiab])) OR (NovoLog[tiab] AND (Mix[tiab] OR 70[tiab] OR 30[tiab])) OR (insulin[tiab] AND ((biphasic[tiab] OR premixed[tiab] OR “pre-mixed”[tiab] OR protamin*[tiab] OR Mix[tiab] OR mixture[tiab]) OR (aspart[tiab] OR lispro[tiab] OR analogue[tiab] OR analogues[tiab] OR analog[tiab] OR analogs[tiab] OR Humalog[tiab]))))) NOT (animals[mh]NOT humans[mh]) | 1149

## EMBASE Strategy

((‘non insulin dependent diabetes mellitus’/exp OR ‘type 2 diabetes’:ti,ab OR ((diabetes:ti,ab OR diabetics:ti,ab OR diabetic:ti,ab) AND (‘non-insulin dependent’:ti,ab OR ‘type 2’:ti,ab or type-2:ti,ab OR ‘type II’:ti,ab))) AND (‘biphasic insulin’/exp OR ‘BIAsp 30’:ti,ab OR ‘BIAsp30’:ti,ab OR (Humalog:ti,ab AND (Mix:ti,ab OR 25:ti,ab OR 50:ti,ab)) OR (NovoLog:ti,ab AND (Mix:ti,ab OR 70:ti,ab OR 30:ti,ab)) OR ((insulin:ti,ab AND (biphasic:ti,ab OR premixed:ti,ab OR ‘pre-mixed’:ti,ab OR protamin*:ti,ab OR Mix:ti,ab) OR (aspart:ti,ab OR lispro:ti,ab OR analogue:ti,ab OR analogues:ti,ab OR analog:ti,ab OR analogs:ti,ab OR Humalog:ti,ab))))) NOT ([animals]/lim NOT [humans]/lim) | 1344

## Cumulative Index to Nursing and Applied Health Literature (CINAHL)

(((MH “Diabetes Mellitus, Non-Insulin-Dependent”) OR (TX “type 2 diabetes”) OR (((TX “diabetes”) OR (TX “diabetics”) OR (TX “diabetic”)) AND ((TX “non-insulin dependent”) OR (TX “type 2”) or (TX “type-2”) OR ( TX “type II”)))) AND ((MH “Insulin/AA”) OR (TX “BIAsp 30”) OR (TX “BIAsp30”) OR ((TX “Humalog”) AND ((TX “Mix”) OR (TX “25”) OR (TX “50”))) OR ((TX “NovoLog”) AND ((TX “Mix”) OR (TX “70”) OR (TX “30”))) OR ((TX “insulin”) AND (((TX “biphasic”) OR (TX “premixed”) OR (TX “pre-mixed”) OR (TX “protamin*”) OR (TX “Mix”) OR (TX “mixture”)) OR ((TX “aspart”) OR (TX “lispro”) OR (TX “analogue”) OR (TX “analogues”) OR (TX “analog”) OR (TX “analogs”) OR (TX “Humalog”)))))) | 299

## The Cochrane Central Register of Controlled Trials (CENTRAL)

#1 (type 2 diabetes):ti,ab,kw in Clinical Trials #2 (diabetes):ti,ab,kw or (diabetics):ti,ab,kw or (diabetic):ti,ab,kw in Clinical Trials #3 (non-insulin dependent):ti,ab,kw or (type 2):ti,ab,kw or (type-2):ti,ab,kw or (type II):ti,ab,kw in Clinical Trials #4 (#2 AND #3) #5 (#1 OR #4) #6 (BIAsp 30):ti,ab,kw or (BIAsp30):ti,ab,kw in Clinical Trials #7 (Humalog):ti,ab,kw in Clinical Trials #8 (Mix):ti,ab,kw or (25):ti,ab,kw or (50):ti,ab,kw in Clinical Trials #9 (#7 AND #8) #10 (NovoLog):ti,ab,kw in Clinical Trials #11 (Mix):ti,ab,kw or (70):ti,ab,kw or (30):ti,ab,kw in Clinical Trials #12 (#10 AND #11) #13 (insulin):ti,ab,kw in Clinical Trials #14 (biphasic):ti,ab,kw or (premixed):ti,ab,kw or (pre-mixed):ti,ab,kw or (protamin*):ti,ab,kw or (mix):ti,ab,kw in Clinical Trials #15 (mixture):ti,ab,kw in Clinical Trials #16 (#14 OR #15) #17 (aspart):ti,ab,kw or (lispro):ti,ab,kw or (analogue):ti,ab,kw or (analogues):ti,ab,kw or (analog):ti,ab,kw in Clinical Trials #18 (analogs):ti,ab,kw or (Humalog):ti,ab,kw in Clinical Trials #19 (#17 OR #18) #20 (#16 OR #19) #21 (#13 AND #20) #22 (#6 OR #9 OR #12 OR #21) #23 (#5 AND #22) | 654