# Appendixes

Appendix A Detailed Electronic Database Search Strategies

Appendix B Hand Searched Journals

Appendix C List of Excluded Articles

Appendix D Data Abstraction Forms

Appendix E Evidence Tables