# Results

Our literature searches identified 8,637 potentially relevant citations (including 1,127 rescreened from the original ECRI evidence report). After review of the abstracts, the full-length articles of 2,480 of these studies were obtained and examined in full text. Finally, 128 new studies were considered eligible for inclusion in the updated review, for a total of 316 included studies. Figure 2 presents the literature flow and Table 2 summarizes the additions to the original report, separately by Key Question.

Figure 2 Flow chart of included studies

CNB = core needle biopsy; KQ = Key Question; N = number of patients; SIP = Scientific Information Packet.

This figure illustrates the flow of studies in the report. We retrieved 7510 publications from our initial database searches, to which we added 1127 publications from the ECRI search files. Of these 2272 were reviewed in full text, with 316 studies included in the final report. Reasons for exclusion included: duplicate references, full text not in English, fewer than 10 patients and no seeding information, less that 50 percent follow-up, reference standard incomplete, more than 15 percent of women have previous or current cancer, used a core-needle instrument that is no longer commercially available, case control or retrospective case study, no primary data, no core-needle biopsy or core-needle biopsy not for diagnosis of primary breast cancer in women, cases selected on the basis of core-needle biopsy or final outcomes, or no outcomes of interest. Overall, 161 studies address KQ1, 145 studies address KQ2, and 143 studies address KQ3.

Table 2 Summary of new evidence evaluated in this update^*^

Key Question | Studies Included in the Original Report | Studies Identified by the Updating Process | Total Number of Studies Synthesized in This Report
Key Question 1: What is the test performance of different types of core needle breast biopsy compared with open biopsy in the diagnosis of breast cancer? | 107^**^ | 54 | 161
Key Question 2: What are the adverse events (harms) associated with core needle breast biopsy compared to the open biopsy in the diagnosis of breast cancer? | 74 | 70 | 144
Key Question 3: How do open biopsy and various core needle techniques differ in terms of patient preference, availability, costs, availability of qualified pathologist interpretations, and other factors that may influence choice of a particular technique? | 84 | 59 | 143

* Some studies addressed multiple Key Questions

** The original ECRI report included a total of 108 studies; one core needle biopsy study overlapped with one of the studies identified in our update which enrolled a larger patient population; thus the smaller study was excluded from Key Question 1.

## Key Question 1 In women with a palpable or nonpalpable breast abnormality, what is the test performance of different types of core needle breast biopsy compared with open biopsy for diagnosis?

### Included Studies

Fifty-four new studies identified by this update met the inclusion criteria for Key Question 1. We synthesized these studies with the 106 studies identified by the original evidence report, for a total of 160 studies providing information on test performance outcomes. Studies had been published between 1990 and 2013. Fifty studies were prospectively designed, and 58 were conducted in the United States. Ten studies provided information on more than one group of patients (typically undergoing biopsy with a different biopsy device). In statistical analyses these groups were treated as separate strata, leading to a total of 171 complete 2×2 tables of diagnostic test results, with information on 69,804 breast lesions.

### Test Performance for Breast Cancer Diagnosis

#### Test Performance of Open Surgical Biopsy

Research studies of needle biopsy methods and technical experts generally suggested that open surgical biopsy could be considered a “gold” standard test (i.e. a test without measurement error). One study identified by the original evidence report, provided information on the test performance of open surgical biopsy, using published literature and primary patient data (patient charts) from patients evaluated at a single medical center.34 Based on a re-review of archived open biopsy material by a second pathologist, patient chart review, study of cases with benign results on biopsy after suspicious mammography results, and expert opinion, the authors concluded that open surgical biopsy may miss one to two percent of breast cancers (i.e. sensitivity of 98% or greater). We found a single clinical study of patients undergoing surgical biopsies who were followed by imaging for 12 months after biopsy. This study reported underestimation in 16.7 percent of ADH lesions (1 of 6 lesions) and 7.1 percent of DCIS lesions (1/14 lesions) diagnosed thorough open biopsy.35 The small number of lesions in this study precludes reliable conclusions. Because open surgical biopsy samples the entire target lesion or a large part of it, in theory underestimation rates can be reduced to zero.

#### Test Performance of Core Needle Biopsy Methods

A total of 160 studies contributed information to analyses of test performance of core needle biopsy methods.35–194 Six studies enrolled women at high risk of cancer development and 154 enrolled women at average risk. The studies reported on a variety of biopsy techniques: 131 study arms reported on the use of a single form of imaging guidance (83 stereotactic; 41 ultrasound; 6 MRI; 1 grid) whereas ten used freehand methods, 29 used multiple methods, including freehand techniques in some cases (and did not report test performance results separately by each method), and one did not report adequate details. Sixty study arms used vacuum-assisted methods to obtain the biopsy sample; 80 used automated methods; 30 used multiple methods; and 1 did not report adequate details. Needle size also varied across studies: 57 used 14G needles, nine used smaller and 46 used larger bores; 48 studies did not report relevant information or used a range of needle sizes. Reference standard tests also differed across studies: 26 used open biopsy on all included patients; 94 used mean or median follow up of between 6 and 24 months for test negative patients, and 40 used mean or median followup of 24 months or more for test negative cases. Details about study design, selection criteria, enrolled populations, biopsy methods and results, are publically available in the SRDR. Consistent with the findings of the original report, the overall risk of bias was considered moderate to high, mainly due to concerns about spectrum bias, retrospective data collection, differential verification, and lack of information regarding the blinding of reference standard test assessors to the index test results. Detailed results from our risk of bias assessment are provided at the end of this section.

The prevalence of malignant disease (invasive or DCIS, at the lesion level) ranged from 1 percent to 94 percent, with a median of 34 percent. The proportion of correct diagnoses ranged from 68 percent to 100 percent, with a median of 96 percent. Table 3 summarizes the results for alternative diagnostic biopsy methods, together with information on the number of lesions evaluated by each test and summary test performance information, for women at average risk of cancer. Table 4 summarizes the same information for women deemed to be at high risk for cancer (e.g. due to genetic factors or strong family history). Figure 3 presents individual study estimates and meta-analytic results in the ROC space for both groups of women. These plots indicate that results were fairly homogeneous across studies for each test and that test sensitivity and specificity were close to 1 (studies cluster at the top left corner of the space). In analyses excluding high risk lesions on core needle biopsy that were also classified as high risk lesions on the reference standard test, the summary sensitivity of the various tests was unaffected; and summary specificity was somewhat increased (Appendix C).

Table 3 Summary estimates of test performance for alternative core needle biopsy methods – women at average risk of cancer

Biopsy Method or Device | N Studies [N biopsies] for Sensitivity & Specificity | Sensitivity | Specificity | N Studies [N biopsies] for DCIS Underestimation | DCIS Underestimation Probability | N Studies [N biopsies] for High Risk Lesion Underestimation | High Risk Lesion Underestimation Probability
Freehand, automated | 10 [786] | 0.91 (0.80 to 0.96) | 0.98 (0.95 to 1.00) | 0 [0] | NA | 1 [6] | 0.88 (0.32 to 1.00)
US-guided, automated | 27 [16287] | 0.99 (0.98 to 0.99) | 0.97 (0.95 to 0.98) | 14 [307] | 0.38 (0.26 to 0.51) | 21 [601] | 0.25 (0.16 to 0.36)
US-guided, vacuum-assisted | 12 [1543] | 0.97 (0.92 to 0.99) | 0.98 (0.96 to 0.99) | 5 [48] | 0.09 (0.02 to 0.26) | 9 [20] | 0.11 (0.02 to 0.33)
Stereotactically guided, automated | 37 [9535] | 0.97 (0.95 to 0.98) | 0.97 (0.96 to 0.98) | 18 [664] | 0.26 (0.19 to 0.36) | 29 [357] | 0.47 (0.37 to 0.58)
Stereotactically guided, vacuum-assisted | 43 [14667] | 0.99 (0.98 to 0.99) | 0.92 (0.89 to 0.94) | 34 [1899] | 0.11 (0.08 to 0.14) | 40 [1002] | 0.18 (0.13 to 0.24)
MRI-guided, automated | 2 [89] | 0.90 (0.57 to 0.99) | 0.99 (0.91 to 1.00) | 0 [0] | NA | 1 [1] | 0.49 (0.02 to 0.97)
MRI-guided, vacuum-assisted | 1 [10] | 1.00 (0.98 to 1.00) | 0.91 (0.54 to 0.99) | 1 [1] | 0.00 (0.00 to 0.38) | 0 [0] | NA
Multiple methods/other | 33 [26028] | 0.99 (0.98 to 0.99) | 0.96 (0.93 to 0.97) | 18 [628] | 0.22 (0.15 to 0.30) | 25 [866] | 0.32 (0.23 to 0.41)

All numbers are medians with 95% CrIs, unless otherwise stated.

CrI = credible interval; DCIS = ductal carcinoma in situ; MRI = magnetic resonance imaging; N = number; NA = not applicable; US = ultrasound.

Table 4 Summary estimates of test performance for alternative core needle biopsy methods – women at high risk of cancer

Biopsy Method or Device | N Studies (N biopsies) for Sensitivity and Specificity | Sensitivity (95% CrI) | Specificity (95% CrI)
Stereotactically guided, automated | 1 [416] | 0.97 (0.82 to 1.00) | 0.97 (0.91 to 0.99)
Stereotactically guided, vacuum-assisted | 2 [311] | 0.99 (0.93 to 1.00) | 0.93 (0.79 to 0.98)
MRI-guided, automated | 2 [56] | 0.90 (0.58 to 0.98) | 0.99 (0.92 to 1.00)
MRI-guided, vacuum-assisted | 1 [76] | 1.00 (0.98 to 1.00) | 0.92 (0.61 to 0.99)

No studies provided information on the test performance of freehand or US-guided biopsy methods, or the use of multiple methods in populations of women at high risk of cancer. Results are based on bivariate model with risk group as a covariate.

CrI = credible interval; DCIS = ductal carcinoma in situ; MRI = magnetic resonance imaging; N = number; US = ultrasound.

Figure 3 Scatterplot of results in the receiver operating characteristic space and summary receiver operating characteristic curves of alternative core needle biopsy methods for the diagnosis of breast cancer

Solid black lines represent results for average risk women; dashed gray lines represent results for high risk women (when studies were available). The numbers of observations and studies include cohorts of women both at average and high risk of cancer. The number of observations reflects the total number of data points in the analysis; some studies contributed patient-level and others lesion-level results. MRI = magnetic resonance imaging; US = ultrasound.

Seven scatterplot graphs presenting individual study estimates and meta-analytic results in the ROC space for six different core-needle biopsy techniques (freehand, automated; ultrasound, automated; ultrasound, vacuum-assisted; stereotactic, automated; stereotactic, vacuum-assisted; magnetic resonance imaging, automated; magnetic resonance imaging, vacuum-assisted). Each graph has an x-axis of one minus the specificity (range 0.0 to 1.0) and a y-axis of sensitivity (range 0.0 to 1.0). Results for average-risk women are represented by solid black lines and results for high-risk women are represented by solid gray lines, when results are available. In all graphs the points cluster at the top left indicating that test sensitivity and specificity were close to 1.

Key findings with respect to test performance (sensitivity, specificity, and positive and negative likelihood ratios^*^) and underestimation rates are summarized narratively below. As mentioned, only six studies reported results on the test performance of various biopsy methods for breast cancer diagnosis in high risk women. Of these studies, only three reported information on underestimation rates (all three for high risk lesions; none for DCIS).

* To aid in the interpretation of likelihood ratios we remind readers that these statistics can be used to convert pre-test probabilities to post-test probabilities. For example, before testing, assume that a patient has probability of disease pre-test p = 0.1 and p r e - t e s t o d d s = (p r e - t e s t p)/(1 - p r e - t e s t p) = (0.1)/(0.9) = 0.11 . If the diagnostic test has a positive likelihood ratio (LR^+^) of 15 then the post-test odds are post-test odds = pre-test odds × LR^+^ = 0.11 × 15 = 1.67. This corresponds to a post-test probability of p o s t - t e s t p = (p o s t - t e s t o d d s)/(p o s t - t e s t o d d s + 1) = (1.67)/(1.67 + 1) = 0.625 (i.e. the post-test probability is approximately 6 times greater than the pre-test value). If the test results had been negative and the test had a negative likelihood ratio (LR^−^) of 0.1, the post-tests odds would be post-test odds = pre-test odds × LR^−^ = 0.11 × 0.1 = 0.011, which corresponds to p o s t - t e s t p = (0.011)/(0.011 + 1) = 0.011 (i.e. approximately the post-test probability is approximately 10 times lower than the pre-test value). As a rule of thumb, LR^+^ > 10 and LR^−^ < 0.1 are generally considered clinically meaningful.

##### Freehand Core Needle Biopsies

Women at average risk of cancer: Ten cohorts reported data on the accuracy of nonguided (i.e., freehand) core needle biopsies performed with automated biopsy devices. The summary sensitivity was 0.91 (95% CrI, 0.80 to 0.96) and the summary specificity was 0.98 (95% CrI, 0.95 to 1.00), corresponding to a positive likelihood ratio of 58.4 (95% CrI, 19.0 to 226.9) and a negative likelihood ratio of 0.09 (95% CrI, 0.04 to 0.20). Only one study provided information on the high risk lesion underestimation rate (five cancers misclassified as high risk lesions among a total of six such lesions on core needle biopsy). No studies provided information on the DCIS underestimation rate.

Women at high risk of cancer: No studies provided information on the test performance (sensitivity, specificity, or underestimation rates) of freehand core needle biopsy techniques in women at high risk of breast cancer.

##### Ultrasound Guided Automated Device Core Needle Biopsies

Women at average risk of cancer: Twenty-seven cohorts of 16,287 biopsies used ultrasound guidance and an automated biopsy device. The summary sensitivity was 0.99 (95% CrI, 0.98 to 0.99) and the summary specificity was 0.97 (95% CrI, 0.95 to 0.98), corresponding to a positive likelihood ratio of 33.5 (95% CrI, 20.7 to 56.9) and a negative likelihood ratio of 0.01 (95% CrI, 0.01 to 0.02). Fourteen studies provided information on the DCIS underestimation; the summary rate was 0.38 (95% CrI, 0.26 to 0.51). Twenty-one studies provided information on high risk lesion underestimation; the summary rate was 0.25 (95% CrI, 0.16 to 0.36).

Women at high risk of cancer: No studies provided information on the test performance (sensitivity, specificity, or underestimation rates) of ultrasound-guided automated core needle biopsy techniques in women at high risk of breast cancer.

##### Ultrasound Guided Vacuum-Assisted Core Needle Biopsies

Women at average risk of cancer: Twelve cohorts of 1,543 biopsies used ultrasound guidance and a vacuum-assisted device to perform breast biopsies. The summary sensitivity was 0.97 (95% CrI, 0.92 to 0.99) and the summary specificity was 0.98 (95% CrI, 0.96 to 0.99), corresponding to a positive likelihood ratio of 57.7 (95% CrI, 25.8 to 138.7) and a negative likelihood ratio of 0.03 (95% CrI, 0.01 to 0.08). Five studies provided information on DCIS underestimation: the summary rate was 0.09 (95% CrI, 0.02 to 0.26). Nine studies provided information on high risk lesion underestimation: the summary rate was 0.11 (95% CrI, 0.02 to 0.33).

Women at high risk of cancer: No studies provided information on the test performance (sensitivity, specificity, or underestimation rates) of ultrasound-guided automated core needle biopsy techniques in women at high risk of breast cancer.

##### Stereotactically Guided Automated Device Core Needle Biopsies

Women at average risk of cancer: Thirty-seven cohorts of 9,535 biopsies used stereotactic guidance and an automated biopsy device. The summary sensitivity was 0.97 (95% CrI, 0.95 to 0.98) and the summary specificity was 0.97 (95% CrI, 0.96 to 0.98), corresponding to a positive likelihood ratio of 33.6 (95% CrI, 22.6 to 50.9) and a negative likelihood ratio of 0.03 (95% CrI, 0.02 to 0.05). Eighteen studies provided information on DCIS underestimation; the summary rate was 0.26 (95% CrI, 0.19 to 0.36). Twenty-nine cohorts provided information on high risk lesion underestimation; the summary rate was 0.47 (95% CrI, 0.37 to 0.58).

Women at high risk of cancer: One study reported information on the test performance of stereotactically guided automated core needle biopsy methods. Using model-based results, sensitivity was 0.97 (0.82 to 1.00) and specificity was 0.97 (0.91 to 0.99). No studies provided information on the underestimation rate of stereotactically guided automated core needle biopsy methods in women at high risk of breast cancer.

##### Stereotactically Guided Vacuum-Assisted Core Needle Biopsies

Women at average risk of cancer: Forty-three cohorts of 14,667 biopsies used stereotactic guidance and a vacuum-assisted device to perform core needle biopsies. The summary sensitivity was 0.99 (95% CrI, 0.98 to 0.99) and the summary specificity was 0.92 (95% CrI, 0.89 to 0.94), corresponding to a positive likelihood ratio of 12.8 (95% CrI, 9.4 to 17.9) and a negative likelihood ratio of 0.01 (95% CrI, 0.01 to 0.02). Thirty-four studies provided information on DCIS underestimation; the summary rate was 0.11 (95% CrI, 0.08 to 0.14). Forty studies provided information on high risk lesion underestimation; the summary underestimation rate was 0.18 (95% CrI, 0.13 to 0.24).

Women at high risk of cancer: Two studies provided information on the test performance of stereotactically guided vacuum assisted core needle biopsies. The summary sensitivity was 0.99 (95% CrI 0.93 to 1.00) and summary specificity was 0.93 (0.79 to 0.98). One of the two studies also reported that two cancer cases were underestimated by the biopsy diagnosis, among a total of 17 high risk lesions (for an underestimation rate of 12%).

##### MRI-Guided Automated Core Needle Biopsies

Women at average risk of cancer: Two cohorts reported data on the accuracy of MRI-guided biopsies performed with automated biopsy devices. The summary sensitivity was 0.90 (95% CrI, 0.58 to 0.99) and the summary specificity was 0.99 (95% CrI, 0.92 to 1.00), corresponding to a positive likelihood ratio of 62.3 (95% CrI, 9.4 to 726.3) and a negative likelihood ratio of 0.10 (95% CrI, 0.01 to 0.44). None of the studies provided information on the DCIS underestimation rate. One study provided information on the high risk lesion underestimation rate (one biopsy-detected high risk lesion was found to be malignant).

Women at high risk of cancer: Two cohorts provided information on the test performance of MRI-guided automated core needle biopsies among women at high risk for cancer. The summary sensitivity was 0.90 (95% CrI 0.57 to 0.99) and summary specificity was 0.99 (0.91 to 1.00). One of the two studies also reported that no cancers were diagnosed in the two women considered to have high risk lesions on core needle biopsy (i.e. no underestimation was observed in the study).

##### MRI-Guided Vacuum-Assisted Core Needle Biopsies

Women at average risk of cancer: One cohort reported data on the accuracy of MRI-guided biopsies performed with automated biopsy devices. All malignant lesions (n=3) were identified on pathologic examination of biopsy samples (model-based sensitivity 1.00, 95% CrI, 0.98 to 1.00); none of the nonmalignant lesions (n=7) were false positives (model-based specificity 0.91, CrI, 0.54 to 0.99). No cancer was diagnosed in the one woman considered to have DCIS on core needle biopsy (i.e. no DCIS underestimation was observed in the study). The study did not provide information on the high risk lesion underestimation rate.

Women at high risk of cancer: One cohort provided information on the test performance of MRI-guided vacuum-assisted core needle biopsies among women at high risk for cancer. The model-based sensitivity was 1.00 (95% CrI 0.98 to 1.00) and summary specificity was 0.92 (0.61 to 0.99). The study also reported that no cancers developed in the seven women considered to have high risk lesions on core needle biopsy (i.e. no underestimation was observed in the study).

##### Populations Biopsied with Multiple Core Needle Methods (or Other Methods)

Women at average risk of cancer: An additional 33 cohorts reported results from populations of women undergoing core needle biopsy with diverse methods. The majority of these studies (31 of 33) did not stratify their results by biopsy method (with respect to imaging guidance or use of vacuum); this group also included one study using grid guidance, and one study that did not report information on the use of vacuum assistance. In this heterogeneous group of studies, the summary sensitivity was 0.99 (95% CrI, 0.98 to 0.99) and the summary specificity was 0.96 (95% CrI, 0.93 to 0.97), corresponding to a positive likelihood ratio of 22.2 (95% CrI, 15.1 to 32.9) and a negative likelihood ratio of 0.01 (95% CrI, 0.01 to 0.02). Eighteen studies provided information on the DCIS underestimation; the summary DCIS underestimation rate was 0.22 (95% CrI, 0.15 to 0.30). Twenty-five studies provided information on high risk lesion underestimation; the summary underestimation rate was 0.32 (95% CrI, 0.23 to 0.41).

Women at high risk of cancer: No studies of high risk women were included in this subgroup.

### Contextualizing the Results of Test Performance Meta-Analyses

To contextualize the results of the test performance meta-analyses presented in the preceding sections we evaluated the impact of testing in a hypothetical cohort of 1,000 women, under alternative scenarios for disease prevalence. Because delayed diagnosis on the basis of biopsy results is the most important (adverse) outcome related to testing we highlight here results based on false negative biopsies (and their complement, true positive biopsies) in Figure A. In populations with low cancer prevalence, the number of cases where treatment may be delayed on the basis of biopsy results (i.e., false negative biopsies) is expected to be small (e.g., for all ultrasound or stereotactically guided biopsy methods less than five out of 1,000 women, if prevalence is 10 percent or less). As prevalence increases the number of false negative results increases for all biopsy methods, but more rapidly for MRI-guided automated and freehand methods, which had the lowest sensitivity. However, results for MRI-guided automated methods were based on only six studies. Figure 4 also presents numerical results for a prevalence of 25 percent, which is approximately the prevalence of breast cancer among women referred for breast biopsy in the United States. All stereotactically and U.S.-guided methods, and MRI-guided vacuum assisted methods are expected to have fewer than ten false negative results (for every 1000 women undergoing biopsy), even when prevalence is as high as 0.30.

Figure 4 Outcomes of testing in a hypothetical cohort of 1,000 women

Lines correspond to different test modalities: grey dashed-dotted = freehand; black solid = stereotactically guided, automated; grey solid = stereotactically guided, vacuum-assisted; black dotted = US-guided, automated; grey dotted = U.S.-guided, vacuum-assisted; black dashed = MRI-guided, automated; grey dashed = MRI-guided, vacuum assisted.

Two line graphs showing the expected number of true positive and false negative test results in a hypothetical cohort of 1000 women, with underlying prevalence of breast cancer on the x axis (range 0.0 to 0.4) and number of women (out of 1000) on the y axis. Different lines represent different test modalities. The true positive graph shows that for all core-biopsy methods, as prevalence increases so does the number of women with true positive results. The false negative graph shows that the number of false negative results also increases with prevalence.

To illustrate the dependence of the number of true positive results among patients who are test positive by breast biopsy on the prevalence of disease, we calculated positive predictive values over a range of prevalences for different biopsy methods (Figure 5). These results suggest that even in low breast cancer prevalence settings (of 5 to 10 percent), 70 to 80 percent of women who test positive will truly have breast cancer for all tests except stereotactically and MRI-guided, vacuum-assisted biopsy methods. These two methods are associated with somewhat lower positive predictive values (approximately 50 to 60 percent) in low-prevalence settings, reflecting their lower specificity (compared to other tests). However, as the prevalence increases, the positive predictive value approaches 1 for all tests.

Figure 5 Positive predictive value of alternative biopsy methods

MRI = magnetic resonance imaging. Black lines are used for automated and gray lines for vacuum-assisted core needle biopsy methods.

Four graphs plotting positive predictive values across a range of prevalences for eight different biopsy methods (freehand, automated; stereotactic, automated; stereotactic, vacuum-assisted; ultrasound automated; ultrasound, vacuum-assisted; magnetic resonance imaging, automated; magnetic resonance imaging, vacuum-assisted). The x-axis for each graph is prevalence (range 0.0 to 0.4) and the y-axis is positive predictive value (range 0.0 to 1.0). All graphs show positive predictive values approaching 1 as the prevalence of disease increases. All tests except stereotactically and MRI-guided vacuum-assisted biopsy have positive predictive values of 70 to 80% even when prevalence is 0.05 to 0.10. Stereotactic and MRI-guided, vacuum-assisted methods show a positive predictive value of 50 to 60% at a prevalence of 0.10, reflecting their lower specificity compared to the other biopsy methods.

The above comparisons (test outcomes in a hypothetical cohort of known prevalence and positive predictive value calculations) can serve as aids for contextualizing the test performance meta-analysis results presented above. However, they do not reflect the uncertainty around the meta-analytic summary estimates. The following section presents the results of formal (indirect) comparisons among alternative core needle biopsy methods.

### Comparative Test Performance

To compare test performance across different biopsy methods we used indirect (meta-regression-based) comparisons. Table 5 presents comparisons between pairs of biopsy methods using the same imaging guidance for sensitivity and specificity. We only examined comparisons between biopsy methods using the same imaging modality because lesion characteristics (e.g., palpability, ability to visualize a lesions) strongly influence the choice of imaging modality. In general, differences among tests were relatively small: for example, differences in sensitivity or specificity never exceeded 0.1 (i.e., 10 percent absolute difference). Stereotactically guided automated biopsy had a specificity that was higher by 0.05 compared to vacuum-assisted biopsy methods, and a sensitivity that was 0.02 lower. Comparisons among MRI-guided biopsy methods were imprecise, reflecting the small number of available studies.

Table 5 Differences in sensitivity between pairs of biopsy methods (meta-regression based indirect comparisons)

Biopsy Methods Compared | Difference in Sensitivity | Difference in Specificity
US-guided, automated vs. vacuum-assisted | 0.01 (−0.01, 0.06) | −0.01 (−0.03, 0.01)
Stereotactically guided, automated vs. vacuum-assisted | −0.02 (−0.04, −0.01) | 0.05 (0.02, 0.08)
MRI-guided, automated vs. vacuum assisted | −0.10 (−0.43, −0.01) | 0.07 (−0.03, 0.43)

All results are shown as medians of differences (95% CrI). Positive values denote that the method on the first-listed biopsy method has higher performance that the comparator (second listed method). CrIs that do not include the null value (0) are highlighted in bold. CrI = credible interval; MRI = magnetic resonance imaging.

### Factors That Affect Test Performance

We considered evidence on the impact of patient or study level factors on test performance from two complementary sources: (1) within-study evidence (i.e. comparisons of test performance over levels of a factor within the patient population enrolled in a study) and (2) evidence from meta-regression analyses (that combine information across studies). Ideally, all studies would consistently report comparisons of test performance across well-defined subgroups (e.g., by patient, or lesion characteristics). Such within-study comparisons are more informative than comparisons across studies: factors related to study setting are common for all patients within the same study and other patient differences can be addressed (at least to some extent) by appropriate analytic methods (e.g., regression adjustment). In the absence of such information, one has to rely on indirect (across-study) comparisons that are generally less convincing because they cannot account for all differences across included populations. Overall, on the basis of both sources of information (within-study analyses and meta-regression analyses), we found that evidence was insufficient to support any specific factor as a modifier of test performance. Detailed results are presented below.

#### Within-Study Evidence

Twenty studies (14 identified by the original review and 6 included in the current update) of 11,280 patients provided information on factors that affect test performance. Specifically, 16 studies provided information on patient and lesion-related factors, 10 on procedural factors, and 3 on clinician and facility factors (some studies provided information on multiple factors). The majority of studies (140 of 160) did not allow investigation of the impact of any factors on test performance. The 20 included studies were reported inconsistently and often lacked details necessary for formal statistical assessment of the impact of various factors on test performance. These findings raise concerns regarding selective analysis and outcome reporting with respect to modifiers of test performance. Table 6 summarizes the findings of individual studies.

Table 6 Studies evaluating factors that may affect test performance (20 studies, reporting on multiple factors each)

Author, Year [PMID] | Biopsy Method | Factors Evaluated | Key Findings
Patient and lesion factors
Cusick et al., 1990 [2183373] | Freehand | Lesion size | Smaller lesions (<2 cm in diameter) were more likely to be misdiagnosed.
Barreto et al. 1991 [2044776] | Freehand | Lesion size Lesion location Patient age | Tumor size did not affect the accuracy of the procedure. All lesions in the study were > 2 cm in diameter. Lesions in the right breast were more likely to be misdiagnosed. Patient age was not related to accuracy.
Makkun et al. 2011 [no PMID] | Ultrasound-guided automated device | Lesion type | The accuracy of biopsy in palpable lesions was 100%, while the accuracy of biopsy in nonpalpable lesions was 79.16%
Povoski et al. 2011 [21835024] | Ultrasound-guided automated device | Size of lesion; BI-RADS classification; | There was no difference between the median size of the lesion in cases of false negative biopsies and the median size in all cases biopsied. Among women undergoing interval followup after biopsy, the rate of false negatives was 0% for lesions initially classified as BI-RADS 3, 0.6% for lesions classified BI-RADS 4, and 2.8% for lesions classified BI-RADS 5.
Wiratkapun et al. 2012 [22252182] | Ultrasound-guided automated device | Patient age; breast density; lesion type; BI-RADS classification; lesion location | There was no statistically significant relationship between underestimation and patient age, breast density, lesion size, lesion visibility on mammography, lesion type (pure mass vs. mass with calcification), lesion BI-RADS classification (4 vs. 5). Lesions in the lower outer quadrant of the breast were more often underestimated. There was a tendency for younger women with larger mass lesions located at the lower quadrants of the breast and with BI-RADS 5 lesions not seen on mammography to have underestimated lesions.
Dahlstrom et al. 1996 [8735717] | Stereotactically guided automated device | Lesion type | There was no difference in the number of cores needed for diagnosis of microcalcifications, densities, or stellate lesions.
Koskela et al. 2005 [16020555] | Stereotactically guided automated device | Lesion type | There were zero false-negatives out of 97 procedures performed on lesions detected as masses on mammography, but 4 false-negatives out of 108 procedures performed on lesions with microcalcifications.
Walker et al. 1997 [no PMID] | Stereotactically guided automated device | Lesion type | The sensitivity of core needle biopsy was much lower for microcalcifications than for any other type of lesion.
Lomoschitz et al. 2004 [15273332] | Stereotactically guided, vacuum-assisted | Lesion type | Biopsies were equally accurate for lesions with microcalcifications and lesions detected as masses on mammography.
Pfarl et al, 2002 [12438044] | Stereotactically guided, vacuum-assisted | Lesion type | Biopsies were equally accurate for lesions with microcalcifications and lesions detected as masses on mammography.
Reiner et al. 2009 [19565246] | Stereotactically guided, vacuum-assisted | Lesion type | The agreement rate between core needle biopsy and surgery was higher in nonpapillary lesions than in papillary lesions, but this difference was not statistically significant. 5 of 6 cases of underestimation occurred in papillary lesions, and the one false negative occurred in a nonpapillary lesion.
Venkataraman et al. 2012 [22127375] | Stereotactically guided, vacuum-assisted | Patient age; lesion size | There was no correlation between patient age and upgrade. However, there was a positive correlation between size of the lesion and upgrade.
Abdsaleh et al. 2003 [12630998] | Multiple methods | Patient breast density | Technical failures were more likely to occur in women with very dense breast tissue.
Ciatto et al. 2007 [16823506] | Multiple methods | Lesion type | False negative results were 2.7% for palpable lesions, 2.2% for nonpalpable lesions, 2.3% for masses on mammography, 1.4% for distortions on mammography, and 2.5% for microcalcifications.
Cipolla et al. 2006 [16473738] | Multiple methods | Lesion type | Correspondence between core needle biopsy and surgical biopsy results was 100% for palpable lesions but only 88% for nonpalpable lesions.
Fajardo et al. 2004 [15035520] | Multiple methods | Lesion type | Sensitivity was 97.4% for biopsies of masses detected on mammography and 90.7% for biopsies of nonpalpable lesions and lesions with microcalcifications.
Procedural factors
de Lucena et al. 2007 [17663457]. | Ultrasound-guided automated device | Number of cores | Taking >2 cores did not improve accuracy. Taking >2 cores did not reduce the rate of false negatives. The 6 tumors (out of 101) that were falsely diagnosed as benign by core needle biopsy would not have been correctly diagnosed even if up to six cores were taken.
Fishman et al. 2003 [12601206] | Ultrasound-guided automated device | Number of cores | Taking >2 cores improved the accuracy of the biopsy, with 4 cores being the optimal number. 1 case of DCIS would have been missed if fewer than 4 cores had been taken; the other 13 tumors identified in the study would have been correctly diagnosed if only 2 cores had been taken.
Kirshenbaum et al. 2003 [484822] | Ultrasound-guided automated device | Number of cores | 1 core was diagnostic in 82.6% of cases, 2 cores in 90.5% of cases, 3 cores in 97.9% of cases, 4 cores in 98.9% of cases, and 5 cores in 100% of cases. 100% of malignant lesions were diagnosed after the fourth core.
Wiratkapun et al. 2012 [22252182] | Ultrasound-guided automated device | Number of cores | There was no statistically significant relationship between underestimation and number of biopsy cores.
Dahlstrom et al. 1996 [8735717] | Stereotactically guided automated device | Number of cores | One core was diagnostic in 71% of cases, two cores in 84% of cases, three cores in 90% of cases, four cores in 91% of cases, and five cores in 93% of cases.
Koskela et al. 2005 [16020555] | Stereotactically guided automated device | Number of cores | Comment that more than three cores must be taken from lesions before an accurate diagnosis can be made.
Lomoschitz et al. 2004 [15273332] | Stereotactically guided, vacuum-assisted | Number of cores | 12 cores were necessary for accurate diagnosis, but taking >12 cores did not improve accuracy.
Venkataraman et al. 2012 [22127375] | Stereotactically guided, vacuum-assisted | Number of cores | There was no correlation between number of cores and upgrade.
Abdsaleh et al. 2003 [12630998] | Multiple methods | Number of cores; patient breast density | Taking 2 cores instead of one increased the accuracy of the procedure. Technical failures were more likely to occur in women with very dense breast tissue.
Helbich et al. 1997 [9169689] | Multiple methods | Patient position | Patients were randomly assigned to undergo stereotactic biopsies in either seated or prone position. The accuracy data were not reported separately for each group, but the authors commented that patient position did not affect the biopsy procedure.
Clinician and facility factors
Barreto et al. 1991 [2044776] | Freehand | Operator experience | Operator inexperience appeared to be related to misdiagnosis.
Pfarl et al, 2002 [12438044] | Stereotactically guided, vacuum-assisted | Operator experience | For 6 of the seven false-negatives, the biopsy had been performed by an operator who had previously performed fewer than 15 stereotactic-guided biopsies.
Ciatto et al. 2007 [16823506] | Multiple methods | Operator experience | Sensitivity of core needle biopsies improved as the operators (radiologists) gained experience, from 88% in the first year of the study to 96% in the eighth year of the study.

BI-RADS = Breast Imaging-Reporting and Data System; PMID = PubMed identification number.

#### Meta-Regression Analyses

Meta-regression analyses were possible for the following factors: needle gauge, choice of reference standard, the proportion of lesions that were palpable, country where the study was performed, whether multiple centers contributed patients to a study, study design, and risk of bias. All models accounted for the biopsy method used (i.e., imaging guidance method and type of device) and the population’s risk of cancer (average vs. high). Table 7 summarizes the findings of the meta-regression analyses. The credible intervals for all examined factors included the null value (indicating the lack of difference in sensitivity or specificity), with the exception of increased sensitivity in studies conducted in the United States (vs. any other country); and higher specificity in studies using followup of 6 to 24 months (as compared to studies using surgical pathology results for all patients) and studies with a prospective design (as compared to studies with a retrospective design). These results must be interpreted with caution, because they rely on indirect comparisons across studies. Furthermore, because these results represent odds ratios for test performance outcomes that are close to 1 (e.g., sensitivity and specificity for all tests were above 0.9), readers should keep in mind that small differences among subgroups of studies can result in (very) large odds ratio values. For example, if the summary sensitivities in two subgroups are 0.99 and 0.98, the odds ratio for sensitivity is approximately 2 ≈ (0.99/0.01)/(0.98/0.02).

Table 7 Meta-regression analysis for test performance outcomes

Modifier Category | Potential Modifier | Comparison | Relative Odds for Sensitivity (95% CrI) | Relative Odds for Specificity (95% CrI)
Biopsy procedure factors | Needle gauge | 14G vs <14G | 0.55 (0.12, 2.26) | 1.59 (0.57, 5.41)
Biopsy procedure factors | Needle gauge | ≥15G vs. <14 | 0.35 (0.07, 1.66) | 0.46 (0.12, 1.74)
Biopsy procedure factors | Needle gauge | Unclear/NR vs. <14G | 0.92 (0.28, 2.71) | 2.69 (1.12, 6.63)
Biopsy procedure factors | Reference standard | ≥2 yrs vs. open biopsy | 1.84 (0.74, 4.35) | 1.42 (0.75, 2.54)
Biopsy procedure factors | Reference standard | 6 mo to 2 yrs vs. open biopsy | 1.59 (0.75, 3.49) | 1.84 (1.05, 3.35)
Lesion factors | Lesion palpability^*^ | >80% palpable lesions vs. ≤80% | 1.04 (0.36, 2.88) | 0.96 (0.37, 2.00)
Lesion factors | Lesion palpability^*^ | palpability NR vs. ≤80% | 0.94 (0.36, 2.39) | 0.93 (0.40, 1.88)
Clinician and facility factors | Country where the study was performed | United States vs. other countries | 1.79 (1.02, 3.15) | 0.96 (0.63, 1.49)
Clinician and facility factors | Multicenter study | ≥1 centers vs. single center | 1.34 (0.49, 3.65) | 1.11 (0.56, 2.29)
Clinician and facility factors | Study design | Prospective vs. retrospective | 1.36 (0.70, 2.73) | 2.11 (1.33, 3.37)
Clinician and facility factors | Study design | Unclear/NR vs. retrospective | 0.95 (0.50, 1.88) | 2.07 (1.29, 3.30)
Study risk of bias | | Intermediate vs. high | 0.56 (0.19, 1.52) | 1.27 (0.61, 2.32)
Study risk of bias | | Low vs. high | 0.56 (0.17, 1.67) | 1.66 (0.78, 3.35)

* Excluding studies of freehand biopsy (because all lesions in such studies were palpable).

Relative odds for sensitivity compare the odds of a positive test result among patients with cancer over the levels of the modifier. Relative odds for specificity compare the odds of a negative test among patients without cancer over the levels of the modifier. Both metrics are obtained from the bivariate meta-analysis model and are exponentiated coefficients from logistic regression; thus, they can be interpreted as odds ratios. Results were adjusted for biopsy technique and baseline risk of breast cancer (high vs. average). CrI = credible interval; NR = not reported; yrs = years.

### Risk of Bias Assessment for Studies Addressing Key Question 1

Overall, on the basis of 14 items related to risk of bias, we deemed 12 studies to be at low risk of bias, 111 to be at moderate risk of bias, and 37 to be at high risk of bias. Given our relatively strict selection criteria related to study design and completeness of followup, it is not surprising that the majority of studies reported enrolling consecutive or randomly selected patients (66 percent), were successful in enrolling 85 percent of all eligible patients (63 percent), and reported complete data on at least 85 percent of all enrolled patients (71 percent). However, only 41 percent of studies were judged to be free of spectrum bias, 68 percent were conducted retrospectively (or did not report relevant information), and 84 percent did not apply a “gold” standard reference test on all patients. In most studies (86 percent) the index test was interpreted by readers blinded to the reference standard test results. However, the vast majority of studies (99 percent) either did not provide information on whether index test results were available to interpreters of the reference standard or reported that blinding was not used. Finally, information on the incorporation of clinical information in the interpretation of the index and reference standard tests was judged inadequate in the majority of studies (99 percent for both items).

## Key Question 2 In women with a palpable or nonpalpable breast abnormality, what are the adverse events (harms) associated with core needle breast biopsy compared to the open biopsy technique in the diagnosis of breast cancer?

This section summarizes findings from a total of 144 studies (70 new studies and 74 from the original evidence report) reporting information on at least one of the outcomes relevant to Key Question 2.^35, 39, 41, 42, 45–47, 49, 53, 58, 62, 63, 67, 73, 75, 78, 80, 82–84, 87, 91–93, 96, 98, 102–104, 107, 108, 110, 113, 117, 121, 123, 125–131, 135–137, 141, 143, 148–151, 153, 155, 157, 161–163, 165, 167, 168, 170, 173–176, 178, 181, 182, 184, 186–188, 190, 192–261^ Overall, studies were considered to be of low to moderate risk of bias. Of note, 76 of the 160 core needle biopsy studies included in Key Question 1 did not provide any information on adverse events, and thus do not allow us to determine whether any adverse events were observed (and not reported). As such, they are uninformative for this Key Question. Further, selective outcome reporting was considered likely for all adverse events examined, because of the large proportion of studies with unclear or missing data.

### Adverse Events of Open Biopsy

Very few of the included studies reported information about complications associated with open surgical biopsy. The original evidence report reported findings from a study published in 1993 and a narrative review published in 2007. The study found that 10.2 percent of a series of 425 wire-localized open biopsy procedures were complicated by vasovagal reactions.235 The narrative review reported that 2 to 10 percent of breast surgeries are complicated by hematoma formation, and that 3.8 percent are complicated by infections.250 The original evidence report also identified two studies on core needle biopsy with information on adverse events of open biopsy. One study reported that 6.3 percent of open surgical biopsies were complicated by infections.192 A second study reported that 2.1 percent of open biopsy procedures were complicated by the development of an abscess, but none of the 234 ultrasound-guided vacuum-assisted core needle procedures had abscess development.125 Finally, we found one study reporting that four of 100 surgical biopsies required repeat biopsy compared to two of 100 vacuum-assisted core needle biopsies35 and one study reporting low levels of pain with open biopsy when local lidocaine was used.259

### Adverse Events of Core Needle Biopsy

We identified 141 studies reporting information on at least one of the adverse events of interest following core needle biopsy (69 new studies and 72 from the original evidence report). Of these studies, 26 reported information related to the dissemination or displacement of cancerous cells during the biopsy procedure, and 112 allowed for the calculation of event rates for hematomas, bleeding, vasovagal reactions, and infections. Table 8 summarizes information for the incidence of these adverse events. Overall, their incidence was low: in more than 50 percent of studies reporting information, the percentage of patients experiencing each of the aforementioned outcomes was less than 2 percent; in 75 percent of studies the event rate was less than 1 percent for infections, less than 5 percent for bleeding and vasovagal reactions, and less than 9 percent for hematoma formation. Results for these outcomes, stratified by biopsy technique, are discussed below. Information on less commonly reported adverse events (including seeding) is summarized narratively in the following sections.

Table 8 Adverse events associated with core needle biopsy for breast cancer diagnosis

Outcome | Number of Studies^*^ | Number of Procedures | Median % of Procedures Where an Event Was Observed (25^th^ – 75^th^ percentile) | Minimum-Maximum Percentage of Procedures Where an Event Was Observed
Hematoma | 58 | 32,584 | 1.44 (0.25–8.57) | 0.00–100.00
Bleeding | 46 | 21,545 | 1.21 (0.33–3.97) | 0.00–100.00
Bleeding requiring treatment | 47 | 22,600 | 0.00 (0.00–0.14) | 0.00–6.45
Infection | 40 | 25,688 | 0.00 (0.00–0.33) | 0.00–2.91
Vasovagal reaction | 39 | 14,482 | 1.27 (0.37–3.88) | 0.00–10.90

* Number of studies providing information on the outcome

max = maximum; min = minimum; perc. = percentile.

### Hematomas and Bleeding

Fifty-eight studies including 32,584 core needle biopsy procedures reported information on hematoma formation. In 50 percent of these studies the event rate for hematomas was less than 1.44 percent, and in 75 percent the event rate was less than 8.57 percent. The highest rates of hematoma formation were observed in studies of vacuum-assisted procedures. For example, in 75 percent of studies of ultrasound-guided vacuum-assisted procedures, the event rate for hematomas was 23.24 percent or greater, while no hematomas were reported in three studies of ultrasound-guided biopsies without vacuum assistance. The median hematoma event rate for studies of stereotactic-guided vacuum-assisted biopsies was 1.59 percent, whereas the maximum event rate in studies of stereotactic-guided biopsies without vacuum-assistance was 1.25 percent. Due to incomplete (and potentially selective) reporting, these percentages should be interpreted with caution; however, vacuum-assisted procedures do appear to have a higher rate of hematoma formation than other core needle biopsy methods. Eight cohorts (reported in a total of 5 studies) of ultrasound-guided vacuum-assisted biopsy identified for this update reported that in 1,487 procedures only one hematoma required surgical intervention.219 The event rates in these studies was similar to the event rate for hematomas requiring treatment calculated across 24 studies included in the original evidence report. No other newly identified studies reported information on the number of hematomas requiring treatment.

Forty-six studies of 21,545 core needle biopsy procedures reported information on bleeding. In 50 percent of these studies the event rate for bleeding was less than 1.21 percent, and in 75 percent the event rate was less than 3.97 percent. In 25 percent of studies of stereotactic-guided vacuum-assisted procedures the event rate for bleeding was 3.75 percent or greater, while the maximum event rate reported in studies of stereotactic-guided biopsies without vacuum assistance was 1.55 percent. The highest event rate in studies of ultrasound-guided vacuum-assisted biopsy was just under 8 percent, while the single study of ultrasound-guided biopsy without vacuum assistance that contained information on bleeding reported an event rate of 5.26 percent. With the same caveats as for hematoma formation, vacuum-assisted procedures appeared to be associated with bleeding more often than nonvacuum-assisted procedures. Overall, bleeding was a rare complication. In addition to the studies reporting bleeding, we identified one study in which 19 percent of 1177 patients undergoing ultrasound guided vacuum-assisted biopsy had skin ecchymosis without hematoma.219 One study of stereotactic-guided vacuum-assisted biopsy identified in our updated searches reported that of 485 women biopsied, one patient was observed in the hospital for one day due to persistent bleeding. A second study of stereotactic-guided vacuum-assisted biopsy identified in our updated searches reported that of 64 women undergoing stereotactic-guided vacuum-assisted biopsy, one patient required surgery to stop bleeding.170 The event rates in these two studies are consistent with the 0.34 percent of vacuum-assisted procedures reported in the previous report to be complicated by bleeding that required treatment. No other newly identified studies reported information on bleeding events that required treatment. Overall, 47 studies provided information on bleeding events that required additional treatment; more than half of the studies reported than no bleeding events requiring treatment were observed and the rate was lower than 0.14 percent in 75 percent of the studies.

Nine studies of various core needle techniques that were included in the original report specified that bruising occurred after core needle biopsy procedures. Three of the nine reported that bruising was a common event, two reported that approximately 50 percent of patients had bruising, and four studies reported that 45 out of 976 patients (4.6%) had severe bruising. We identified two additional studies that reported information on bruising. One study of stereotactic-guided biopsy without vacuum assistance noted that 1.2 percent of 200 patients reported tenderness, swelling or bruising at the biopsy site following the biopsy.67 The second study reported that 2 of 101 patients undergoing stereotactic vacuum-assisted biopsy experienced mild bruising that resolved without treatment.207

Table 9 summarizes information on hematomas and bleeding (total and cases requiring treatment), stratified by biopsy technique.

Table 9 Core needle biopsy procedures and rates of hematoma formation and bleeding

Outcome | Biopsy Technique | N Studies | Number of Procedures | Median % of Procedures Where an Event Was Observed (25^th^ to 75^th^ percentile) | Minimum-Maximum Percentage of Procedures Where an Event Was Observed
Hematoma formation | all devices | 58 | 32,584 | 1.44 (0.25–8.57) | 0.00–100.00
Hematoma formation | freehand, automated | 2 | 1,487 | 0.00–0.00
Hematoma formation | US, automated | 3 | 937 | 0.00–3.24
Hematoma formation | US, vacuum-assisted | 8 | 3,291 | 13.20 (3.76–23.24) | 0.99–36.27
Hematoma formation | stereotactic, automated | 5 | 1,706 | 0.97 (0.77–1.00) | 0.00–1.25
Hematoma formation | stereotactic, vacuum-assisted | 22 | 12,345 | 1.59 (0.69–8.57) | 0.00–100.00
Hematoma formation | MRI, automated | 2 | 116 | NA | 1.33–4.88
Hematoma formation | MRI, vacuum-assisted | 1 | 58 | NA | 43.10
Hematoma formation | other | 15 | 12,644 | 1.07 (0.00–7.20) | 0.00–79.12
Bleeding | all devices | 46 | 21,545 | 1.21 (0.33–3.97) | 0.00–100.00
Bleeding | freehand, automated | 3 | 1,732 | NA | 0.14–3.97
Bleeding | US, automated | 1 | 190 | NA | NA
Bleeding | US, vacuum-assisted | 6 | 2,251 | 2.52 (1.14–4.95) | 0.70–7.84
Bleeding | stereotactic, automated | 5 | 1,144 | 0.48 (0.00–1.29) | 0.00–1.55
Bleeding | stereotactic, vacuum-assisted | 19 | 13,584 | 0.78 (0.30–3.75) | 0.14–26.94
Bleeding | MRI, automated | 0 | 0 | NA | NA
Bleeding | MRI, vacuum-assisted | 1 | 10 | 0.00 | 0.00
Bleeding | other | 11 | 2,634 | 2.10 (0.44–4.24) | 0.00–100.00
Bleeding requiring treatment | all devices | 47 | 22,600 | 0.00 (0.00–0.14) | 0.00–6.45
Bleeding requiring treatment | freehand, automated | 3 | 1,732 | NA | 0.00–0.00
Bleeding requiring treatment | US, automated | 2 | 1,152 | NA | 0.00–0.00
Bleeding requiring treatment | US, vacuum-assisted | 7 | 2,321 | 0.00 (0.00–1.14) | 0.00–4.95
Bleeding requiring treatment | stereotactic, automated | 3 | 496 | NA | 0.00–0.00
Bleeding requiring treatment | stereotactic, vacuum-assisted | 18 | 13,452 | 0.00 (0.00–0.20) | 0.00–3.03
Bleeding requiring treatment | MRI, automated | 0 | 0 | NA | NA
Bleeding requiring treatment | MRI, vacuum-assisted | 1 | 10 | 0.00 | NA
Bleeding requiring treatment | other | 13 | 3,437 | 0.00 (0.00–0.00) | 0.00–6.45

We only report the minimum and maximum percentage of events when three or fewer studies were available for a biopsy technique. When a single study reported information we simply list the percentage of procedures associated with complications. MRI = magnetic resonance imaging; NA = not applicable; US = ultrasound.

### Infections

Across 40 studies, including 25,688 core needle procedures, the median percentage of infectious complications was 0.00 percent. One study, identified by the original evidence report, reported that a patient developed an abscess that required surgical treatment in a series of 268 stereotactically guided vacuum-assisted procedures.168 One study identified by this update reported that 2 of 118 patients undergoing stereotactic vacuum-assisted biopsy developed infections that required antibiotics.248 Table 10 summarizes information on infections, stratified by biopsy technique.

Table 10 Core needle biopsy procedures and rates of infectious complications

Biopsy Technique | N Studies | Number of Procedures | Median % of Procedures Where an Event Was Observed (25^th^ – 75^th^ percentile) | Minimum-Maximum Percentage of Procedures Where an Event Was Observed
All devices | 40 | 25,688 | 0.00 (0.00–0.33) | 0.00–2.91
Freehand, automated | 3 | 1,637 | NA | 0.00–2.00
US, automated | 4 | 1,675 | 0.05 (0.00–0.92) | 0.00–1.74
US, vacuum-assisted | 4 | 1,962 | 0.00 (0.00–0.99) | 0.00–1.98
Stereotactic, automated | 10 | 2,321 | 0.00 (0.00–0.63) | 0.00–2.91
Stereotactic, vacuum-assisted | 9 | 4,803 | 0.00 (0.00–0.20) | 0.00–0.89
MRI, automated | 0 | 0 | NA | NA
MRI, vacuum-assisted | 0 | 0 | NA | NA
Other techniques | 10 | 13,290 | 0.10 (0.00–0.26) | 0.00–2.20

We only report the minimum and maximum percentage of events when three or fewer studies were available for a biopsy technique. MRI = magnetic resonance imaging; NA = not applicable; US = ultrasound.

### Pain and Use of Pain Medications

The original report identified three vacuum-assisted biopsy procedures reported to have been terminated after patients complained of severe pain, and we identified one study of 4086 stereotactic-guided vacuum-assisted procedures in which four biopsies were suspended due to pain.233 No studies reported procedure termination due to patient complaints of pain in any other types of biopsy procedures. Twenty-five studies of a wide variety of biopsy methods reported information about patient pain during the procedure (pain was assessed heterogeneously and for that reason we did not calculate overall event rates).

Eleven studies reported information on the use of pain medications. One of these studies reported that 100 percent of patients were sent home with narcotics after an open biopsy procedure, and only three patients required narcotics after a core needle procedure.102 Twenty patients were reported to have required acetaminophen after a core needle procedure.125 Note that being sent home with a medication may not necessarily mean the patients required or used the medication.

### Vasovagal Reactions

Thirty-nine studies with 14,482 procedures reported information about the occurrence of vasovagal reactions (fainting or near-fainting) during core needle biopsy. The median event rate in these studies was 1.27 percent, although one study reported an event rate of nearly 11 percent. More than 40 percent of the vasovagal reactions occurred in patients who were reported to have been positioned sitting upright for the biopsy procedure (many of the studies did not report patient position so the other 60 percent of vasovagal reactions could have occurred in patients positioned in a variety of positions, or could have occurred primarily in seated patients).

Table 11 summarizes information on vasovagal reactions, stratified by biopsy technique.

Table 11 Core needle biopsy procedures and rates of vasovagal reactions

Biopsy Technique | N Studies | Number of Procedures | Median % of Procedures Where an Event Was Observed (25^th^ – 75^th^ percentile) | Minimum-Maximum Percentage of Procedures Where an Event Was Observed
All devices | 39 | 14,482 | 1.27 (0.37–3.88) | 0.00–10.90
Freehand, automated | 1 | 1,431 | NA | 0.00–0.00
US, automated | 2 | 235 | NA | 0.53–8.89
US, vacuum-assisted | 3 | 2,532 | NA | 0.43–1.43
Stereotactic, automated | 12 | 1,978 | 1.44 (0.51–3.47) | 0.00–8.33
Stereotactic, vacuum-assisted | 13 | 5,843 | 1.90 (0.34–5.41) | 0.00–10.90
MRI, automated | 0 | 0 | NA | NA
MRI, vacuum-assisted | 1 | 10 | NA | 0.00
Other techniques | 7 | 2,453 | 1.78 (0.99–2.20) | 0.00–3.47

We only report the minimum and maximum percentage of events when three or fewer studies were available for a biopsy technique. When a single study reported information we simply list the percentage of procedures associated with complications. MRI = magnetic resonance imaging; NA = not applicable; US = ultrasound.

### Impact of Biopsy Procedure on Usual Activities and Time to Recovery

Three studies provided information on the impact of biopsy procedures on usual activities. The first study reported that of 34 women undergoing ultrasound-guided vacuum-assisted breast biopsy, 16 (47%) women stated that the procedure did not interfere with usual activity, 14 (41%) stated that there was minor interference, and four (12%) felt that there was mild interference.125 The second study reported four cases in which the patient felt constrained in her daily life due to the procedure.216 The third study reported vacuum-assisted biopsy results in less psychological/physical stress when compared to surgical procedures.35

A single study provided information regarding time to recovery, measured by asking patients how long it had taken for them to return to their normal activities after the biopsy procedure.80 This study reported that the average time of recovery was 3.5 days for open biopsy procedures and 1.5 days for stereotactically guided automated gun core needle biopsy procedures.

### Impact of Biopsy Procedure on Subsequent Mammographic Procedures

Five studies reported information about the impact of core needle biopsies on subsequent mammographic examinations. Three studies reported on stereotactic-guided vacuum-assisted core needle procedures. These studies enrolled 3,748 patients, of whom 3,345 (89.2%) were reported to have no mammographically visible scarring after the biopsy procedure. Only seven of the patients were reported to have scars that were potentially diagnostically confusing on subsequent mammographic procedures. In the fourth study, 91 patients underwent stereotactic- or ultrasound-guided vacuum-assisted core needle biopsy. The researchers reported that at 6-month followup there was no evidence of scarring, architectural distortion, alterations of the skin, fat necrosis, or other changes that are frequently observed after surgical breast biopsy.216 In the fifth study, patients underwent mammography at 6 or 12 months, and the authors reported that mammograms showed structural distortions at the biopsy site in the 100 women who underwent surgical biopsy, and no sequelae in the 100 women who received vacuum-assisted core needle biopsy.35

### Miscellaneous Reported Adverse Events

The original report identified eight studies with information on pneumothorax, seizures, vomiting, or acute inflammation, and we identified one additional study reporting vomiting and one additional study reporting inflammation. Four studies of 2,600 patients reported that four cases of pneumothorax, none of which required treatment, had occurred. None of these four studies used the same core needle biopsy method. Two studies reported that one patient per study (out of 3,487 patients in total) had suffered a seizure during a stereotactic-guided vacuum-assisted procedure. One study of 268 patients undergoing stereotactic-guided vacuum-assisted biopsies reported that three patients developed acute inflammation at the biopsy site after the procedure. One study of 485 women undergoing stereotactic-guided vacuum-assisted biopsies reported that two patients developed signs of inflammation judged to be mastitis. Two studies reported that a patient vomited during the procedure; one of these studies was of 185 stereotactic-guided vacuum-assisted procedures and the second was of 236 vacuum-assisted procedures using either stereotactic or ultrasound guidance. We did not identify any new studies reporting any other significant adverse events associated with core biopsy procedures.

### Dissemination and Displacement of Cancerous Cells During the Biopsy Procedure

To address the potential dissemination or displacement of cancerous cells by breast biopsy we did not use the study-design evaluation criteria for Key Questions 1 and 2; instead, we considered any clinical study that addressed the topic (including case reports and case series). Full details of the included studies are available in SRDR.

We reviewed 14 studies that used histopathology to demonstrate dissemination or displacement of cells by core needle biopsy procedures (four new studies and 10 studies included in the original report). Nine studies had a cohort design, and five were case series or case reports.

The percentage of needle tracks previously reported to contain displaced cancerous cells ranged from 0 to 65 percent. We identified a cohort study that reported that the percentage of ultrasound-guided biopsies with cancerous cells in the needle wash material ranged from 33 percent to 69 percent.244 The original report observed that the risk of finding displaced cancerous cells was increased by greater duration of the biopsy procedure,230 multiple needle passes,243 and a short interval between core needle biopsy and surgical excision,205 while the risk was decreased by diagnosis of invasive lobular carcinoma243 and the use of vacuum-assisted core needle biopsy.205 The incidence of positive cytological findings in needle wash material was also greater with multiple needle passes and automated device (versus vacuum-assisted) biopsy.244

Although the clinical significance of these displaced cancerous cells is debated,205 we found four case reports of patients developing tumors at the site of prior core needle biopsies, which supplement the six case reports previously identified for this review.199, 201, 218, 224, 246 Four of these ten women were reported to have not received radiation therapy for the primary tumor; for the other six women it was not reported whether they had received radiation therapy.

The previous evidence report found four studies with 1,879 women that explored the risk of tumor recurrence following biopsy.202, 208, 220, 221 Three of these four studies reported that women who did not have a preoperative needle biopsy had a higher rate of tumor recurrence than women who did receive a preoperative needle biopsy;202, 208, 221 the fourth study reported the opposite. We identified an additional cohort study, published in 2011, that reported no development of tumors along the needle track among more than a thousand women receiving a core needle biopsy diagnosis of cancer in early 2008 through 2009.^253^ The majority of the women in the original four studies were treated with breast-conserving surgery and radiation therapy; the newly identified fifth study did not report whether women received radiation therapy.

The original evidence report found three studies with 3,103 women that investigated the risk of seeding the lymph nodes with cancerous cells after biopsy procedures.210, 232, 234 Two of the three studies reported that the method of biopsy did not affect the rate of positive sentinel lymph nodes; the third study reported that the rate of metastases to the sentinel lymph node was higher in women who underwent some form of preoperative biopsy. We found two new studies examining the topic of epithelial cell displacement into lymph nodes after biopsy. One study described 15 cases of epithelial cell displaced into the lymph node subcapsular sinus in a series of axillary lymph node dissections taken approximately 2 weeks after either core needle or open breast biopsy.200 The authors stated that this was probably the result of mechanical transport of cells during biopsy and that the clinical implications are likely not significant. The second study examined epithelial displacement into lymphovascular spaces in the breast core needle biopsy specimens of seven women who were diagnosed with pure DCIS after core needle biopsy and surgical excision.222 These women did not have recurrences or metastases after 24 to 84 months followup. The authors suggest that because this epithelial displacement is seen in the initial core biopsy sample, the presence of tumor cell clusters in lymphovascular spaces may not reflect lymphovascular invasion.197

The original evidence report identified a case series report of 25 cases of false-positive sentinel lymph nodes, in which the false-positives appeared to be caused by displacement of benign epithelial cells during a biopsy procedure.197 Twelve of the false-positive cases had undergone core needle biopsy prior to the sentinel lymph procedure, 12 had undergone wire-localization open biopsy, and one had undergone a fine-needle aspiration procedure. Findings of false-positive sentinel lymph nodes are clinically important because the findings are likely to lead to adverse events from unnecessary treatment. Because 22 of the 25 cases had intraductal papilloma at the biopsy site, the authors of the case series report suggested using caution when interpreting sentinel lymph node histopathology in cases where intraductal papilloma was noted during the initial biopsy procedure.

### Factors That Modify the Association of Biopsy Procedures With Adverse Events

Due to the small number of studies providing information on any of the factors of interest and the poor reporting of adverse events across studies, we believe that the evidence is insufficient to establish any specific factor (other than patient positioning for vasovagal events and the use of vacuum for bleeding, as discussed in preceding sections) as a determinant of the rate of adverse events among women undergoing biopsy for breast cancer diagnosis. Information extracted from individual studies is summarized in Table 12.

Table 12 Studies evaluating factors that may affect the incidence of adverse events

Author, Year [PMID] | Biopsy Technique | Factors Evaluated | Key Findings
Patient and lesion factors
Lin et al., 2000 [not indexed] | Ultrasound guided vacuum-assisted | Breast density | Among 8 women with hematomas and pre-biopsy mammograms, 75% had breasts classified as dense. No patients with breasts classified as fatty developed hematomas.
Wang et al., 2012 [21300503] | Ultrasound guided vacuum-assisted | Lesion size | No statistically significant difference was observed in mean lesion size for cases with and without hematoma.
Zografos et al. 2008 [18814132] | Stereotactic-guided vacuum-assisted | BI-RADS classification, patient age | There was no statistically significant association between hematoma formation and BI-RADS classification or patient age.
Frank et al., 2007 [17661855] | Stereotactic-guided automated gun | Patient age | Pain was not associated with patient age (p=0.11).
Chetlen et al., 2013 [23789678] | Multiple methods | Medications received at the time of biopsy | Non–clinically significant hematomas developed in 22 of 102 (21.6%) procedures performed on patients taking antithrombotic medications vs. 67 of 515 procedures (13.0%) performed on patients not on antithrombotic therapy. The probability of development of a non–clinically significant hematoma was 21.6% in association with antithrombotic therapy and 13.0% without antithrombotic therapy (p = 0.025). This finding was confirmed in multivariable logistic regression analysis. The mean log volume of hematoma in patients taking antithrombotics did not differ significantly from that in patients not taking antithrombotics (p = 0.126). In analyses adjusted for needle size, the association of antithrombotic treatment with log volume remained nonstatistically significant (p = 0.07).
Procedural factors
McMahon et al. 1992 [1422715] | Freehand | Needle gauge | 18G core needle procedure were associated with significantly less pain than 14G core needle procedures, but there was no significant difference in pain between 14G and 16G procedures.
Wong and Hisham 2003 [484085] | Freehand | Needle gauge | No difference in the amount of pain experienced by patients undergoing a 14G core needle procedure vs. a 16G core needle procedure.
Zagouri et al., 2011 [21709018] | Stereotactic-guided vacuum-assisted | Number of cores | In women who underwent additional sampling (96 cores vs. the standard 24–36), the rate of clinically significant hematomas doubled from 3.5% to 7.5%.
Frank et al., 2007 [17661855] | Stereotactic-guided automated gun | Number of cores, duration of procedure | Pain was associated with the number of biopsy cores (p=0.032) and the duration of the procedure (p=0.046).
Schaefer et al., 2012 [22381441] | Multiple methods | Needle gauge; biopsy device | There were significantly higher rates of bleeding (p<0.001) and hematoma (p=0.029) in the Mammotome 8G than in the Mammotome 11G group. There were no significant differences in bleeding rates (p=0.799) or hematoma rates (p=0.596) between the ATEC 12G and the ATEC 9G group. There were no significant differences in bleeding or hematoma rates in the Mammotome 8G group and the ATEC 9G group, but there was less bleeding (p=0.015) and fewer hematomas (p=0.001) in the Mammotome 11G group than in the ATEC 12G group.
Seror et al., 2012 [21310570] | Multiple methods | Needle gauge/probe | There was no difference in pain with different probe sizes (12 mm, 15 mm, and 20 mm).
Szynglarewicz et al., 2011 [21367573] | Multiple methods | Vacuum-assistance; biopsy device | Biopsy with an automated device was significantly more painful than biopsy with a vacuum-assisted hand-held device (p<0.01).
Chetlen et al., 2013 [23789678] | Multiple methods | Needle gauge; number of cores | The proportion of hematoma formation after biopsy with 9G needles was 29.5% vs. 3.6% after biopsy with 12G or 14G needles (the difference was statistically significant and remained significant in multivariable logistic regression analysis). The mean log volume of hematoma comparing larger versus smaller gauge needles was not statistically significantly different (p = 0.08). In analyses adjusted for antithrombotic treatment, the association of needle size with log volume became statistically significant (p = 0.048). The paper stated that the mean and median numbers of tissue samples obtained from patients who developed and those who did not develop a hematoma were not statistically significantly different. However the reported p-values were both statistically significant (p < 0.001). The authors noted that the number of tissue samples was strongly correlated with needle gauge.
Clinician and facility factors
Kirshenbaum et al., 2003 [12876040] | Multiple methods | Operator experience | The majority of vasovagal reactions occurred when inexperienced operators performed the biopsy procedures.

PMID = PubMed identification number.

## Key Question 3 How do open biopsy and various core needle techniques differ in terms of patient preference, availability, costs, availability of qualified pathologist interpretations, and other factors that may influence choice of a particular technique?

We identified 59 new studies35, 41, 43, 49, 62, 78, 86, 96, 118, 121, 134, 137, 138, 142, 163, 170, 174, 198, 206, 211, 213, 217, 226, 229, 236, 239, 255, 259, 262–292 that addressed various aspects of KQ3. Together with the 84 studies39, 42, 46, 47, 50, 54, 58, 73, 75, 91, 104, 107, 115–117, 125, 127, 141, 143, 149, 167, 181, 182, 184, 188, 230, 249, 293–349 included in the original evidence report, this section synthesizes evidence from 143 studies. Generally, our findings confirmed those of the original evidence report. In the following sub-sections, we first discuss aspects of diagnostic biopsy important to patients, followed by economic factors that may influence the choice of a particular technique, and then proceed to summarize information on other factors, including the availability of equipment, procedure duration time, time to complete tumor removal, wait time for test results, and recurrence rates. Because of the nature of this Key Question and the heterogeneity of the sources of information used to address each outcome of interest, we did not attempt to grade the strength of evidence for most outcomes considered for this Key Question (this is consistent with the original evidence report).

### Anxiety and Distress

We identified 12 studies35, 121, 198, 211, 226, 266, 268, 276, 281, 282, 286, 288 that looked at levels of anxiety and distress related to biopsy procedures. This outcome was not specifically examined in the original report, and we base our conclusions on the studies retrieved for this update. Overall, patients reported increased levels of anxiety and distress immediately before or during the procedure, and these levels were reduced after the procedure. One study reported mean anxiety levels just before the procedure to be well above normal on State Trait Anxiety Inventory (STAI) (mean 48; normal=35.9), Impact of Event Scale (mean 26; normal < 8.5), Center for Epidemiological Studies-Depression Scale (mean 16; normal 8), and Perceived Stress Scale (mean 19; normal=12.6).268 This was corroborated by a second study that reported participants prebiopsy STAI-S and STAI-T T scores were two standard deviations higher than the mean T score (T-score mean 50, SD 10).281 Yet another study reported that one procedure out of 602 could not be completed because of patient anxiety.121 One study found greater anxiety in surgical biopsy patients than in those receiving core needle vacuum-assisted biopsies.

Four studies,226, 266, 282, 288 three of which were randomized controlled trials, looked at a range of options to ameliorate stress during core needle biopsy procedures, with relaxation, medication, empathy, and hypnosis all showing reductions in stress either just before or during the procedure. One randomized controlled trial reported on stress levels in three groups of patients (those receiving usual care, relaxation, or medication to reduce anxiety). All three groups had preprocedural state anxiety levels that were significantly higher than normal and reported significant reductions in anxiety 24 hours after the procedure. Patients in the medication group reported significantly less anxiety during the procedure, when compared with the usual care and relaxation groups.266 They also reported that there was no statistically significant difference in anxiety levels during the procedure for those who underwent stereotactically guided versus ultrasound-guided procedures.266 A second randomized controlled trial looked at the use of empathy and hypnosis in relieving anxiety. The authors found that standard care patients experienced an increase in anxiety during the procedure, patients who were given empathy experienced no change in anxiety during the procedure, and patients receiving hypnosis experienced a decrease in anxiety during the procedure. A final randomized controlled trial reported that the main effect of an education intervention on anxiety was that those in the control group tended to have lower postconsultation anxiety than those in the education group.

### Procedure Preference

We found two studies198, 286 that specifically addressed procedure preference in addition to the 20^39, 46, 58, 73, 91, 125, 181, 182, 299, 303, 304, 306, 309, 311, 312, 317, 321, 322, 331, 347^ in the original evidence report. Both of the new studies reported a positive experience with core needle biopsy, relative to surgical biopsy. One study reported that women who had previously experienced only core needle or surgical biopsy were willing to wait a median of 3.2 weeks longer to avoid surgical than to avoid core needle biopsy; while women who had experienced both were willing to wait 2.4 weeks longer to avoid surgical than to avoid core needle biopsy.286 This supports the findings of the original report: the majority of studies reported core needle biopsies to be preferable to open biopsies. However, a single study reported the reverse: a survey of 59 patients (20 open biopsy, 20 fine needle aspiration, and 19 core needle biopsy) from Detroit, Michigan in 1997 and 1998 found that 90 percent were satisfied with their open surgical biopsy compared to only 80 percent satisfied with a vacuum-assisted core needle biopsy, though the authors reported that this difference was not statistically significant at the p=0.05 level.299 The original evidence report also noted that the majority of the studies reported such information as that the patients tolerated the procedure well or would recommend it to others in the future. One study reported that 99 percent of image-guided core needle biopsy patients rated their overall experience as positive and 97 percent said they would recommend the center to a family member or friend if they needed a biopsy.198 Another study reported that patients preferred the decubitus position to the prone position.182 Two studies reported that vacuum-assisted procedures were more comfortable than other types of core needle biopsies.317 Two other studies reported that patients lost less time to core needle procedures than to open procedures.309

### Surgical Procedures Avoided

We identified 12 new studies35, 49, 86, 96, 118, 137, 170, 263, 269, 274, 289, 290 providing information on the number of surgical procedures avoided by the use of core needle biopsy methods for breast cancer diagnosis. Including the 30 studies42, 47, 50, 58, 115–117, 143, 167, 293–295, 297, 304, 305, 308, 319, 320, 324, 325, 327, 329, 332, 335, 340, 342, 344–346, 349 considered in the original report, a total of 42 studies provide information on this outcome. In general, studies found that core needle biopsy obviated the need for surgery for a substantial proportion of women, ranging from 29 to 87 percent. Of the 42 studies, ten reported comparisons against open surgical biopsy with respect to the number of patients requiring only one surgical procedure (vs. more than one). Meta-analysis of these studies suggested that the odds of requiring only one surgical procedure were almost 15 times higher among women receiving core needle biopsy; odds ratio = 14.8 (95% CrI, 7.2 to 50.2). This result should be interpreted with caution because of the possibility of confounding by indication. Women may have been selected for a specific diagnostic approach on the basis of clinical or other factors, which may also be associated with the need for additional surgical interventions.

### Cosmetic Results

We identified three new studies that addressed cosmetic results62, 239, 255 with core needle or open biopsy. Two reported that core needle biopsy produced minimal scars that were acceptable to the patients, and the third reported that vacuum-assisted core needle biopsy produced “better cosmetic effects compared to open excision.” 255 The original evidence report identified 10 other studies46, 104, 125, 143, 181, 299, 306, 322, 331, 347 that included information on cosmetic results for vacuum-assisted core needle biopsy and reported that patients were generally satisfied with the cosmetic results. Only one of the 10 studies included in the original report compared a group of patients undergoing core needle biopsy to a group of patients undergoing open biopsy.299 This study reported a greater satisfaction with appearance of the breast 2 years after surgery in core needle patients (95 percent very satisfied) than in open biopsy patients (25 percent very satisfied).299

### Resource Utilization and Costs

We found two additional studies on the relative costs of core needle biopsy.134, 290 The results below reflect a total of ten studies, including eight studies identified in the original report.107, 188, 310, 313, 330, 333, 339, 341 The original report concluded that the costs of surgical biopsy are considerably greater than those of core needle biopsy. In this update we identified one study (2008) reporting average charges for core needle biopsy at $10,500 and excision biopsy at $11,500.^290^ The authors based their costs on the calculation of mean patient charges for initial diagnostic procedure and subsequent necessary surgeries, which were compared for patients undergoing biopsy for BI-RADS-5 lesions between 1998 and 2002. The authors recommend core needle biopsy as the initial diagnostic approach for highly suspicious lesions, based upon improved pathologic margins and fewer surgical procedures rather than significant costs savings.

Another study compared per-procedure costs of core needle biopsy and fine needle biopsy. Based on reimbursements for facility fees, but excluding professional fees, the costs were $477.92 versus $166.34, respectively.134

The original evidence report reported on the relative costs of open surgical biopsy and various core needle biopsy techniques in six studies. The studies reviewed factors that included purchase price of devices, personnel time and costs, the costs of processing and analyzing samples, patient volume, whether the device is used as a complementary procedure, and what mammography results determine the use of a core needle biopsy technique. The original report also noted that MRI-guidance is the most expensive method of performing core needle biopsies.350 We did not find any new studies comparing the costs or cost-effectiveness of different core needle or imaging techniques.

We did not identify any new studies for resource utilization. The two studies discussed in the original evidence report188, 330 stated that vacuum-assisted procedures and procedures that required dedicated prone tables required more physician and room time.

### Physician Experience

We identified seven new studies,265, 271, 277–279, 283, 285 which, together with the 10 studies included in the original report,127, 141, 188, 303, 314, 315, 323, 326, 336, 338 support the conclusions that greater experience with particular devices improves accuracy, shortens procedure duration times, and leads to a decrease in the number of open biopsies. One study reported a trend that indicated that in a training program, the fellows were able to establish an accurate diagnosis with fewer core biopsy samples in their later cases (i.e. as the training progressed and they gained experience).265 A second study introduced a training program for breast lesion excision system biopsy, for which they reported that fellows who had previous experience in vacuum-assisted biopsy could perform the new procedure after four procedures (median), while those without previous exposure showed proficiency after nine procedures (median). This was compared to the 12 procedures required for a new user to become proficient with vacuum-assisted biopsy.278 A survey of 79 fellows who had graduated from approved breast fellowships between 2005 and 2009 reported that many physicians feel poorly prepared to do ultrasound-guided (41 poorly prepared; 16 moderately prepared; 22 well prepared) or stereotactic (57 poorly prepared; 7 moderately prepared; 15 well prepared) core needle biopsies.285 A report of data from the National Accreditation Program for Breast Centers showed that the two most common deficiencies for breast centers were in standards for ultrasound-guided biopsy (24 of 238 centers failed) and for stereotactic core needle biopsy (17 of 238 centers failed).279 Two new studies reported on the effects of training programs. The first reported that residents performed 83 percent of vacuum-assisted biopsies and 86 percent of core needle biopsies successfully after a training program and that their comfort level increased at least one level.271 The other showed that surgeon-directed, multi-year, quality improvement workshops across 12 hospitals improved preoperative core biopsy rates.277

### Availability of a Qualified Pathologist

We did not identify any new studies for this outcome. The two studies included in the original report showed conflicting results, with one reporting that whether the specimen was read by a local or central pathologist had little effect as agreement rates were very high,300 and the second reporting that the pathologist’s lack of experience with the TruCut device explains its poor performance.311

### Availability of Equipment/Utilization

The original report identified three studies reporting on the impact of equipment availability and utilization,301, 344, 348 to which we added four217, 284, 288, 289 more for a total of seven. The original report concluded that wait times are longer for open procedures and dedicated prone biopsy tables. We found a randomized controlled trial that reported that patients who waited 4 days or more for a core needle biopsy procedure were less satisfied than patients who waited 3 days or less (p=0.007).288 We did not find any new studies reporting the overall wait times for core needle biopsies or comparing wait times for core needle vs. open biopsy procedures.

Other studies looked at utilization rates of core needle biopsies over time. One study reported that the nonoperative diagnosis rates in core needle biopsy had increased from 49 percent in 1995/96 to 87 percent in 2000/01 to 94 percent in 2005/06.^289^ A second study reported that with a stable total patient population and constant number of open and needle-localized procedures, stereotactic breast biopsies had increased from 56 in 1995 to 68 in 1996, 118 in 1997, and 172 in 1998.^217^ They further reported that diagnostic yield had increased in the stereotactic era.217 A third study reported a similar increase in core needle biopsy utilization between January 1992 and March 1998, with a corresponding decrease in open biopsies.284

### Procedure Duration Time

We identified an additional 17 studies41, 43, 78, 121, 137, 138, 163, 174, 206, 211, 213, 226, 236, 259, 270, 275, 287 that reported results for procedure duration across various types of biopsy. When these studies are added to the 40 studies39, 42, 46, 47, 50, 54, 58, 73, 75, 91, 141, 143, 149, 181, 182, 184, 188, 230, 249, 296, 298, 302, 303, 307, 309, 316–318, 323, 326, 328, 330, 331, 333, 334, 337, 338, 343, 347, 349 identified in the original evidence report, reported procedure times range between 3 and 128 minutes. This large range is probably the result of different definitions for procedure time. For example, one study reported times for “total procedure” (from signing of informed consent to end of preparation for next patient) as 26.7 minutes for ultrasound guided core biopsy and 47.5 minutes for stereotactic core biopsy; “room time” (from signing of informed consent to end of procedure) as 23.1 minutes for ultrasound guided core biopsy and 36.5 minutes for stereotactic core biopsy; and “physician time” (time radiologist located lesion to time enough samples had been obtained) as 12.3 minutes for ultrasound guided core biopsy and 18.6 minutes for stereotactic core biopsy.287

Mean procedure times for ultrasound-guided core needle biopsies ranged from 3 to 60 minutes, based on 11 original39, 50, 91, 143, 188, 303, 309, 316, 330, 337, 343 and five new studies,206, 213, 226, 270, 287 while stereotactically guided core needle procedures tended to take longer, with mean procedure times ranging from 10 to 100 minutes (15 original42, 46, 54, 58, 75, 91, 141, 175, 181, 182, 296, 316, 317, 330, 349 plus five new studies 137, 174, 211, 236, 287). Twelve studies (four new41, 43, 78, 163 and eight from the original report149, 249, 323, 326, 328, 333, 334, 338 studies) gave mean times for MRI-guided procedures, ranging from 8 to 70 minutes.

Vacuum-assisted core biopsies had reported mean or median durations of 3 to 70 minutes, based on 28 studies (19 original39, 42, 46, 58, 143, 181, 230, 249, 298, 302, 303, 323, 326, 328, 330, 331, 333, 334, 347 and 9 new41, 43, 121, 137, 138, 206, 213, 236, 287). Two studies gave mean times for open procedures, ranging from 40 to 45 minutes depending on tumor size.259, 298

### Time to Complete Tumor Removal

We identified nine studies142, 229, 262, 264, 267, 272, 273, 280, 290 that reported results for time in days from biopsy to surgery for tumor removal. There were no studies addressing this specific outcome in the original report. Overall times from biopsy to tumor removal ranged from 5 to 153 days. One study directly compared wait times for core needle and surgical biopsies, reporting an average time from initial procedure to final surgical procedure for core needle biopsy as 27 days and excisional biopsy as 22 days.290 The rest of the studies gave results for core needle biopsy only, with means ranging from 14 to 62 days and medians ranging from 9 to 83 days. One study reported that the implementation of a Rapid Diagnosis and Support Program reduced the time from biopsy to surgery from 51.54 to 33.36 days.262 A second study reported that excisional biopsy is a factor in the increase in delays between first physician encounter and surgery from 1992 to 2005.^264^

### Wait Time for Test Results

We found seven studies that discussed wait times for core needle biopsy results.142, 198, 262, 272, 273, 291, 292 There were two studies included in the original report, for a total of nine studies addressing this outcome. Overall, core needle wait times ranged from 1 to 114 days, with most reported as between 1 and 1.3 days. The two studies in the original report that compared wait times after core needle and open biopsies showed that wait times for core needle biopsy results are shorter by an average of 7 to 10 days. One study reported that using a microwave processor (a nonstandard processing method that is not in widespread use) to reduce wait times for test results reduced the average wait for results (P<0.001).142 Another study reported that the implementation of a Rapid Diagnosis and Support Program reduced wait times from 3.92 to 3.35 days.262 One study looked specifically at the reasons for diagnostic delays that exceeded 90 days and found that many diagnostic delays were the result of false negative results that were caused by sampling errors.291 Two studies assessed patient satisfaction with wait times. One found that most participants (88 percent) thought the wait for test results (usually the day after the biopsy by phone) was reasonable.198 The other reported an improvement in patient satisfaction scores sense of timeliness of provision of diagnostic test results from 4.5 (of 5) before the implementation of the Rapid Diagnosis and Support Program to 4.75 after its implementation.262

### Recurrence Rates

We found one study that discussed recurrence rates among core needle biopsy patients.213 In this study, 143 lesions in 86 patients were completely excised using an ultrasound-guided Mammotome system. Excision was considered complete when a fluid-filled cavity or air bubbles were demonstrated by ultrasound. Of these 143 lesions, only one lesion recurred within six months. A second biopsy showed breast adenosis, the same diagnosis as the original biopsy.