# References

1 American Cancer Society. Breast Cancer Facts & Figures 2013–2014. Atlanta, GA. American Cancer Society. 2013. www.cancer.org/acs/groups/content/@research/documents/document/acspc-040951.pdf. Accessed March 26, 2014.
2 Hubbard RA, Kerlikowske K, Flowers CI, et al. Cumulative probability of false-positive recall or biopsy recommendation after 10 years of screening mammography: a cohort study. Ann Intern Med. Oct. 18. 2011;155(8):481-92. [pmid: 22007042].
3 Elmore JG, Barton MB, Moceri VM, et al. Ten-year risk of false positive screening mammograms and clinical breast examinations. N Engl J Med. Apr. 16. 1998;338(16):1089-96. [pmid: 9545356].
4 Yu YH, Wei W, Liu JL. Diagnostic value of fine-needle aspiration biopsy for breast mass: a systematic review and meta-analysis. BMC Cancer. 2012;12:41. [pmid: 22277164].
5 Bruening W, Schoelles K, Treadwell J, et al. Comparative Effectiveness of Core-Needle and Open Surgical Biopsy for the Diagnosis of Breast Lesions. Comparative Effectiveness Review No. 19. (Prepared by the ECRI Institute Evidence-based Practice Center under Contract No. 290-02-0019). AHRQ Publication No. 10-EHC007-EF. Rockville, MD. Agency for Healthcare Research and Quality. December. 2009. www.ncbi.nlm.nih.gov/books/NBK45220/pdf/TOC/pdf. Accessed April 25, 2013.
6 Bruening W, Fontanarosa J, Tipton K, et al. Systematic review: comparative effectiveness of core-needle and open surgical biopsy to diagnose breast lesions. Ann Intern Med. Feb. 16. 2010;152(4):238-46. [pmid: 20008742].
7 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. April. 2012. www.effectivehealthcare.ahrq.gov/ehc/products/60/318/MethodsGuide_Prepublication-Draft_20120523.pdf. Accessed April 25, 2013.
8 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. Int J Surg. 2010;8(5):336-41. [pmid: 20171303].
9 Dekkers OM, Egger M, Altman DG, et al. Distinguishing case series from cohort studies. Ann Intern Med. Jan. 3. 2012;156(1 Pt 1):37-40. [pmid: 22213493].
10 Drummond M, Barbieri M, Cook J, et al. Transferability of economic evaluations across jurisdictions: ISPOR Good Research Practices Task Force report. Value Health. Jun. 2009;12(4):409-18. [pmid: 19900249].
11 Ramsey S, Willke R, Briggs A, et al. Good research practices for cost-effectiveness analysis alongside clinical trials: the ISPOR RCT-CEA Task Force report. Value Health. Sep–Oct. 2005;8(5):521-33. [pmid: 16176491].
12 Leeflang MM, Scholten RJ, Rutjes AW, et al. Use of methodological search filters to identify diagnostic accuracy studies can lead to the omission of relevant studies. J Clin Epidemiol. Mar. 2006;59(3):234-40. [pmid: 16488353].
13 Whiting P, Westwood M, Burke M, et al. Systematic reviews of test accuracy should search a range of databases to identify primary studies. J Clin Epidemiol. Apr. 2008;61(4):357-64. [pmid: 18313560].
14 Whiting PF, Rutjes AW, Westwood ME, et al. QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. Oct. 18. 2011;155(8):529-36. [pmid: 22007046].
15 Whiting P, Rutjes AW, Reitsma JB, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. Nov. 10. 2003;3:25. [pmid: 14606960].
16 Whiting P, Rutjes AW, Dinnes J, et al. Development and validation of methods for assessing the quality of diagnostic accuracy studies. Health Technol Assess. Jun. 1. 2004;8(25):iii-234. [pmid: 15193208].
17 Whiting PF, Weswood ME, Rutjes AW, et al. Evaluation of QUADAS, a tool for the quality assessment of diagnostic accuracy studies. BMC Med Res Methodol. Mar. 6. 2006;6:9. [pmid: 16519814].
18 Wells G, Shea B, O’Connell D, et al. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. www.ohri.ca/programs/clinical_epidemiology/oxford.asp. Accessed 29 April 2013.
19 Higgins JP, Altman DG, Gotzsche PC, et al. Cochrane Bias Methods Group/Cochrane Statistical Methods Group. The Cochrane Collaboration’s tool for assessing risk of bias in randomised trials. BMJ. Oct. 18. 2011;343:d5928. [pmid: 22008217].
20 Drummond MF, Jefferson TO. Guidelines for authors and peer reviewers of economic submissions to the BMJ. The BMJ Economic Evaluation Working Party. BMJ. Aug. 3. 1996;313(7052):275-83. [pmid: 8704542].
21 Trikalinos TA, Balion CM. Chapter 9: options for summarizing medical test performance in the absence of a “gold standard”. J Gen Intern Med. Jun. 2012;27(Suppl 1):S67-75. [pmid: 22648677].
22 Trikalinos TA, Balion CM, Coleman CI, et al. Chapter 8: meta-analysis of test performance when there is a “gold standard”. J Gen Intern Med. Jun. 2012;27(Suppl 1):S56-66. [pmid: 22648676].
23 Hamza TH, van Houwelingen HC, Stijnen T. The binomial distribution of meta-analysis was preferred to model within-study variability. J Clin Epidemiol. Jan. 2008;61(1):41-51. [pmid: 18083461].
24 Rutter CM, Gatsonis CA. A hierarchical regression approach to meta-analysis of diagnostic test accuracy evaluations. Stat Med. Oct. 15. 2001;20(19):2865-84. [pmid: 11568945].
25 Arends LR, Hamza TH, van Houwelingen JC, et al. Bivariate random effects meta-analysis of ROC curves. Med Decis Making. Sep–Oct. 2008;28(5):621-38. [pmid: 18591542].
26 Stijnen T, Hamza TH, Ozdemir P. Random effects meta-analysis of event outcome in the framework of the generalized linear mixed model with applications in sparse data. Stat Med. Dec. 20. 2010;29(29):3046-67. [pmid: 20827667].
27 Hamza TH, van Houwelingen HC, Heijenbrok-Kal MH, et al. Associating explanatory variables with summary receiver operating characteristic curves in diagnostic meta-analysis. J Clin Epidemiol. Dec. 2009;62(12):1284-91. [pmid: 19398297].
28 van Houwelingen HC, Arends LR, Stijnen T. Advanced methods in meta-analysis: multivariate approach and meta-regression. Stat Med. Feb. 28. 2002;21(4):589-624. [pmid: 11836738].
29 Olkin I. Diagnostic statistical procedures in medical meta-analyses. Stat Med. Sep. 15–30. 1999;18(17–18):2331-41. [pmid: 10474143].
30 Dahabreh IJ, Trikalinos TA, Lau J, et al. An Empirical Assessment of Bivariate Methods for Meta-Analysis of Test Accuracy. Rockville (MD). 2012.
31 Singh S, Chang SM, Matchar DB, et al. Grading a body of evidence on diagnostic tests. Chang SMM, Smetana DB, Umscheid GW, CA, editors. Methods Guide for Medical Test Reviews. AHRQ Publication No. 12-EHC017. Rockville, MD. Agency for Healthcare Research and Quality. June. 2012;chapter 7. www.ncbi.nlm.nih.gov/books/NBK98241/. Accessed April 25, 2013.
32 Lau J, Ioannidis JP, Terrin N, et al. The case of the misleading funnel plot. BMJ. Sep. 16. 2006;333(7568):597-600. [pmid: 16974018].
33 Sterne JA, Sutton AJ, Ioannidis JP, et al. Recommendations for examining and interpreting funnel plot asymmetry in meta-analyses of randomised controlled trials. BMJ. 2011;343:d4002. [pmid: 21784880].
34 Antley CM, Mooney EE, Layfield LJ. A comparison of of accuracy rates between open biopsy, cutting-needle biopsy, and fine-needle aspiration biopsy of the breast: a 3-year experience. The Breast Journal. 1998;4(1):3-8.
35 Pistolese CA, Ciarrapico A, Perretta T, et al. Cost-effectiveness of two breast biopsy procedures: surgical biopsy versus vacuum-assisted biopsy. Radiol Med. Jun. 2012;117(4):539-57. [pmid: 22020428].
36 Abdsaleh S, Azavedo E, Lindgren PG. Semiautomatic core biopsy. A modified biopsy technique in breast diseases. Acta Radiol. Jan. 2003;44(1):47-51. [pmid: 12630998].
37 Ahmed ME, Ahmad I, Akhtar S. Ultrasound guided fine needle aspiration cytology versus core biopsy in the preoperative assessment of non-palpable breast lesions. J Ayub Med Coll Abbottabad. Apr–Jun. 2010;22(2):138-42. [pmid: 21702288].
38 Akita A, Tanimoto A, Jinno H, et al. The clinical value of bilateral breast MR imaging: is it worth performing on patients showing suspicious microcalcifications on mammography?. Eur Radiol. Sep. 2009;19(9):2089-96. [pmid: 19350244].
39 Alonso-Bartolome P, Vega-Bolivar A, Torres-Tabanera M, et al. Sonographically guided 11-G directional vacuum-assisted breast biopsy as an alternative to surgical excision: utility and cost study in probably benign lesions. Acta Radiol. Jul. 2004;45(4):390-6. [pmid: 15323390].
40 Ambrogetti D, Bianchi S, Ciatto S. Accuracy of percutaneous core biopsy of isolated breast microcalcifications identified by mammography. Experience with a vacuum-assisted large-core biopsy device. Radiol Med. Oct. 2003;106(4):313-9. [pmid: 14612823].
41 An YY, Kim SH, Kang BJ, et al. Usefulness of magnetic resonance imaging-guided vacuum-assisted breast biopsy in Korean women: a pilot study. World J Surg Oncol. Aug. 16. 2013;11(1):200. [pmid: 23948057].
42 Apesteguia L, Mellado M, Saenz J, et al. Vacuum-assisted breast biopsy on digital stereotaxic table of nonpalpable lesions non-recognisable by ultrasonography. Eur Radiol. Mar. 2002;12(3):638-45. [pmid: 11870480].
43 Arazi-Kleinman T, Skair-Levy M, Slonimsky E, et al. JOURNAL CLUB: Is screening MRI indicated for women with a personal history of breast cancer? Analysis based on biopsy results. AJR Am J Roentgenol. Oct. 2013;201(4):919-27. [pmid: 24059385].
44 Barreto V, Hamed H, Griffiths AB, et al. Automatic needle biopsy in the diagnosis of early breast cancer. Eur J Surg Oncol. Jun. 1991;17(3):237-9. [pmid: 2044776].
45 Bauer RL, Sung J, Eckhert KH Jr, et al. Comparison of histologic diagnosis between stereotactic core needle biopsy and open surgical biopsy. Ann Surg Oncol. Jun. 1997;4(4):316-20. [pmid: 9181231].
46 Beck RM, Gotz L, Heywang-Kobrunner SH. Stereotaxic vacuum core breast biopsy--experience of 560 patients. Swiss Surg. 2000;6(3):108-10. [pmid: 10894010].
47 Becker L, Taves D, McCurdy L, et al. Stereotactic core biopsy of breast microcalcifications: comparison of film versus digital mammography, both using an add-on unit. AJR Am J Roentgenol. Dec. 2001;177(6):1451-7. [pmid: 11717106].
48 Bernardi D, Borsato G, Pellegrini M, et al. On the diagnostic accuracy of stereotactic vacuum-assisted biopsy of nonpalpable breast abnormalities. Results in a consecutive series of 769 procedures performed at the Trento Department of Breast Diagnosis. Tumori. Jan–Feb. 2012;98(1):113-8. [pmid: 22495711].
49 Boarki K, Labib M. The role of US guided handheld vacuum assisted breast core biopsy (VACB) in the surgical management of breast nodules: preliminary report of KCCC experience. Gulf J Oncolog. Jul. 2008;(4):39-44. [pmid: 20084774].
50 Bolivar AV, Alonso-Bartolome P, Garcia EO, et al. Ultrasound-guided core needle biopsy of non-palpable breast lesions: a prospective analysis in 204 cases. Acta Radiol. Nov. 2005;46(7):690-5. [pmid: 16372687].
51 Brancato B, Crocetti E, Bianchi S, et al. Accuracy of needle biopsy of breast lesions visible on ultrasound: audit of fine needle versus core needle biopsy in 3233 consecutive samplings with ascertained outcomes. Breast. Aug. 2012;21(4):449-54. [pmid: 22088803].
52 Brenner RJ, Bassett LW, Fajardo LL, et al. Stereotactic core-needle breast biopsy: a multi-institutional prospective trial. Radiology. Mar. 2001;218(3):866-72. [pmid: 11230668].
53 Britton PD, Flower CD, Freeman AH, et al. Changing to core biopsy in an NHS breast screening unit. Clin Radiol. Oct. 1997;52(10):764-7. [pmid: 9366536].
54 Burbank F. Stereotactic breast biopsy of atypical ductal hyperplasia and ductal carcinoma in situ lesions: improved accuracy with directional, vacuum-assisted biopsy. Radiology. Mar. 1997;202(3):843-7. [pmid: 9051043].
55 Cangiarella J, Waisman J, Symmans WF, et al. Mammotome core biopsy for mammary microcalcification: analysis of 160 biopsies from 142 women with surgical and radiologic followup. Cancer. Jan. 1. 2001;91(1):173-7. [pmid: 11148574].
56 Caruso ML, Gabrieli G, Marzullo G, et al. Core Biopsy as Alternative to Fine-Needle Aspiration Biopsy in Diagnosis of Breast Tumors. Oncologist. 1998;3(1):45-9. [pmid: 10388083].
57 Chang JM, Won JK, Lee KB, et al. Comparison of shear-wave and strain ultrasound elastography in the differentiation of benign and malignant breast lesions. AJR Am J Roentgenol. Aug. 2013;201(2):W347-56. [pmid: 23883252].
58 Chapellier C, Balu-Maestro C, Amoretti N, et al. Vacuum-assisted breast biopsies. Experience at the Antoine Lacassagne Cancer Center (Nice, France). Clin Imaging. Mar–Apr. 2006;30(2):99-107. [pmid: 16500540].
59 Cho N, Moon WK, Park JS, et al. Nonpalpable breast masses: evaluation by US elastography. Korean J Radiol. Mar–Apr. 2008;9(2):111-8. [pmid: 18385557].
60 Ciatto S, Houssami N, Ambrogetti D, et al. Accuracy and underestimation of malignancy of breast core needle biopsy: the Florence experience of over 4000 consecutive biopsies. Breast Cancer Res Treat. Mar. 2007;101(3):291-7. [pmid: 16823506].
61 Cipolla C, Fricano S, Vieni S, et al. Validity of needle core biopsy in the histological characterisation of mammary lesions. Breast. Feb. 2006;15(1):76-80. [pmid: 16473738].
62 Cornelis A, Verjans M, Van den Bosch T, et al. Efficacy and safety of direct and frontal macrobiopsies in breast cancer. Eur J Cancer Prev. Aug. 2009;18(4):280-4. [pmid: 19352188].
63 Cross MJ, Evans WP, Peters GN, et al. Stereotactic breast biopsy as an alternative to open excisional biopsy. Ann Surg Oncol. May. 1995;2(3):195-200. [pmid: 7641014].
64 Crowe JP Jr, Patrick RJ, Rybicki LA, et al. Does ultrasound core breast biopsy predict histologic finding on excisional biopsy?. The American Journal of Surgery. 2003;186:397-99.
65 Crystal P, Koretz M, Shcharynsky S, et al. Accuracy of sonographically guided 14-gauge core-needle biopsy: results of 715 consecutive breast biopsies with at least two-year follow-up of benign lesions. J Clin Ultrasound. Feb. 2005;33(2):47-52. [pmid: 15674836].
66 Cusick JD, Dotan J, Jaecks RD, et al. The role of Tru-Cut needle biopsy in the diagnosis of carcinoma of the breast. Surg Gynecol Obstet. May. 1990;170(5):407-10. [pmid: 2183373].
67 Dahlstrom JE, Jain S, Sutton T, et al. Diagnostic accuracy of stereotactic core biopsy in a mammographic breast cancer screening programme. Histopathology. May. 1996;28(5):421-7. [pmid: 8735717].
68 Dahlstrom JE, Jain S. Histological correlation of mammographically detected microcalcifications in stereotactic core biopsies. Pathology (Phila). Nov. 2001;33(4):444-8. [pmid: 11827410].
69 de Lucena CE, Dos Santos Junior JL, de Lima Resende CA, et al. Ultrasound-guided core needle biopsy of breast masses: How many cores are necessary to diagnose cancer?. J Clin Ultrasound. Sep. 2007;35(7):363-6. [pmid: 17663457].
70 Delle Chiaie L, Terinde R. Three-dimensional ultrasound-validated large-core needle biopsy: is it a reliable method for the histological assessment of breast lesions?. Ultrasound Obstet Gynecol. Apr. 2004;23(4):393-7. [pmid: 15065192].
71 Dhillon MS, Bradley SA, England DW. Mammotome biopsy: impact on preoperative diagnosis rate. Clin Radiol. Mar. 2006;61(3):276-81. [pmid: 16488210].
72 Dillon MF, Hill AD, Quinn CM, et al. The accuracy of ultrasound, stereotactic, and clinical core biopsies in the diagnosis of breast cancer, with an analysis of false-negative cases. Ann Surg. Nov. 2005;242(5):701-7. [pmid: 16244544].
73 Doyle AJ, Collins JP, Forkert CD. Decubitus stereotactic core biopsy of the breast: technique and experience. AJR Am J Roentgenol. Mar. 1999;172(3):688-90. [pmid: 10063861].
74 Doyle AJ, Murray KA, Nelson EW, et al. Selective use of image-guided large-core needle biopsy of the breast: accuracy and cost-effectiveness. AJR Am J Roentgenol. Aug. 1995;165(2):281-4. [pmid: 7618540].
75 Elvecrog EL, Lechner MC, Nelson MT. Nonpalpable breast lesions: correlation of stereotaxic large-core needle biopsy and surgical biopsy results. Radiology. Aug. 1993;188(2):453-5. [pmid: 8327696].
76 Faizi KS, Hameed T, Azim K, et al. Diagnostic accuracy of Trucut biopsy in the detection of breast lumps. Pakistan Journal of Medical and Health Sciences. 2012;6(4):979-82.
77 Fajardo LL, Pisano ED, Caudry DJ, et al. Stereotactic and sonographic large-core biopsy of nonpalpable breast lesions: results of the Radiologic Diagnostic Oncology Group V study. Acad Radiol. Mar. 2004;11(3):293-308. [pmid: 15035520].
78 Fischbach F, Eggemann H, Bunke J, et al. MR-guided freehand biopsy of breast lesions in a 1.0-T open MR imager with a near-real-time interactive platform: preliminary experience. Radiology. Nov. 2012;265(2):359-70. [pmid: 22923721].
79 Fishman JE, Milikowski C, Ramsinghani R, et al. US-guided core-needle biopsy of the breast: how many specimens are necessary?. Radiology. Mar. 2003;226(3):779-82. [pmid: 12601206].
80 Frazee RC, Roberts JW, Symmonds RE, et al. Open versus stereotactic breast biopsy. Am J Surg. Nov. 1996;172(5):491-3. discussion 4-5. [pmid: 8942551].
81 Fuhrman G, Cederbom G, Champagne J, et al. Stereotactic core needle breast biopsy is an accurate diagnostic technique to assess nonpalpable mammographic abnormalities. J La State Med Soc. Apr. 1996;148(4):167-70. [pmid: 8935619].
82 Fuhrman GM, Cederbom GJ, Bolton JS, et al. Image-guided core-needle breast biopsy is an accurate technique to evaluate patients with nonpalpable imaging abnormalities. Ann Surg. Jun. 1998;227(6):932-9. [pmid: 9637557].
83 Georgian-Smith D, D’Orsi C, Morris E, et al. Stereotactic biopsy of the breast using an upright unit, a vacuum-suction needle, and a lateral arm-support system. AJR Am J Roentgenol. Apr. 2002;178(4):1017-24. [pmid: 11906893].
84 Gisvold JJ, Goellner JR, Grant CS, et al. Breast biopsy: a comparative study of stereotaxically guided core and excisional techniques. AJR Am J Roentgenol. Apr. 1994;162(4):815-20. [pmid: 8140997].
85 Gruber R, Jaromi S, Rudas M, et al. Histologic work-up of non-palpable breast lesions classified as probably benign at initial mammography and/or ultrasound (BI-RADS category 3). Eur J Radiol. Mar. 2013;82(3):398-403. [pmid: 22429299].
86 Gruber R, Walter E, Helbich TH. Impact of stereotactic 11-g vacuum-assisted breast biopsy on cost of diagnosis in Austria. Eur J Radiol. Jan. 2011;77(1):131-6. [pmid: 19853395].
87 Hahn SY, Shin JH, Han BK, et al. Sonographically-guided vacuum-assisted biopsy with digital mammography-guided skin marking of suspicious breast microcalcifications: comparison of outcomes with stereotactic biopsy in Asian women. Acta Radiol. Feb. 1. 2011;52(1):29-34. [pmid: 21498322].
88 Hamed H, De Freitas R, Rasbridge S, et al. A prospective randomized study of two gauges of biopty-cut needle in diagnosis of early breast cancer. Breast. 1995;4(2):135-6.
89 Han BK, Choe YH, Ko YH, et al. Stereotactic core-needle biopsy of non-mass calcifications: outcome and accuracy at long-term follow-up. Korean J Radiol. Oct–Dec. 2003;4(4):217-23. [pmid: 14726638].
90 Head JF, Haynes AE, Elliott MC, et al. Stereotaxic localization and core needle biopsy of nonpalpable breast lesions: two-year follow-up of a prospective study. Am Surg. Dec. 1996;62(12):1018-23. [pmid: 8955240].
91 Helbich TH, Mayr W, Schick S, et al. Coaxial technique: approach to breast core biopsies. Radiology. Jun. 1997;203(3):684-90. [pmid: 9169689].
92 Heywang-Kobrunner SH, Heinig A, Hellerhoff K, et al. Use of ultrasound-guided percutaneous vacuum-assisted breast biopsy for selected difficult indications. Breast J. Jul–Aug. 2009;15(4):348-56. [pmid: 19500104].
93 Heywang-Kobrunner SH, Schaumloffel U, Viehweg P, et al. Minimally invasive stereotaxic vacuum core breast biopsy. Eur Radiol. 1998;8(3):377-85. [pmid: 9510569].
94 Houserkova D, Prasad SN, Svach I, et al. The value of dynamic contrast enhanced breast MRI in mammographically detected BI-RADS 5 microcalcifications. Biomed Pap Med Fac Univ Palacky Olomouc Czech Repub. Jun. 2008;152(1):107-15. [pmid: 18795084].
95 Huang PC, Cheung YC, Lo YF, et al. A comparison of spring-loaded and vacuum-assisted techniques for stereotactic breast biopsy of impalpable microcalcification lesions: experience at Chang Gung Memorial Hospital at Linkou. Chang Gung Med J. Jan–Feb. 2011;34(1):75-83. [pmid: 21392477].
96 Huang YC, Ho CY. Stereotactic 11-guage Vacuum-assisted Breast Biopsy: Experience of 420 Cases with Microcalcification on Mammography of Non-palpable Lesions. J Radiol Sci. December. 2011;36(4):195-202.
97 Ioffe OB, Berg WA, Silverberg SG, et al. Mammographic-histopathologic correlation of large-core needle biopsies of the breast. Mod Pathol. Aug. 1998;11(8):721-7. [pmid: 9720499].
98 Jackman RJ, Lamm RL. Stereotactic histologic biopsy in breasts with implants. Radiology. Jan. 2002;222(1):157-64. [pmid: 11756720].
99 Jackman RJ, Marzoni FA Jr, Rosenberg J. False-negative diagnoses at stereotactic vacuum-assisted needle breast biopsy: long-term follow-up of 1,280 lesions and review of the literature. AJR Am J Roentgenol. Feb. 2009;192(2):341-51. [pmid: 19155393].
100 Jackman RJ, Nowels KW, Rodriguez-Soto J, et al. Stereotactic, automated, large-core needle biopsy of nonpalpable breast lesions: false-negative and histologic underestimation rates after long-term follow-up. Radiology. Mar. 1999;210(3):799-805. [pmid: 10207484].
101 Jales RM, Sarian LO, Peralta CF, et al. Complex breast masses: assessment of malignant potential based on cyst diameter. J Ultrasound Med. Apr. 2012;31(4):581-7. [pmid: 22441915].
102 Johnson AT, Henry-Tillman RS, Smith LF, et al. Percutaneous excisional breast biopsy. Am J Surg. Dec. 2002;184(6):550-4. discussion 4. [pmid: 12488164].
103 Kettritz U, Morack G, Decker T. Stereotactic vacuum-assisted breast biopsies in 500 women with microcalcifications: radiological and pathological correlations. Eur J Radiol. Aug. 2005;55(2):270-6. [pmid: 16036159].
104 Kettritz U, Rotter K, Schreer I, et al. Stereotactic vacuum-assisted breast biopsy in 2874 patients: a multicenter study. Cancer. Jan. 15. 2004;100(2):245-51. [pmid: 14716757].
105 Khattar SC, Torp-Pedersen S, Horn T, et al. Ultrasound-guided biopsy of palpable breast masses. Eur J Ultrasound. 1997;6(1):1-7.
106 Kim HS, Kim MJ, Kim EK, et al. US-guided vacuum-assisted biopsy of microcalcifications in breast lesions and long-term follow-up results. Korean J Radiol. Nov–Dec. 2008;9(6):503-9. [pmid: 19039266].
107 Kirshenbaum KJ, Voruganti T, Overbeeke C, et al. Stereotactic core needle biopsy of nonpalpable breast lesions using a conventional mammography unit with an add-on device. AJR Am J Roentgenol. Aug. 2003;181(2):527-31. [pmid: 12876040].
108 Kirshenbaum K, Keppke A, Hou K, et al. Reassessing specimen number and diagnostic yield of ultrasound guided breast core biopsy. Breast J. Sep. 2012;18(5):464-9. [pmid: 22775971].
109 Kirwan SE, Denton ER, Nash RM, et al. Multiple 14G stereotactic core biopsies in the diagnosis of mammographically detected stellate lesions of the breast. Clin Radiol. Oct. 2000;55(10):763-6. [pmid: 11052877].
110 Koskela AK, Sudah M, Berg MH, et al. Add-on device for stereotactic core-needle breast biopsy: how many biopsy specimens are needed for a reliable diagnosis?. Radiology. Sep. 2005;236(3):801-9. [pmid: 16020555].
111 Lai JT, Burrowes P, MacGregor JH. Diagnostic accuracy of a stereotaxically guided vacuum-assisted large-core breast biopsy program in Canada. Can Assoc Radiol J. Aug. 2001;52(4):223-7. [pmid: 11512293].
112 Latosinsky S, Cornell D, Bear HD, et al. Evaluation of stereotactic core needle biopsy (SCNB) of the breast at a single institution. Breast Cancer Res Treat. Apr. 2000;60(3):277-83. [pmid: 10930116].
113 Levin MF, Papoff WJ, Doan L, et al. Stereotaxic percutaneous core biopsy versus surgical biopsy of nonpalpable breast lesions using a standard mammographic table with an add-on device. Can Assoc Radiol J. Feb. 2001;52(1):29-32. [pmid: 11247262].
114 Liberman L, Dershaw DD, Glassman JR, et al. Analysis of cancers not diagnosed at stereotactic core breast biopsy. Radiology. Apr. 1997;203(1):151-7. [pmid: 9122384].
115 Liberman L, Ernberg LA, Heerdt A, et al. Palpable breast masses: is there a role for percutaneous imaging-guided core biopsy?. AJR Am J Roentgenol. Sep. 2000;175(3):779-87. [pmid: 10954467].
116 Liberman L, Feng TL, Dershaw DD, et al. US-guided core breast biopsy: use and cost-effectiveness. Radiology. Sep. 1998;208(3):717-23. [pmid: 9722851].
117 Liberman L, Kaplan JB, Morris EA, et al. To excise or to sample the mammographic target: what is the goal of stereotactic 11-gauge vacuum-assisted breast biopsy?. AJR Am J Roentgenol. Sep. 2002;179(3):679-83. [pmid: 12185043].
118 Liberman L, Sama MP. Cost-effectiveness of stereotactic 11-gauge directional vacuum-assisted breast biopsy. AJR Am J Roentgenol. Jul. 2000;175(1):53-8. [pmid: 10882245].
119 Lin WC, Hsu GC, Yu CP, et al. Value of sonographically guided needle sampling of cystic versus solid components in the diagnosis of complex cystic breast masses. Acta Radiol. Jul. 2009;50(6):595-601. [pmid: 19452336].
120 Lomoschitz FM, Helbich TH, Rudas M, et al. Stereotactic 11-gauge vacuum-assisted breast biopsy: influence of number of specimens on diagnostic accuracy. Radiology. Sep. 2004;232(3):897-903. [pmid: 15273332].
121 Luparia A, Durando M, Campanino P, et al. Efficacy and cost-effectiveness of stereotactic vacuum-assisted core biopsy of nonpalpable breast lesions: analysis of 602 biopsies performed over 5 years. Radiol Med. Apr. 2011;116(3):477-88. [pmid: 21225359].
122 Mainiero MB, Philpotts LE, Lee CH, et al. Stereotaxic core needle biopsy of breast microcalcifications: correlation of target accuracy and diagnosis with lesion size. Radiology. Mar. 1996;198(3):665-9. [pmid: 8628852].
123 Makkun S, Prueksadee J, Chayakulkheeree J, et al. The accuracy of ultrasound guided 14-gauge core needle breast biopsy: Correlation with surgical excision or long term follow-up. Asian Pacific Journal of Tropical Disease. 2011:222-6.
124 Makoske T, Preletz R, Riley L, et al. Long-term outcomes of stereotactic breast biopsies. Am Surg. Dec. 2000;66(12):1104-8. discussion 8-9. [pmid: 11149580].
125 March DE, Coughlin BF, Barham RB, et al. Breast masses: removal of all US evidence during biopsy by using a handheld vacuum-assisted device--initial experience. Radiology. May. 2003;227(2):549-55. [pmid: 12676972].
126 Margolin FR, Leung JW, Jacobs RP, et al. Percutaneous imaging-guided core breast biopsy: 5 years’ experience in a community hospital. AJR Am J Roentgenol. Sep. 2001;177(3):559-64. [pmid: 11517047].
127 McMahon AJ, Lutfy AM, Matthew A, et al. Needle core biopsy of the breast with a spring-loaded device. Br J Surg. Oct. 1992;79(10):1042-5. [pmid: 1422715].
128 Meloni GB, Becchere MP, Soro D, et al. Percutaneous vacuum-assisted core breast biopsy with upright stereotactic equipment. Indications, limitations and results. Acta Radiol. Nov. 2002;43(6):575-8. [pmid: 12485254].
129 Meyer JE, Christian RL, Lester SC, et al. Evaluation of nonpalpable solid breast masses with stereotaxic large-needle core biopsy using a dedicated unit. AJR Am J Roentgenol. Jul. 1996;167(1):179-82. [pmid: 8659367].
130 Meyer JE, Smith DN, Lester SC, et al. Large-core needle biopsy of nonpalpable breast lesions. JAMA. May. 5. 1999;281(17):1638-41. [pmid: 10235159].
131 Mikhail RA, Nathan RC, Weiss M, et al. Stereotactic core needle biopsy of mammographic breast lesions as a viable alternative to surgical biopsy. Ann Surg Oncol. Sep. 1994;1(5):363-7. [pmid: 7850536].
132 Morris EA, Liberman L, Trevisan SG, et al. Histologic heterogeneity of masses at percutaneous breast biopsy. Breast J. Jul–Aug. 2002;8(4):187-91. [pmid: 12100109].
133 Mueller-Holzner E, Frede T, Daniaux M, et al. Ultrasound-guided core needle biopsy of the breast: does frozen section give an accurate diagnosis?. Breast Cancer Res Treat. Dec. 2007;106(3):399-406. [pmid: 17318378].
134 Nagar S, Iacco A, Riggs T, et al. An analysis of fine needle aspiration versus core needle biopsy in clinically palpable breast lesions: a report on the predictive values and a cost comparison. Am J Surg. Aug. 2012;204(2):193-8. [pmid: 22464444].
135 Nguyen M, McCombs MM, Ghandehari S, et al. An update on core needle biopsy for radiologically detected breast lesions. Cancer. Dec. 1. 1996;78(11):2340-5. [pmid: 8941004].
136 Ohsumi S, Takashima S, Aogi K, et al. Breast biopsy for mammographically detected non-palpable lesions using a vacuum-assisted biopsy device (Mammotome) and an upright-type stereotactic mammography unit. Jpn J Clin Oncol. Nov. 2001;31(11):527-31. [pmid: 11773259].
137 Ohsumi S, Taira N, Takabatake D, et al. Breast biopsy for mammographically detected nonpalpable lesions using a vacuum-assisted biopsy device (Mammotome) and upright-type stereotactic mammography unit without a digital imaging system: experience of 500 biopsies. Breast Cancer. 2012. Apr. 5. [pmid: 22477266].
138 Order BM, Schaefer PJ, Peters G, et al. Evaluation of two different vacuum-assisted breast biopsy systems: Mammotome(R) system 11G/8G vs. ATEC(R) system 12G/9G. Acta Radiol. Mar. 1. 2013;54(2):137-43. [pmid: 23319718].
139 Parker SH, Burbank F, Jackman RJ, et al. Percutaneous large-core breast biopsy: a multi-institutional study. Radiology. Nov. 1994;193(2):359-64. [pmid: 7972743].
140 Parker SH, Jobe WE, Dennis MA, et al. US-guided automated large-core breast biopsy. Radiology. May. 1993;187(2):507-11. [pmid: 8475299].
141 Parker SH, Lovin JD, Jobe WE, et al. Stereotactic breast biopsy with a biopsy gun. Radiology. Sep. 1990;176(3):741-7. [pmid: 2167501].
142 Parkin E, Hindocha S, Subar D, et al. An initial experience with rapid microwave processing in the one-stop breast clinic. World J Surg. Dec. 2010;34(12):3036-41. [pmid: 20703464].
143 Perez-Fuentes JA, Longobardi IR, Acosta VF, et al. Sonographically guided directional vacuum-assisted breast biopsy: preliminary experience in Venezuela. AJR Am J Roentgenol. Dec. 2001;177(6):1459-63. [pmid: 11717107].
144 Peters N, Hoorntje L, Mali W, et al. Diagnostic performance of stereotactic large core needle biopsy for nonpalpable breast lesions in routine clinical practice. Int J Cancer. Jan. 15. 2008;122(2):468-71. [pmid: 17935136].
145 Peters NHGM, Meeuwis C, Bakker CJG, et al. Feasibility of MRI-guided large-core-needle biopsy of suspiscious breast lesions at 3T. Eur Radiol. 2009;19:1639-44. [pmid: 19214520].
146 Pettine S, Place R, Babu S, et al. Stereotactic breast biopsy is accurate, minimally invasive, and cost effective. Am J Surg. May. 1996;171(5):474-6. [pmid: 8651388].
147 Pfarl G, Helbich TH, Riedl CC, et al. Stereotactic 11-gauge vacuum-assisted breast biopsy: a validation study. AJR Am J Roentgenol. Dec. 2002;179(6):1503-7. [pmid: 12438044].
148 Pfleiderer SO, Brunzlow H, Schulz-Wendtland R, et al. Two-year follow-up of stereotactically guided 9-G breast biopsy: a multicenter evaluation of a self-contained vacuum-assisted device. Clin Imaging. Sep–Oct. 2009;33(5):343-7. [pmid: 19712812].
149 Pfleiderer SO, Reichenbach JR, Azhari T, et al. A manipulator system for 14-gauge large core breast biopsies inside a high-field whole-body MR scanner. J Magn Reson Imaging. Apr. 2003;17(4):493-8. [pmid: 12655591].
150 Philpotts LE, Hooley RJ, Lee CH. Comparison of automated versus vacuum-assisted biopsy methods for sonographically guided core biopsy of the breast. AJR Am J Roentgenol. Feb. 2003;180(2):347-51. [pmid: 12540431].
151 Pistolese CA, Ciarrapico AM, Della Gatta F, et al. Cost-effectiveness analysis of two vacuum-assisted breast biopsy systems: Mammotome and Vacora. Radiol Med. Aug. 2009;114(5):743-56. [pmid: 19484585].
152 Pitre B, Baron PL, Baron LF, et al. Stereotactic core biopsy of the breast: results of one-year follow-up of 101 patients. Am Surg. Dec. 1997;63(12):1124-7. [pmid: 9393264].
153 Povoski SP, Jimenez RE, Wang WP. Ultrasound-guided diagnostic breast biopsy methodology: retrospective comparison of the 8-gauge vacuum-assisted biopsy approach versus the spring-loaded 14-gauge core biopsy approach. World J Surg Oncol. 2011;9:87. [pmid: 21835024].
154 Puglisi F, Pertoldi B, Ramello M, et al. Diagnostic accuracy of perforated compression grid approach for mammographically guided core needle biopsy of breast lesions. Cancer Lett. Nov. 15. 1999;146(2):181-8. [pmid: 10656624].
155 Reiner CS, Helbich TH, Rudas M, et al. Can galactography-guided stereotactic, 11-gauge, vacuum-assisted breast biopsy of intraductal lesions serve as an alternative to surgical biopsy?. Eur Radiol. Dec. 2009;19(12):2878-85. [pmid: 19565246].
156 Rosenblatt R, Fineberg SA, Sparano JA, et al. Stereotactic core needle biopsy of multiple sites in the breast: efficacy and effect on patient care. Radiology. Oct. 1996;201(1):67-70. [pmid: 8816522].
157 Sauer G, Deissler H, Strunz K, et al. Ultrasound-guided large-core needle biopsies of breast lesions: analysis of 962 cases to determine the number of samples for reliable tumour classification. Br J Cancer. Jan. 31. 2005;92(2):231-5. [pmid: 15611793].
158 Schueller G, Jaromi S, Ponhold L, et al. US-guided 14-gauge core-needle breast biopsy: results of a validation study in 1352 cases. Radiology. Aug. 2008;248(2):406-13. [pmid: 18641246].
159 Schulz-Wendtland R, Kramer S, Lang N, et al. Ultrasonic guided microbiopsy in mammary diagnosis: indications, technique and results. Anticancer Res. May–Jun. 1998;18(3C):2145-6. [pmid: 9703772].
160 Scopa CD, Koukouras D, Spiliotis J, et al. Comparison of fine needle aspiration and Tru-Cut biopsy of palpable mammary lesions. Cancer Detect Prev. 1996;20(6):620-4. [pmid: 8939348].
161 Sim LS, Kei PL. Upright stereotactic vacuum-assisted needle biopsy of suspicious breast microcalcifications. J Med Imaging Radiat Oncol. Aug. 2008;52(4):358-64. [pmid: 18811759].
162 Smith DN, Rosenfield Darling ML, Meyer JE, et al. The utility of ultrasonographically guided large-core needle biopsy: results from 500 consecutive breast biopsies. J Ultrasound Med. Jan. 2001;20(1):43-9. [pmid: 11149527].
163 Smith LF, Henry-Tillman R, Mancino AT, et al. Magnetic resonance imaging-guided core needle biopsy and needle localized excision of occult breast lesions. Am J Surg. Oct. 2001;182(4):414-8. [pmid: 11720683].
164 Smyth AT, Cederbom GJ. Core biopsy of breast lesions. J La State Med Soc. Nov. 1994;146(11):499-501. [pmid: 7806950].
165 Soo MS, Ghate S, Delong D. Stereotactic biopsy of noncalcified breast lesions: utility of vacuum-assisted technique compared to multipass automated gun technique. Clin Imaging. Nov–Dec. 1999;23(6):347-52. [pmid: 10899415].
166 Stolier AJ. Stereotactic breast biopsy: a surgical series. J Am Coll Surg. Sep. 1997;185(3):224-8. [pmid: 9291397].
167 Sutton S, Dahlstrom JE, Jain S. Stereotactic large-gauge core biopsy: its role in the diagnosis of non-palpable mammographic abnormalities presenting to a screening service. Australas Radiol. May. 1997;41(2):103-8. [pmid: 9153803].
168 Tonegutti M, Girardi V. Stereotactic vacuum-assisted breast biopsy in 268 nonpalpable lesions. Radiol Med. Feb. 2008;113(1):65-75. [pmid: 18338128].
169 Toth D, Sebo E, Sarkadi L, et al. Role of core needle biopsy in the treatment of radial scar. Breast. Dec. 2012;21(6):761-3. [pmid: 22397896].
170 Tothova L, Rauova K, Valkovic L, et al. Stereotactic vacuum-assisted breast biopsy: our experience and comparison with stereotactic automated needle biopsy. Bratisl Lek Listy. 2013;114(2):71-7. [pmid: 23331202].
171 Uematsu T, Kasami M, Yuen S. Usefulness and limitations of the Japan Mammography Guidelines for the categorization of microcalcifications. Breast Cancer. 2008;15(4):291-7. [pmid: 18288569].
172 Uematsu T, Kasami M, Yuen S. A cluster of microcalcifications: women with high risk for breast cancer versus other women. Breast Cancer. 2009;16(4):307-14. [pmid: 19350360].
173 Vag T, Pfleiderer SO, Bottcher J, et al. Ultrasound-guided breast biopsy using a 10-gauge self-contained vacuum-assisted device. Eur Radiol. Dec. 2007;17(12):3100-2. [pmid: 17639409].
174 Vega A, Arrizabalaga R, Garijo F, et al. Nonpalpable breast lesion. Stereotaxic core needle aspiration biopsy with a single pass. Acta Radiol. Mar. 1995;36(2):117-21. [pmid: 7710788].
175 Vega Bolivar A, Ortega Garcia E, Garijo Ayensa F. Stereotaxic core needle aspiration biopsy with multiple passes in nonpalpable breast lesions. Acta Radiol. Jul. 1998;39(4):389-94. [pmid: 9685825].
176 Venkataraman S, Dialani V, Gilmore HL, et al. Stereotactic core biopsy: Comparison of 11 gauge with 8 gauge vacuum assisted breast biopsy. Eur J Radiol. Oct. 2012;81(10):2613-9. [pmid: 22127375].
177 Verkooijen HM. Diagnostic accuracy of stereotactic large-core needle biopsy for nonpalpable breast disease: results of a multicenter prospective study with 95% surgical confirmation. Int J Cancer. Jun. 20. 2002;99(6):853-9. [pmid: 12115488].
178 Walker TM. Impalpable breast lesions: Stereotactic core biopsy with an ‘add-on’ unit. Breast. June. 1997;6(3):126-31.
179 Wang J, Kuo WH, Pan SL, et al. Use of Bayesian modeling to estimate the sensitivity of stereotactic directional vacuum-assisted breast biopsy when the gold standard is incomplete. Acad Radiol. Nov. 2009;16(11):1316-22. [pmid: 19665906].
180 Ward SE, Taves DH, McCurdy LI. Stereotaxic core needle biopsy of breast microcalcifications obtained using a standard mammography table with an add-on unit. Can Assoc Radiol J. Feb. 2000;51(1):10-5. [pmid: 10711288].
181 Weber WP, Zanetti R, Langer I, et al. Mammotome: less invasive than ABBI with similar accuracy for early breast cancer detection. World J Surg. Apr. 2005;29(4):495-9. [pmid: 15770379].
182 Welle GJ, Clark M, Loos S, et al. Stereotactic breast biopsy: recumbent biopsy using add-on upright equipment. AJR Am J Roentgenol. Jul. 2000;175(1):59-63. [pmid: 10882246].
183 White RR, Halperin TJ, Olson JA Jr, et al. Impact of core-needle breast biopsy on the surgical management of mammographic abnormalities. Ann Surg. Jun. 2001;233(6):769-77. [pmid: 11371735].
184 Whitman GJ, Kopans DB, McCarthy KA, et al. Coaxial core needle biopsy under mammographic guidance: indications and applications. AJR Am J Roentgenol. Jul. 1998;171(1):67-70. [pmid: 9648766].
185 Wiratkapun C, Treesit T, Wibulpolprasert B, et al. Diagnostic accuracy of ultrasonography-guided core needle biopsy for breast lesions. Singapore Med J. Jan. 2012;53(1):40-5. [pmid: 22252182].
186 Wong TE, Hisham AN. Core needle biopsy of palpable breast lump: the influence of needle size. Med J Malaysia. Aug. 2003;58(3):399-404. [pmid: 14750380].
187 Wu YK, Huang YM, Chou ASB, et al. Management of breast fibroadenomas by ultrasound-guided vacuum-assisted biopsy- Three years experience. Tzu Chi Med J. 2005;17(6):405-8.
188 Wunderbaldinger P, Helbich TH, Partik B, et al. First experience with a new dedicated ultrasound system for computer-guided large-core breast biopsy. Eur Radiol. 2001;11(12):2460-4. [pmid: 11734940].
189 Yeoman LJ, Michell MJ, Humphreys S, et al. Radiographically guided fine needle aspiration cytology and core biopsy in the assessment of impalpable breast lesions. The Breast. 1996;5:41-7.
190 Yeow KM, Lo YF, Wang CS, et al. Ultrasound-guided core needle biopsy as an initial diagnostic test for palpable breast masses. J Vasc Interv Radiol. Nov. 2001;12(11):1313-7. [pmid: 11698631].
191 Youk JH, Kim EK, Kim MJ, et al. Sonographically guided 14-gauge core needle biopsy of breast masses: a review of 2,420 cases with long-term follow-up. AJR Am J Roentgenol. Jan. 2008;190(1):202-7. [pmid: 18094312].
192 Zannis VJ, Aliano KM. The evolving practice pattern of the breast surgeon with disappearance of open biopsy for nonpalpable lesions. Am J Surg. Dec. 1998;176(6):525-8. [pmid: 9926783].
193 Zografos G, Zagouri F, Sergentanis TN, et al. Vacuum-assisted breast biopsy in nonpalpable solid breast lesions without microcalcifications: the Greek experience. Diagn Interv Radiol. Sep. 2008;14(3):127-30. [pmid: 18814132].
194 Zuiani C, Mazzarella F, Londero V, et al. Stereotactic vacuum-assisted breast biopsy: results, follow-up and correlation with radiological suspicion. Radiol Med. Mar. 2007;112(2):304-17. [pmid: 17361368].
195 Awuah B, Martin IK, Takyi V, et al. Implementation of a percutaneous core needle biopsy training program: results from the University of Michigan-Komfo Anokye Teaching Hospital breast cancer research partnership. Ann Surg Oncol. Apr. 2011;18(4):957-60. [pmid: 21104327].
196 Bi TQ, Ren CL, Chaudhary P, et al. Diagnosis and excision of breast multi-focal lesions by ultrasound-guided vacuum-assisted biopsy: A comparative evaluation. Journal of Xi’an Medical University. 2010;(3):208-11.
197 Bleiweiss IJ, Nagi CS, Jaffer S. Axillary sentinel lymph nodes can be falsely positive due to iatrogenic displacement and transport of benign epithelial cells in patients with breast carcinoma. J Clin Oncol. May. 1. 2006;24(13):2013-8. [pmid: 16606970].
198 Brandon CJ, Mullan PB. Patients’ perception of care during image-guided breast biopsy in a rural community breast center: communication matters. J Cancer Educ. Mar. 2011;26(1):156-60. [pmid: 21188664].
199 Brenner RJ, Gordon LM. Malignant seeding following percutaneous breast biopsy: documentation with comprehensive imaging and clinical implications. Breast J. Nov–Dec. 2011;17(6):651-6. [pmid: 21906209].
200 Carter BA, Jensen RA, Simpson JF, et al. Benign transport of breast epithelium into axillary lymph nodes after biopsy. Am J Clin Pathol. Feb. 2000;113(2):259-65. [pmid: 10664628].
201 Chao C, Torosian MH, Boraas MC, et al. Local recurrence of breast cancer in the stereotactic core needle biopsy site: case reports and review of the literature. Breast J. Mar–Apr. 2001;7(2):124-7. [pmid: 11328321].
202 Chen AM, Haffty BG, Lee CH. Local recurrence of breast cancer after breast conservation therapy in patients examined by means of stereotactic core-needle biopsy. Radiology. Dec. 2002;225(3):707-12. [pmid: 12461249].
203 Chetlen AL, Kasales C, Mack J, et al. Hematoma formation during breast core needle biopsy in women taking antithrombotic therapy. AJR Am J Roentgenol. Jul. 2013;201(1):215-22. [pmid: 23789678].
204 Chou CP, Wang YC, Chang SJ, et al. Evaluation of the Effects of Chitosan Hemostasis Dressings on Hemorrhage Caused by Breast Biopsy. Breast Care (Basel). Jun. 2012;7(3):220-4. [pmid: 22872796].
205 Diaz LK, Wiley EL, Venta LA. Are malignant cells displaced by large-gauge needle core biopsy of the breast?. AJR Am J Roentgenol. Nov. 1999;173(5):1303-13. [pmid: 10541110].
206 Duchesne N, Parker SH, Klaus AJ, et al. Breast biopsy: multicenter study of radiofrequency introducer with US-guided handheld system--initial experience. Radiology. Jul. 2004;232(1):205-10. [pmid: 15220503].
207 Faour I, Al-Salam S, El-Terifi H, et al. The use of a vacuum-assisted biopsy device (Mammotome) in the early detection of breast cancer in the United Arab Emirates. Ann N Y Acad Sci. Sep. 2008;1138:108-13. [pmid: 18837890].
208 Fitzal F, Sporn EP, Draxler W, et al. Preoperative core needle biopsy does not increase local recurrence rate in breast cancer patients. Breast Cancer Res Treat. May. 2006;97(1):9-15. [pmid: 16502019].
209 Frank LS, Frank JL, March D, et al. Does therapeutic touch ease the discomfort or distress of patients undergoing stereotactic core breast biopsy? A randomized clinical trial. Pain Med. Jul–Aug. 2007;8(5):419-24. [pmid: 17661855].
210 Hansen NM, Ye X, Grube BJ, et al. Manipulation of the primary breast tumor and the incidence of sentinel node metastases from invasive breast cancer. Arch Surg. Jun. 2004;139(6):634-9. discussion 9-40. [pmid: 15197090].
211 Harries R, Lawson S, Bruckers L. Assessment of microcalcifications with limited number of high-precision macrobiopsies. Eur J Cancer Prev. Sep. 2010;19(5):374-8. [pmid: 20495463].
212 Harter LP, Curtis JS, Ponto G, et al. Malignant seeding of the needle track during stereotaxic core needle breast biopsy. Radiology. Dec. 1992;185(3):713-4. [pmid: 1343569].
213 He Q, Fan X, Guan Y, et al. Percutaneous excisional biopsy of impalpable breast lesions under ultrasound visualization. Breast. Dec. 2008;17(6):666-70. [pmid: 18835778].
214 Hertl K, Marolt-Music M, Kocijancic I, et al. Haematomas after percutaneus vacuum-assisted breast biopsy. Ultraschall Med. Feb. 2009;30(1):33-6. [pmid: 18773386].
215 Hoorntje LE, Schipper ME, Kaya A, et al. Tumour cell displacement after 14G breast biopsy. Eur J Surg Oncol. Jun. 2004;30(5):520-5. [pmid: 15135480].
216 Huber S, Wagner M, Medl M, et al. Benign breast lesions: minimally invasive vacuum-assisted biopsy with 11-gauge needles patient acceptance and effect on follow-up imaging findings. Radiology. Mar. 2003;226(3):783-90. [pmid: 12616021].
217 Hyser MJ, Vanuno D, Mallesh A, et al. Changing patterns of care for occult breast lesions in a community teaching hospital. Am Surg. May. 2000;66(5):438-42. discussion 42-3. [pmid: 10824743].
218 Ishizuna K, Ota D, Okamoto J, et al. A case of mucinous carcinoma of the breast in which needle tract seeding was diagnosed by preoperative diagnostic imaging. Breast Cancer. Oct. 2011;18(4):324-7. [pmid: 19701680].
219 Kibil W, Hodorowicz-Zaniewska D, Kulig J. Mammotome biopsy under ultrasound control in the diagnostics and treatment of nodular breast lesions - own experience. Pol Przegl Chir. May. 1. 2012;84(5):242-6. [pmid: 22763299].
220 King TA, Hayes DH, Cederbom GJ, et al. Biopsy technique has no impact on local recurrence after breast-conserving therapy. Breast J. Jan–Feb. 2001;7(1):19-24. [pmid: 11348411].
221 Knight R, Horiuchi K, Parker SH, et al. Risk of needle-track seeding after diagnostic image-guided core needle biopsy in breast cancer. JSL S. Jul–Sep. 2002;6(3):207-9. [pmid: 12166757].
222 Koo JS, Jung WH, Kim H. Epithelial displacement into the lymphovascular space can be seen in breast core needle biopsy specimens. Am J Clin Pathol. May. 2010;133(5):781-7. [pmid: 20395526].
223 Kubota K, Gomi N, Wakita T, et al. Magnetic resonance imaging of the metal clip in a breast: safety and its availability as a negative marker. Breast Cancer. 2004;11(1):55-9. [pmid: 14718794].
224 Kwo S, Grotting JC. Does stereotactic core needle biopsy increase the risk of local recurrence of invasive breast cancer?. Breast J. May–Jun. 2006;12(3):191-3. [pmid: 16684313].
225 Lai JT, Burrowes P, MacGregor JH. Vacuum-assisted large-core breast biopsy: complications and their incidence. Can Assoc Radiol J. Aug. 2000;51(4):232-6. [pmid: 10976242].
226 Lang EV, Berbaum KS, Faintuch S, et al. Adjunctive self-hypnotic relaxation for outpatient medical procedures: a prospective randomized trial with women undergoing large core breast biopsy. Pain. Dec. 15. 2006;126(1–3):155-64. [pmid: 16959427].
227 Liberman L, Vuolo M, Dershaw DD, et al. Epithelial displacement after stereotactic 11-gauge directional vacuum-assisted breast biopsy. AJR Am J Roentgenol. Mar. 1999;172(3):677-81. [pmid: 10063859].
228 Lin JH, Kuo WH, Huang CS, et al. Ultrasound-guided mammotome biopsy of breast lesions in Taiwanese women. Journal of Medical Ultrasound. 2009;8(2):102-7.
229 Linebarger JH, Landercasper J, Ellis RL, et al. Core needle biopsy rate for new cancer diagnosis in an interdisciplinary breast center: evaluation of quality of care 2007–2008. Ann Surg. Jan. 2012;255(1):38-43. [pmid: 22167007].
230 Michalopoulos NV, Zagouri F, Sergentanis TN, et al. Needle tract seeding after vacuum-assisted breast biopsy. Acta Radiol. Apr. 2008;49(3):267-70. [pmid: 18365811].
231 Nakamura Y, Urashima M, Matsuura A, et al. Stereotactic directional vacuum-assisted breast biopsy using lateral approach. Breast Cancer. Oct. 2010;17(4):286-9. [pmid: 19784717].
232 Newman EL, Kahn A, Diehl KM, et al. Does the method of biopsy affect the incidence of sentinel lymph node metastases?. Breast J. Jan–Feb. 2006;12(1):53-7. [pmid: 16409587].
233 Penco S, Rizzo S, Bozzini AC, et al. Stereotactic vacuum-assisted breast biopsy is not a therapeutic procedure even when all mammographically found calcifications are removed: analysis of 4,086 procedures. AJR Am J Roentgenol. Nov. 2010;195(5):1255-60. [pmid: 20966337].
234 Peters-Engl C, Konstantiniuk P, Tausch C, et al. The impact of preoperative breast biopsy on the risk of sentinel lymph node metastases: analysis of 2502 cases from the Austrian Sentinel Node Biopsy Study Group. Br J Cancer. Nov. 15. 2004;91(10):1782-6. [pmid: 15477859].
235 Rissanen TJ, Makarainen HP, Mattila SI, et al. Wire localized biopsy of breast lesions: a review of 425 cases found in screening or clinical mammography. Clin Radiol. Jan. 1993;47(1):14-22. [pmid: 8428412].
236 Rovera F, Dionigi G, Marelli M, et al. Breast cancer diagnosis: the role of stereotactic vacuum-assisted aspiration biopsy. Int J Surg. 2008;6(Suppl 1):S104-8. [pmid: 19121611].
237 Schaefer FK, Order BM, Eckmann-Scholz C, et al. Interventional bleeding, hematoma and scar-formation after vacuum-biopsy under stereotactic guidance: Mammotome((R))-system 11 g/8 g vs. ATEC((R))-system 12 g/9 g. Eur J Radiol. May. 2012;81(5):e739-45. [pmid: 22381441].
238 Sergentanis TN, Zagouri F, Domeyer P, et al. Biopsy method: a major predictor of adherence after benign breast biopsy?. AJR Am J Roentgenol. Nov. 2009;193(5):W452-7. [pmid: 19843727].
239 Seror JY, Lesieur B, Scheuer-Niro B, et al. Predictive factors for complete excision and underestimation of one-pass en bloc excision of non-palpable breast lesions with the Intact((R)) breast lesion excision system. Eur J Radiol. Apr. 2012;81(4):719-24. [pmid: 21310570].
240 Stolier A, Skinner J, Levine EA. A prospective study of seeding of the skin after core biopsy of the breast. Am J Surg. Aug. 2000;180(2):104-7. [pmid: 11044522].
241 Szynglarewicz B, Matkowski R, Kasprzak P, et al. Pain experienced by patients during minimal-invasive ultrasound-guided breast biopsy: vacuum-assisted vs core-needle procedure. Eur J Surg Oncol. May. 2011;37(5):398-403. [pmid: 21367573].
242 Taplin SH, Abraham L, Geller BM, et al. Effect of previous benign breast biopsy on the interpretive performance of subsequent screening mammography. J Natl Cancer Inst. Jul. 21. 2010;102(14):1040-51. [pmid: 20601590].
243 Uematsu T, Kasami M. Risk of needle tract seeding of breast cancer: cytological results derived from core wash material. Breast Cancer Res Treat. Jul. 2008;110(1):51-5. [pmid: 17674195].
244 Uematsu T, Kasami M. The use of positive core wash cytology to estimate potential risk of needle tract seeding of breast cancer: directional vacuum-assisted biopsy versus automated core needle biopsy. Breast Cancer. 2010;17(1):61-7. [pmid: 19360459].
245 Uematsu T, Yuen S, Kasami M, et al. Dynamic contrast-enhanced MR imaging in screening detected microcalcification lesions of the breast: is there any value?. Breast Cancer Res Treat. Jul. 2007;103(3):269-81. [pmid: 17063274].
246 Uriburu JL, Vuoto HD, Cogorno L, et al. Local recurrence of breast cancer after skin-sparing mastectomy following core needle biopsy: case reports and review of the literature. Breast J. May–Jun. 2006;12(3):194-8. [pmid: 16684314].
247 Ventrella V, Tufaro A, Zito FA, et al. Mammographic characteristics and vacuum-assisted breast biopsy (VABB) of non-palpable breast lesions. Acta Radiol. Jul. 1. 2011;52(6):602-7. [pmid: 21565889].
248 Viala J, Gignier P, Perret B, et al. Stereotactic vacuum-assisted biopsies on a digital breast 3D-tomosynthesis system. Breast J. Jan–Feb. 2013;19(1):4-9. [pmid: 23252555].
249 Viehweg P, Bernerth T, Kiechle M, et al. MR-guided intervention in women with a family history of breast cancer. Eur J Radiol. Jan. 2006;57(1):81-9. [pmid: 16364583].
250 Vitug AF, Newman LA. Complications in breast surgery. Surg Clin North Am. Apr. 2007;87(2):431-51. x. [pmid: 17498536].
251 Wang ZL, Liu G, Huang Y, et al. Percutaneous excisional biopsy of clinically benign breast lesions with vacuum-assisted system: comparison of three devices. Eur J Radiol. Apr. 2012;81(4):725-30. [pmid: 21300503].
252 Ward ST, Shepherd JA, Khalil H. Freehand versus ultrasound-guided core biopsies of the breast: reducing the burden of repeat biopsies in patients presenting to the breast clinic. Breast. Apr. 2010;19(2):105-8. [pmid: 20074953].
253 Wei X, Li Y, Zhang S, et al. Experience in large-core needle biopsy in the diagnosis of 1431 breast lesions. Med Oncol. Jun. 2011;28(2):429-33. [pmid: 20339957].
254 Wong CS, Chu YC, Wong KW, et al. Is ultrasonography-guided modified coaxial core biopsy of the breast a better technique?. Hong Kong Med J. Aug. 2009;15(4):246-8. [pmid: 19652229].
255 Yao F, Li J, Wan Y, et al. Sonographically guided vacuum-assisted breast biopsy for complete excision of presumed benign breast lesions. J Ultrasound Med. Dec. 2012;31(12):1951-7. [pmid: 23197548].
256 Youngson BJ, Cranor M, Rosen PP. Epithelial displacement in surgical breast specimens following needling procedures. Am J Surg Pathol. Sep. 1994;18(9):896-903. [pmid: 8067510].
257 Youngson BJ, Liberman L, Rosen PP. Displacement of carcinomatous epithelium in surgical breast specimens following stereotaxic core biopsy. Am J Clin Pathol. May. 1995;103(5):598-602. [pmid: 7741106].
258 Zagouri F, Gounaris A, Liakou P, et al. Vacuum-assisted breast biopsy: more cores, more hematomas?. In Vivo. Jul–Aug. 2011;25(4):703-5. [pmid: 21709018].
259 Zografos GC, Zagouri F, Sergentanis TN, et al. Predictors of pain during open breast biopsy under local anesthesia: is there such a thing?. Pain Pract. Mar–Apr. 2008;8(2):151. [pmid: 18366472].
260 Zografos GC, Zagouri F, Sergentanis TN, et al. Minimizing underestimation rate of microcalcifications excised via vacuum-assisted breast biopsy: a blind study. Breast Cancer Res Treat. May. 2008;109(2):397-402. [pmid: 17653855].
261 Zografos GC, Zagouri F, Sergentanis TN, et al. Hematoma after vacuum-assisted breast biopsy: are interleukins predictors?. Onkologie. Jul. 2009;32(7):395-7. [pmid: 19556816].
262 Arnaout A, Smylie J, Seely J, et al. Improving breast diagnostic services with a Rapid Access Diagnostic and Support (RADS) program. Ann Surg Oncol. Oct. 2013;20(10):3335-40. [pmid: 23975290].
263 Berg WA, Arnoldus CL, Teferra E, et al. Biopsy of amorphous breast calcifications: pathologic outcome and yield at stereotactic biopsy. Radiology. Nov. 2001;221(2):495-503. [pmid: 11687695].
264 Bleicher RJ, Ruth K, Sigurdson ER, et al. Preoperative delays in the US Medicare population with breast cancer. J Clin Oncol. Dec. 20. 2012;30(36):4485-92. [pmid: 23169513].
265 Brenner RJ, Fajardo L, Fisher PR, et al. Percutaneous core biopsy of the breast: effect of operator experience and number of samples on diagnostic accuracy. AJR Am J Roentgenol. Feb. 1996;166(2):341-6. [pmid: 8553943].
266 Bugbee ME, Wellisch DK, Arnott IM, et al. Breast core-needle biopsy: clinical trial of relaxation technique versus medication versus no intervention for anxiety reduction. Radiology. Jan. 2005;234(1):73-8. [pmid: 15564386].
267 Chang JM, Moon WK, Cho N, et al. Management of ultrasonographically detected benign papillomas of the breast at core needle biopsy. AJR Am J Roentgenol. Mar. 2011;196(3):723-9. [pmid: 21343519].
268 Flory N, Lang EV. Distress in the radiology waiting room. Radiology. Jul. 2011;260(1):166-73. [pmid: 21474702].
269 Gruber R, Walter E, Helbich TH. Cost comparison between ultrasound-guided 14-g large core breast biopsy and open surgical biopsy: an analysis for Austria. Eur J Radiol. Jun. 2010;74(3):519-24. [pmid: 19427153].
270 Hahn M, Kagan KO, Siegmann KC, et al. Mammotome versus ATEC: a comparison of two breast vacuum biopsy techniques under sonographic guidance. Arch Gynecol Obstet. Feb. 2010;281(2):287-92. [pmid: 19404655].
271 Hoover SJ, Berry MP, Rossick L, et al. Ultrasound-guided breast biopsy curriculum for surgical residents. Surg Innov. Mar. 2008;15(1):52-8. [pmid: 18407929].
272 Landercasper J, Ellis RL, Mathiason MA, et al. A community breast center report card determined by participation in the national quality measures for breast centers program. Breast J. Sep–Oct. 2010;16(5):472-80. [pmid: 20722650].
273 Landercasper J, Linebarger JH, Ellis RL, et al. A quality review of the timeliness of breast cancer diagnosis and treatment in an integrated breast center. J Am Coll Surg. Apr. 2010;210(4):449-55. [pmid: 20347737].
274 Lee CH, Egglin TK, Philpotts L, et al. Cost-effectiveness of stereotactic core needle biopsy: analysis by means of mammographic findings. Radiology. Mar. 1997;202(3):849-54. [pmid: 9051045].
275 Lee T. Comparison of Breast Cancer Screening Results in Korean Middle-Aged Women: A Hospital-based Prospective Cohort Study. Osong Public Health Res Perspect. Aug. 2013;4(4):197-202. [pmid: 24159556].
276 Liao MN, Chen MF, Chen SC, et al. Uncertainty and anxiety during the diagnostic period for women with suspected breast cancer. Cancer Nurs. Jul–Aug. 2008;31(4):274-83. [pmid: 18600114].
277 Lovrics P, Hodgson N, O’Brien MA, et al. The implementation of a surgeon-directed quality improvement strategy in breast cancer surgery. Am J Surg. 2013. Nov. 8. [pmid: 24315382].
278 Michalopoulos NV, Maniou I, Zografos GC. Breast lesion excision system biopsy: the learning curve. AJR Am J Roentgenol. Nov. 2012;199(5):W667. [pmid: 23096217].
279 Moran MS, Kaufman C, Burgin C, et al. What currently defines a breast center? Initial data from the national accreditation program for breast centers. J Oncol Pract. Mar. 2013;9(2):e62-70. [pmid: 23814526].
280 Mosunjac M, Park J, Strauss A, et al. Time to treatment for patients receiving BCS in a public and a private university hospital in Atlanta. Breast J. Mar–Apr. 2012;18(2):163-7. [pmid: 22239743].
281 Novy DM, Price M, Huynh PT, et al. Percutaneous core biopsy of the breast: correlates of anxiety. Acad Radiol. Jun. 2001;8(6):467-72. [pmid: 11394538].
282 Park ER, Traeger L, Willett J, et al. A relaxation response training for women undergoing breast biopsy: exploring integrated care. Breast. Oct. 2013;22(5):799-805. [pmid: 23587450].
283 Park HL, Min SY, Kwon SH, et al. Nationwide survey of use of vacuum-assisted breast biopsy in South Korea. Anticancer Res. Dec. 2012;32(12):5459-64. [pmid: 23225452].
284 Rubin E, Mennemeyer ST, Desmond RA, et al. Reducing the cost of diagnosis of breast carcinoma: impact of ultrasound and imaging-guided biopsies on a clinical breast practice. Cancer. Jan. 15. 2001;91(2):324-32. [pmid: 11180078].
285 Sclafani LM, Bleznak A, Kelly T, et al. Training a new generation of breast surgeons: are we succeeding?. Ann Surg Oncol. Jun. 2012;19(6):1856-61. [pmid: 22219063].
286 Swan JS, Lawrence WF, Roy J. Process utility in breast biopsy. Med Decis Making. Jul–Aug. 2006;26(4):347-59. [pmid: 16855124].
287 Szynglarewicz B, Kasprzak P, Kornafel J, et al. Duration time of vacuum-assisted biopsy for nonpalpable breast masses: comparison between stereotactic and ultrasound-guided procedure. Tumori. Jul–Aug. 2011;97(4):517-21. [pmid: 21989443].
288 Walker MS, Farria D, Schmidt M, et al. Educational intervention for women undergoing image-guided breast biopsy: results of a randomized clinical trial. Cancer Control. Oct. 2007;14(4):380-7. [pmid: 17914338].
289 Wallis MG, Cheung S, Kearins O, et al. Nonoperative diagnosis--effect on repeat-operation rates in the UK breast screening programme. Eur Radiol. Feb. 2009;19(2):318-23. [pmid: 18751983].
290 Wolf R, Quan G, Calhoun K, et al. Efficiency of Core Biopsy for BI-RADS-5 Breast Lesions. Breast J. Sep–Oct. 2008;14(5):471-5. [pmid: 18821933].
291 van Breest Smallenburg V, Nederend J, Voogd AC, et al. Trends in breast biopsies for abnormalities detected at screening mammography: a population-based study in the Netherlands. Br J Cancer. Jul. 9. 2013;109(1):242-8. [pmid: 23695018].
292 Kulkarni D, Irvine T, Reyes RJ. The use of core biopsy imprint cytology in the ‘one-stop’ breast clinic. Eur J Surg Oncol. Oct. 2009;35(10):1037-40. [pmid: 19268520].
293 de Roos MA, Pijnappel RM, Groote AD, et al. Ductal carcinoma in situ presenting as microcalcifications: the effect of stereotactic large-core needle biopsy on surgical therapy. Breast. Dec. 2004;13(6):461-7. [pmid: 15563852].
294 Al-Sobhi SS, Helvie MA, Pass HA, et al. Extent of lumpectomy for breast cancer after diagnosis by stereotactic core versus wire localization biopsy. Ann Surg Oncol. Jun. 1999;6(4):330-5. [pmid: 10379852].
295 Altomare V, Guerriero G, Giacomelli L, et al. Management of nonpalpable breast lesions in a modern functional breast unit. Breast Cancer Res Treat. Sep. 2005;93(1):85-9. [pmid: 16184463].
296 Bloomston M, D’Angelo P, Galliano D, et al. One hundred consecutive advanced breast biopsy instrumentation procedures: complications, costs, and outcome. Ann Surg Oncol. Mar. 1999;6(2):195-9. [pmid: 10082046].
297 Carmon M, Rivkin L, Abu-Dalo R, et al. Increased mammographic screening and use of percutaneous image-guided core biopsy in non-palpable breast cancer: impact on surgical treatment. Isr Med Assoc J. Jun. 2004;6(6):326-8. [pmid: 15214456].
298 Chen SC, Yang HR, Hwang TL, et al. Intraoperative ultrasonographically guided excisional biopsy or vacuum-assisted core needle biopsy for nonpalpable breast lesions. Ann Surg. Nov. 2003;238(5):738-42. [pmid: 14578737].
299 Chun K, Velanovich V. Patient-perceived cosmesis and satisfaction after breast biopsy: comparison of stereotactic incisional, excisional, and wire-localized biopsy techniques. Surgery. May. 2002;131(5):497-501. [pmid: 12019401].
300 Collins LC, Connolly JL, Page DL, et al. Diagnostic agreement in the evaluation of image-guided breast core needle biopsies: results from a randomized clinical trial. Am J Surg Pathol. Jan. 2004;28(1):126-31. [pmid: 14707874].
301 Deurloo EE, Gilhuijs K, Schultze Kool LJ, et al. Displacement of breast tissue and needle deviations during stereotactic procedures. Invest Radiol. 2001;36(6):347-53. [pmid: 11410756].
302 Diebold T, Hahn T, Solbach C, et al. Evaluation of the stereotactic 8G vacuum-assisted breast biopsy in the histologic evaluation of suspicious mammography findings (BI-RADS IV). Invest Radiol. Jul. 2005;40(7):465-71. [pmid: 15973139].
303 Duchesne N, Parker SH, Lechner MC, et al. Multicenter evaluation of a new ultrasound-guided biopsy device: Improved ergonomics, sampling and rebiopsy rates. Breast J. Jan–Feb. 2007;13(1):36-43. [pmid: 17214791].
304 Elliott RL, Haynes AE, Bolin JA, et al. Stereotaxic needle localization and biopsy of occult breast lesions: first year’s experience. Am Surg. Feb. 1992;58(2):126-31. [pmid: 1550304].
305 Fenoglio ME, Gallagher JQ, Joy N, et al. Stereotactic core breast biopsy versus needle localization breast biopsy—The effect of initial diagnostic modality on surgical therapy in patients with breast cancer. Minim Invasive Ther Allied Technol. 1997;6(3):225-7.
306 Fine RE, Whitworth PW, Kim JA, et al. Low-risk palpable breast masses removed using a vacuum-assisted hand-held device. Am J Surg. Oct. 2003;186(4):362-7. [pmid: 14553851].
307 Florentine BD, Cobb CJ, Frankel K, et al. Core needle biopsy. A useful adjunct to fine-needle aspiration in select patients with palpable breast lesions. Cancer. Feb. 25. 1997;81(1):33-9. [pmid: 9100539].
308 Friese CR, Neville BA, Edge SB, et al. Breast biopsy patterns and outcomes in Surveillance, Epidemiology, and End Results-Medicare data. Cancer. Feb. 15. 2009;115(4):716-24. [pmid: 19152430].
309 Geller BM, Oppenheimer RG, Mickey RM, et al. Patient perceptions of breast biopsy procedures for screen-detected lesions. Am J Obstet Gynecol. Apr. 2004;190(4):1063-9. [pmid: 15118643].
310 Golub RM, Bennett CL, Stinson T, et al. Cost minimization study of image-guided core biopsy versus surgical excisional biopsy for women with abnormal mammograms. J Clin Oncol. Jun. 15. 2004;22(12):2430-7. [pmid: 15197205].
311 Gukas ID, Nwana EJ, Ihezue CH, et al. Tru-cut biopsy of palpable breast lesions: a practical option for pre-operative diagnosis in developing countries. Cent Afr J Med. May. 2000;46(5):127-30. [pmid: 11210334].
312 Handy RB, Fajardo LL, Innis CA, et al. Patient perceptions of stereotaxic large-core breast biopsy. Acad Radiol. Dec. 1996;3(12):1007-11. [pmid: 9017015].
313 Hatmaker AR, Donahue RM, Tarpley JL, et al. Cost-effective use of breast biopsy techniques in a Veterans health care system. Am J Surg. Nov. 2006;192(5):e37-41. [pmid: 17071179].
314 Hoffmann J. Analysis of surgical and diagnostic quality at a specialist breast unit. Breast. Aug. 2006;15(4):490-7. [pmid: 16343904].
315 Holloway CM, Saskin R, Brackstone M, et al. Variation in the use of percutaneous biopsy for diagnosis of breast abnormalities in Ontario. Ann Surg Oncol. Oct. 2007;14(10):2932-9. [pmid: 17619931].
316 Howisey RL, Acheson MB, Rowbotham RK, et al. A comparison of Medicare reimbursement and results for various imaging-guided breast biopsy techniques. Am J Surg. May. 1997;173(5):395-8. [pmid: 9168074].
317 Hui JY, Chan LK, Chan RL, et al. Prone table stereotactic breast biopsy. Hong Kong Med J. Dec. 2002;8(6):447-51. [pmid: 12459602].
318 Janes RH, Bouton MS. Initial 300 consecutive stereotactic core-needle breast biopsies by a surgical group. Am J Surg. Dec. 1994;168(6):533-6. discussion 6-7. [pmid: 7977991].
319 Johnson JM, Dalton RR, Landercasper J, et al. Image-guided or needle-localized open biopsy of mammographic malignant-appearing microcalcifications?. J Am Coll Surg. Dec. 1998;187(6):604-9. [pmid: 9849733].
320 Kaufman CS, Delbecq R, Jacobson L. Excising the reexcision: stereotactic core-needle biopsy decreases need for reexcision of breast cancer. World J Surg. Oct. 1998;22(10):1023-7. discussion 8. [pmid: 9747160].
321 Killebrew LK, Oneson RH. Comparison of the diagnostic accuracy of a vacuum-assisted percutaneous intact specimen sampling device to a vacuum-assisted core needle sampling device for breast biopsy: initial experience. Breast J. Jul–Aug. 2006;12(4):302-8. [pmid: 16848839].
322 Krainick-Strobel U, Huber B, Majer I, et al. Complete extirpation of benign breast lesions with an ultrasound-guided vacuum biopsy system. Ultrasound Obstet Gynecol. Mar. 2007;29(3):342-6. [pmid: 17167817].
323 Lehman CD, Deperi ER, Peacock S, et al. Clinical experience with MRI-guided vacuum-assisted breast biopsy. AJR Am J Roentgenol. Jun. 2005;184(6):1782-7. [pmid: 15908530].
324 Liberman L, Dershaw DD, Rosen PP, et al. Stereotaxic core biopsy of impalpable spiculated breast masses. AJR Am J Roentgenol. Sep. 1995;165(3):551-4. [pmid: 7645467].
325 Liberman L, Gougoutas CA, Zakowski MF, et al. Calcifications highly suggestive of malignancy: comparison of breast biopsy methods. AJR Am J Roentgenol. Jul. 2001;177(1):165-72. [pmid: 11418420].
326 Liberman L, Holland AE, Marjan D, et al. Underestimation of atypical ductal hyperplasia at MRI-guided 9-gauge vacuum-assisted breast biopsy. AJR Am J Roentgenol. Mar. 2007;188(3):684-90. [pmid: 17312054].
327 Liberman L, LaTrenta LR, Dershaw DD, et al. Impact of core biopsy on the surgical management of impalpable breast cancer. AJR Am J Roentgenol. Feb. 1997;168(2):495-9. [pmid: 9016234].
328 Liberman L, Morris EA, Dershaw DD, et al. Fast MRI-guided vacuum-assisted breast biopsy: initial experience. AJR Am J Roentgenol. Nov. 2003;181(5):1283-93. [pmid: 14573421].
329 Lind DS, Minter R, Steinbach B, et al. Stereotactic core biopsy reduces the reexcision rate and the cost of mammographically detected cancer. J Surg Res. Jul. 15. 1998;78(1):23-6. [pmid: 9733612].
330 Mainiero MB, Gareen IF, Bird CE, et al. Preferential use of sonographically guided biopsy to minimize patient discomfort and procedure time in a percutaneous image-guided breast biopsy program. J Ultrasound Med. Nov. 2002;21(11):1221-6. [pmid: 12418763].
331 Mariotti C, Feliciotti F, Baldarelli M, et al. Digital stereotactic biopsies for nonpalpable breast lesion. Surg Endosc. Jun. 2003;17(6):911-7. [pmid: 12632135].
332 Morrow M, Venta L, Stinson T, et al. Prospective comparison of stereotactic core biopsy and surgical excision as diagnostic procedures for breast cancer patients. Ann Surg. Apr. 2001;233(4):537-41. [pmid: 11303136].
333 Orel SG, Rosen M, Mies C, et al. MR imaging-guided 9-gauge vacuum-assisted core-needle breast biopsy: initial experience. Radiology. Jan. 2006;238(1):54-61. [pmid: 16304093].
334 Perlet C, Heywang-Kobrunner SH, Heinig A, et al. Magnetic resonance-guided, vacuum-assisted breast biopsy: results from a European multicenter study of 538 lesions. Cancer. Mar. 1. 2006;106(5):982-90. [pmid: 16456807].
335 Pijnappel RM, Peeters PH, van den Donk M, et al. Diagnostic strategies in non-palpable breast lesions. Eur J Cancer. Mar. 2002;38(4):550-5. [pmid: 11872348].
336 Popiela TJ, Tabor J, Nowak W, et al. Detectability of pre-clinical breast pathologies in own experience. Pol Przegl Chir. 2002;74(1):36-43.
337 Rotenberg L, Verhille R, Schulz-Wendtland R, et al. Multicenter clinical experience with large core soft tissue biopsy without vacuum assistance. Eur J Cancer Prev. Dec. 2004;13(6):491-8. [pmid: 15548942].
338 Schneider E, Rohling KW, Schnall MD, et al. An apparatus for MR-guided breast lesion localization and core biopsy: design and preliminary results. J Magn Reson Imaging. Sep. 2001;14(3):243-53. [pmid: 11536401].
339 Shin S, Schneider HB, Cole FJ Jr, et al. Follow-up recommendations for benign breast biopsies. Breast J. Sep–Oct. 2006;12(5):413-7. [pmid: 16958957].
340 Smith DN, Christian R, Meyer JE. Large-core needle biopsy of nonpalpable breast cancers. The impact on subsequent surgical excisions. Arch Surg. Mar. 1997;132(3):256-9. discussion 60. [pmid: 9125023].
341 Soo MS, Kliewer MA, Ghate S, et al. Stereotactic breast biopsy of noncalcified lesions: a cost-minimization analysis comparing 14-gauge multipass automated core biopsy to 14- and 11-gauge vacuum-assisted biopsy. Clin Imaging. Jan–Feb. 2005;29(1):26-33. [pmid: 15859015].
342 Strong JW, Worsham GF, Austin RM, et al. Stereotactic core biopsy of nonpalpable breast lesions. J S C Med Assoc. Dec. 1995;91(12):489-96. [pmid: 8587312].
343 Uematsu T, Kasami M, Uchida Y, et al. Ultrasonographically guided 18-gauge automated core needle breast biopsy with post-fire needle position verification (PNPV). Breast Cancer. 2007;14(2):219-28. [pmid: 17485909].
344 Verkooijen HM, Borel Rinkes IH, Peeters PH, et al. Impact of stereotactic large-core needle biopsy on diagnosis and surgical treatment of nonpalpable breast cancer. Eur J Surg Oncol. Apr. 2001;27(3):244-9. [pmid: 11393185].
345 Whitten TM, Wallace TW, Bird RE, et al. Image-guided core biopsy has advantages over needle localization biopsy for the diagnosis of nonpalpable breast cancer. Am Surg. Dec. 1997;63(12):1072-7. discussion 7-8. [pmid: 9393255].
346 Williams AB, Roberts JV, Michell MJ, et al. Prone stereotactic breast core biopsy: The impact on surgical management of nonpalpable breast cancers. Breast. 1999;8(1):12-5.
347 Wong TT, Cheung PS, Ma MK, et al. Experience of stereotactic breast biopsy using the vacuum-assisted core needle biopsy device and the advanced breast biopsy instrumentation system in Hong Kong women. Asian J Surg. Jan. 2005;28(1):18-23. [pmid: 15691792].
348 Wunderbaldinger P, Wolf G, Turetschek K, et al. Comparison of sitting versus prone position for stereotactic large-core breast biopsy in surgically proven lesions. AJR Am J Roentgenol. May. 2002;178(5):1221-5. [pmid: 11959735].
349 Yim JH, Barton P, Weber B, et al. Mammographically detected breast cancer. Benefits of stereotactic core versus wire localization biopsy. Ann Surg. Jun. 1996;223(6):688-97. discussion 97-700. [pmid: 8645042].
350 Launders. CER Breast Biopsy Project. ECRI Institute. Plymouth Meeting, PA. August. 12. 2008.
351 Bossuyt PM, Reitsma JB, Bruns DE, et al. Towards complete and accurate reporting of studies of diagnostic accuracy: The STARD Initiative. Ann Intern Med. Jan. 7. 2003;138(1):40-4. [pmid: 12513043].
352 Brennan ME, Turner RM, Ciatto S, et al. Ductal carcinoma in situ at core-needle biopsy: meta-analysis of underestimation and predictors of invasive breast cancer. Radiology. Jul. 2011;260(1):119-28. [pmid: 21493791].
353 Liebens F, Carly B, Cusumano P, et al. Breast cancer seeding associated with core needle biopsies: a systematic review. Maturitas. Feb. 20. 2009;62(2):113-23. [pmid: 19167175].
354 Schueller G, Schueller-Weidekamm C, Helbich TH. Accuracy of ultrasound-guided, large-core needle breast biopsy. Eur Radiol. Sep. 2008;18(9):1761-73. [pmid: 18414872].