# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential non-financial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential non-financial conflicts of interest identified.

The list of Peer Reviewers follows:

- Binita Ashar, M.D.
  Center for Devices and Radiological Health
  U.S. Food and Drug Administration
  Baltimore, MD
- Ira J. Bleiweiss, M.D.
  Icahn School of Medicine at Mount Sinai
  New York City, NY
- Edi Brogi, M.D.
  Memorial Sloan-Kettering Cancer Center
  New York City, NY
- Laurie L. Fajardo, M.D.
  University of Iowa Health Care
  Iowa City, IA
- Seema Khan, M.D.
  Feinberg School of Medicine
  Northwestern University
  Chicago, IL
- Tracy Lively, Ph.D.
  Cancer Diagnosis Program
  National Cancer Institute
  Bethesda, MD
- Robert A. Smith, Ph.D.
  American Cancer Society
  Atlanta, GA