# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicting opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

One Technical Expert was a patient and remains anonymous. The list of the remaining Technical Experts who participated in developing this report follows:

- Patricia Carney, Ph.D.
  Oregon Health and Science University
  Portland, OR
- Joanne Elmore, M.D., M.P.H.
  University of Washington
  School of Public Health
  Seattle, WA
- Richard E. Fine, M.D.
  Department of Surgery
  Department of Surgical Oncology
  University of Tennessee College of Medicine
  The West Clinic Comprehensive Breast Center
  Memphis, TN
- Mark A. Helvie, M.D.
  University of Michigan Health System
  Ann Arbor, MI
- Carol Lee, M.D.
  Memorial Sloan Kettering Cancer Center
  New York City, NY
- Barabara Monsees, M.D.
  Evens Professor of Women’s Health
  Department of Radiology
  Washington University School of Medicine
  St. Louis, MO
- Liane Philpotts, M.D.
  Yale University School of Medicine
  New Haven, CT
- Melissa Pilewskie, M.D.
  Memorial Sloan-Kettering Cancer Center
  Evelyn H. Lauder Breast Center
  New York City, NY