# Assessment of the Strength of Evidence

Key Question | Population | Outcome | Comparison or biopsy method | Risk of Bias | Consistency | Precision | Directness | Overall Rating | Key Findings and Comments
Key Question 1: Comparative effectiveness of core-needle biopsy and open surgical biopsy | Average risk women | Test performance | Freehand | Moderate to high | Consistent | Precise | Direct (studies investigating a given technique) | Low | – Sensitivity: 0.91 (0.80 to 0.96) – Specificity: 0.98 (0.95 to 1.00)
Key Question 1: Comparative effectiveness of core-needle biopsy and open surgical biopsy | Average risk women | Test performance | US-guided, automated | Moderate to high | Consistent | Precise | Direct (studies investigating a given technique) | Moderate | – Sensitivity: 0.99 (0.98 to 0.99) – Specificity: 0.97 (0.95 to 0.98)
Key Question 1: Comparative effectiveness of core-needle biopsy and open surgical biopsy | Average risk women | Test performance | US-guided, automated | Moderate to high | Consistent | Precise | Direct (studies investigating a given technique) | Moderate | – Sensitivity: 0.97 (0.92 to 0.99) – Specificity: 0.98 (0.96 to 0.99)
Key Question 1: Comparative effectiveness of core-needle biopsy and open surgical biopsy | Average risk women | Test performance | Stereotactically guided, automated | Moderate to high | Consistent | Precise | Direct (studies investigating a given technique) | Moderate | – Sensitivity: 0.97 (0.95 to 0.98) – Specificity: 0.97 (0.96 to 0.98)
Key Question 1: Comparative effectiveness of core-needle biopsy and open surgical biopsy | Average risk women | Test performance | Stereotactically guided, automated | Moderate to high | Consistent | Precise | Direct (studies investigating a given technique) | Moderate | – Sensitivity: 0.99 (0.98 to 0.99) – Specificity: 0.92 (0.89 to 0.94)
Key Question 1: Comparative effectiveness of core-needle biopsy and open surgical biopsy | Average risk women | Test performance | MRI-guided, automated | Moderate to high | Consistent | Imprecise | Direct (studies investigating a given technique) | Insufficient | – Sensitivity: 0.90 (0.57 to 0.99) – Specificity: 0.99 (0.91 to 1.00)
Key Question 1: Comparative effectiveness of core-needle biopsy and open surgical biopsy | Average risk women | Test performance | MRI-guided, automated | Moderate to high | Consistent | Imprecise | Direct (studies investigating a given technique) | Insufficient | – Sensitivity: 1.00 (0.98 to 1.00) – Specificity: 0.91 (0.54 to 0.99)
Key Question 1: Comparative effectiveness of core-needle biopsy and open surgical biopsy | Average risk women | Comparative test performance | US-guided, automated vs. vacuum-assisted | Moderate to high | Reliance on indirect comparisons does not allow assessment of consistency (effects are not estimable within studies) | Precise | Indirect (regression based comparisons across studies) | Low | – Difference in sensitivity: 0.01 (−0.01 to 0.06) [no difference] – Difference in specificity: −0.01 (−0.03 to 0.01) [no difference]
Key Question 1: Comparative effectiveness of core-needle biopsy and open surgical biopsy | Average risk women | Comparative test performance | Stereotactically-guided, automated vs. vacuum-assisted | Moderate to high | Reliance on indirect comparisons does not allow assessment of consistency (effects are not estimable within studies) | Precise | Indirect (regression based comparisons across studies) | Low | – Difference in sensitivity: −0.02 (−0.04 to −0.01) [vacuum-assisted is better] – Difference in specificity: 0.05 (0.02 to 0.08) [automated is better]
Key Question 1: Comparative effectiveness of core-needle biopsy and open surgical biopsy | Average risk women | Comparative test performance | MRI-guided, automated vs. vacuum-assisted | Moderate to high | Reliance on indirect comparisons does not allow assessment of consistency (effects are not estimable within studies) | Very imprecise | Indirect (regression based comparisons across studies) | Insufficient | – Difference in sensitivity: −0.10 (−0.43 to −0.01) [vacuum-assisted is better] – Difference in specificity: 0.07 (−0.03 to 0.43) [no difference]
Key Question 1: Comparative effectiveness of core-needle biopsy and open surgical biopsy | Average risk women | DCIS underestimation | Ultrasound-guided, automated | Moderate to high | Moderately inconsistent | Imprecise | Comparisons between tests were indirect (across studies) | Low | – Average underestimation probability: 0.38 (0.26 to 0.51) [14 studies]
Key Question 1: Comparative effectiveness of core-needle biopsy and open surgical biopsy | Average risk women | DCIS underestimation | Ultrasound-guided, vacuum-assisted | Moderate to high | Moderately inconsistent | Imprecise | Comparisons between tests were indirect (across studies) | Low | – Average underestimation probability: 0.09 (0.02 to 0.26) [5 studies]
Key Question 1: Comparative effectiveness of core-needle biopsy and open surgical biopsy | Average risk women | DCIS underestimation | Stereotactically guided, automated | Moderate to high | Moderately inconsistent | Imprecise | Comparisons between tests were indirect (across studies) | Low | – Average underestimation probability: 0.26 (0.19 to 0.36) [18 studies]
Key Question 1: Comparative effectiveness of core-needle biopsy and open surgical biopsy | Average risk women | DCIS underestimation | Stereotactically guided, vacuum-assisted | Moderate to high | Moderately inconsistent | Imprecise | Comparisons between tests were indirect (across studies) | Low | – Average underestimation probability: 0.11 (0.08 to 0.14) [34 studies]
Key Question 1: Comparative effectiveness of core-needle biopsy and open surgical biopsy | Average risk women | DCIS underestimation | Other biopsy methods | Moderate to high | Moderately inconsistent | Imprecise | Comparisons between tests were indirect (across studies) | Insufficient | No available studies or few studies with small numbers of lesions.
Key Question 1: Comparative effectiveness of core-needle biopsy and open surgical biopsy | Average risk women | High risk lesion underestimation rate | Ultrasound-guided, automated | Moderate to high | Moderately inconsistent | Imprecise | Comparisons between tests were indirect (across studies) | Low | – Average underestimation probability: 0.25 (0.16 to 0.36) [21 studies]
Key Question 1: Comparative effectiveness of core-needle biopsy and open surgical biopsy | Average risk women | High risk lesion underestimation rate | Ultrasound-guided, vacuum-assisted | Moderate to high | Moderately inconsistent | Imprecise | Comparisons between tests were indirect (across studies) | Low | – Average underestimation probability: 0.11 (0.02 to 0.33) [9 studies]
Key Question 1: Comparative effectiveness of core-needle biopsy and open surgical biopsy | Average risk women | High risk lesion underestimation rate | Stereotactically guided, automated | Moderate to high | Moderately inconsistent | Imprecise | Comparisons between tests were indirect (across studies) | Low | – Average underestimation probability: 0.47 (0.37 to 0.58) [29 studies]
Key Question 1: Comparative effectiveness of core-needle biopsy and open surgical biopsy | Average risk women | High risk lesion underestimation rate | Stereotactically guided, vacuum-assisted | Moderate to high | Moderately inconsistent | Imprecise | Comparisons between tests were indirect (across studies) | Low | – Average underestimation probability: 0.18 (0.13 to 0.24) [40 studies]
Key Question 1: Comparative effectiveness of core-needle biopsy and open surgical biopsy | Average risk women | High risk lesion underestimation rate | Other biopsy methods | Moderate to high | Moderately inconsistent | Imprecise | Comparisons between tests were indirect (across studies) | Insufficient | No available studies or few studies with small numbers of lesions.
Key Question 1: Comparative effectiveness of core-needle biopsy and open surgical biopsy | Women at high risk of cancer | Test performance | All biopsy methods | Moderate to high | Number and sample size of studies does not allow assessment of consistency | Imprecise | Direct (studies investigating a given technique) | Insufficient | No available studies or few studies with small numbers of lesions.
Key Question 1: Comparative effectiveness of core-needle biopsy and open surgical biopsy | Women at high risk of cancer | Comparative test performance | Comparisons of biopsy methods using the same imaging guidance | Moderate to high | Number and sample size of studies does not allow assessment of consistency | Imprecise | Comparisons between tests were indirect (across studies) or not possible | Insufficient | No available studies or few studies with small numbers of lesions.
Key Question 1: Comparative effectiveness of core-needle biopsy and open surgical biopsy | Women at high risk of cancer | DCIS underestimation | All biopsy methods | Moderate to high | Number and sample size of studies does not allow assessment of consistency | Imprecise | Comparisons between tests were indirect (across studies) or not possible | Insufficient | No available studies or few studies with small numbers of lesions.
Key Question 1: Comparative effectiveness of core-needle biopsy and open surgical biopsy | Women at high risk of cancer | High risk lesion underestimation | All biopsy methods | Moderate to high | Number and sample size of studies does not allow assessment of consistency | Imprecise | Comparisons between tests were indirect (across studies) or not possible | Insufficient | No available studies or few studies with small numbers of lesions.
Key Question 1: Comparative effectiveness of core-needle biopsy and open surgical biopsy | Women at average and high risk of breast cancer | Modifiers of test performance | All biopsy methods | Moderate to high | Unclear | Imprecise | Indirect | Insufficient | – Few studies provided within sample information for each modifier of interest; meta-regression results rely on cross-study comparisons so consistency of effects cannot be assessed – Within-study (direct) evidence was sparse; between study evidence relied on indirect comparisons across studies – In meta-regression analyses CrIs were wide and extreme odds ratio values were often observed because sensitivity and specificity for all tests were very close to 1 (see Results for additional details)
Key Question 2: Adverse events of core-needle biopsy and open surgical biopsy | All patient populations | Any complications | Open vs. core-needle biopsy | NA | NA | NA | NA | Not rated | – Few studies provided information on open biopsy; comparisons of methods are indirect and based on limited empirical evidence and expert opinion – Open surgical biopsy is associated with an increased incidence of adverse events compared to core-needle biopsy
Key Question 2: Adverse events of core-needle biopsy and open surgical biopsy | All patient populations | Severe complications | Open vs. core-needle biopsy | NA | NA | NA | NA | Not rated | – Few studies provided information on open biopsy; comparisons of methods are indirect and based on limited empirical evidence and expert opinion – Open surgical biopsy is associated with an increased incidence of serious adverse events compared to core-needle biopsy
Key Question 2: Adverse events of core-needle biopsy and open surgical biopsy | All patient populations | Bleeding (any severity) | Comparisons among all core-needle biopsy methods | Moderate to high | Consistent | Imprecise | Indirect | Low | – Median %: 1.21 (25^th^ perc. = 0.33; 75^th^ perc. = 3.97) – Selective outcome and analysis reporting likely – Few studies reported bleeding requiring treatment; the event rate was low (<0.40 perc.) in those studies
Key Question 2: Adverse events of core-needle biopsy and open surgical biopsy | All patient populations | Bleeding events that require treatment | Comparisons among all core-needle biopsy methods | Moderate to high | Consistent | Imprecise | Indirect | Low | – Median %: 0 (25^th^ perc. = 0; 75^th^ perc. = 0.14) – Selective outcome and analysis reporting likely – Few studies reported bleeding requiring treatment; the event rate was low
Key Question 2: Adverse events of core-needle biopsy and open surgical biopsy | All patient populations | Hematoma formation | Comparisons among all core-needle biopsy methods | Moderate to high | Consistent | Imprecise | Indirect | Low | – Median %: 1.44 (25^th^ perc. = 0.25; 75^th^ perc.= 8.57) – Selective outcome and analysis reporting likely
Key Question 2: Adverse events of core-needle biopsy and open surgical biopsy | All patient populations | Infectious complications | Comparisons among all core-needle biopsy methods | Moderate to high | Consistent | Imprecise | Indirect | Low | – Median %: 0 (25^th^ perc. = 0; 75^th^ perc.= 0.33) – Selective outcome and analysis reporting likely
Key Question 2: Adverse events of core-needle biopsy and open surgical biopsy | All patient populations | Vasovagal reactions: | Comparisons among all core-needle biopsy methods | Moderate to high | Consistent | Imprecise | Indirect | Low | – Median %: 1.27 (25^th^ perc. = 0.37; 75^th^ perc.= 3.88) – Potential for selective outcome and analysis reporting
Key Question 2: Adverse events of core-needle biopsy and open surgical biopsy | All patient populations | Pain and severe pain | Comparisons among all core-needle biopsy methods | Moderate to high | Consistent | Imprecise | Indirect | Low | 25 studies of a wide variety of biopsy methods reported information about patient pain during the procedure (pain was assessed heterogeneously across studies).
Key Question 2: Adverse events of core-needle biopsy and open surgical biopsy | All patient populations | Other adverse events | Comparisons among all core-needle biopsy methods | Moderate to high | Unclear | Imprecise | Indirect | Insufficient | – Most events were reported by a single study precluding assessment of consistency – Individual studies did not provide adequate information for precise estimation of the event rate) – Only informal indirect comparisons among biopsy methods were possible – Potential for selective outcome and analysis reporting
Key Question 2: Adverse events of core-needle biopsy and open surgical biopsy | All patient populations | Modifiers of test adverse events – vasovagal reactions | Sitting upright during the biopsy procedure | Moderate to high | Unclear (few available studies; heterogeneous reporting) | Imprecise | Direct | Low | – Vasovagal reactions were more common among patients sitting during the biopsy procedure – Results were reported in few studies (11 studies; 8 from the original evidence report and 3 from this update) – Potential for selective outcome and analysis reporting
Key Question 2: Adverse events of core-needle biopsy and open surgical biopsy | All patient populations | Modifiers of test adverse events – bleeding | Vacuum-assisted versus non-vacuum assisted biopsy methods | Moderate to high | Fairly consistent | Imprecise | Indirect | Low | – Vacuum-assisted procedures were generally associated with increased rates of bleeding and hematoma formation – Bleeding events were generally uncommon – Comparisons among biopsy methods were based on informal indirect comparisons (across studies) – Potential for selective outcome and analysis reporting
Key Question 2: Adverse events of core-needle biopsy and open surgical biopsy | All patient populations | All other modifiers of adverse events | Comparisons among all core-needle biopsy methods | Moderate to high | Unclear | Imprecise (and sometimes impossible to assess due to incomplete information) | Direct | Insufficient | – Most factors assessed by a single study limiting our ability to assess consistency – Potential for selective outcome and analysis reporting. – Within-study comparisons provided direct evidence

CrI = credible interval; DCIS = ductal carcinoma in situ; NA = not applicable; perc.= percentile