# Sensitivity Analysis to the Exclusion of High Risk Lesions on Core Needle Biopsy That Were Confirmed to be High Risk Lesions in Subsequent Open Biopsy or Surgical Excision

Table C1 Summary estimates of test performance for alternative core-needle biopsy methods – women at average risk of cancer

Biopsy method or device | Sensitivity | Specificity
Freehand, automated | 0.91 (0.80 to 0.96) | 0.99 (0.97 to 1.00)
US-guided, automated | 0.99 (0.98 to 0.99) | 0.99 (0.98 to 1.00)
US-guided, vacuum-assisted | 0.97 (0.92 to 0.99) | 0.99 (0.97 to 1.00)
Stereotactically guided, automated | 0.97 (0.95 to 0.98) | 0.98 (0.97 to 0.99)
Stereotactically guided, vacuum-assisted | 0.99 (0.98 to 0.99) | 0.96 (0.94 to 0.98)
MRI-guided, automated | 0.90 (0.57 to 0.99) | 0.99 (0.89 to 1.00)
MRI-guided, vacuum-assisted | 1.00 (0.98 to 1.00) | 0.93 (0.42 to 1.00)
Multiple methods/other | 0.99 (0.98 to 0.99) | 0.97 (0.96 to 0.99)

CrI = credible interval; DCIS = ductal carcinoma in situ; MRI = magnetic resonance imaging; N = number; NA = not applicable; US = ultrasound

Note: All numbers are medians with 95% CrIs. ‘Other’ denotes one study using grid guidance and one study that did not report information on the use of vacuum assistance.

Table C2 Summary estimates of test performance for alternative core-needle biopsy methods – women at high risk of cancer

Biopsy method or device | Sensitivity (95% CrI) | Specificity (95% CrI)
Stereotactically guided, automated | 0.97 (0.82, 1.00) | 0.98 (0.91, 1.00)
Stereotactically guided, vacuum-assisted | 0.99 (0.93, 1.00) | 0.97 (0.83, 0.99)
MRI-guided, automated | 0.90 (0.58, 0.98) | 0.99 (0.91, 1.00)
MRI-guided, vacuum-assisted | 1.00 (0.98, 1.00) | 0.94 (0.52, 1.00)

CrI = credible interval; DCIS = ductal carcinoma in situ; MRI = magnetic resonance imaging; N = number; US = ultrasound

Note: All numbers are medians with 95% CrIs. No studies provided information on the test performance of freehand or US-guided biopsy methods, or the use of multiple methods in populations of women at high risk of cancer. Results are based on bivariate model with risk group as a covariate.