# Excluded Studies

Reason for Exclusion | Excluded Studies (see list of references on the next page)
< 10 patients, no seeding | 1–35
> 15% current or previous breast cancer | 36–110
Case control or retrospective case study | 111–260
Incomplete reference standard | 261–315
Instrument no longer available | 316
Less than 50% follow-up | 317–372
No CNB or CNB not for diagnosis of breast cancer in women | 373–573 574–769
No primary data | 770–825
Non-English full text | 826–914
Not outcome of interest (no KQ1, KQ2, KQ3) | 915–1107 1108–1281 1282–1363 1364–1479
Selected on the basis of CNB or final outcomes | 1480–1649 1650–1896 1897–2018 2019–2164

CNB = core-needle biopsy; KQ = Key Question.

## Citations to Excluded Studies

1 Idiopathic granulomatous mastitis in Hispanic women - Indiana, 2006–2008. MMWR Morb Mortal Wkly Rep. Dec. 4. 2009;58(47):1317-21. [pmid: 19959984].
2 Abrari A. Pseudoangiomatous stromal hyperplasia (PASH) tumour at the surgical scar site in a patient of carcinoma breast. BMJ Case Rep. 2011. 2011. [pmid: 22688488].
3 Baker KS, Davey DD, Stelling CB. Ductal abnormalities detected with galactography: frequency of adequate excisional biopsy. AJR Am J Roentgenol. Apr. 1994;162(4):821-4. [pmid: 8140998].
4 Beatty JS, Williams HT, Aldridge BA, et al. Incidental PET/CT findings in the cancer patient: how should they be managed?. Surgery. Aug. 2009;146(2):274-81. [pmid: 19628085].
5 Bitencourt AG, Cohen MP, Graziano L, et al. Pseudoaneurysm after ultrasound-guided vacuum-assisted core breast biopsy. Breast J. Mar–Apr. 2012;18(2):177-8. [pmid: 22211950].
6 Chung A, Schoder H, Sampson M, et al. Incidental breast lesions identified by 18F-fluorodeoxyglucose-positron emission tomography. Ann Surg Oncol. Aug. 2010;17(8):2119-25. [pmid: 20162459].
7 Dey D, Nicol A, Singer S. Benign phyllodes tumor of the breast with intracytoplasmic inclusion bodies identical to infantile digital fibromatosis. Breast J. Mar–Apr. 2008;14(2):198-9. [pmid: 18266786].
8 Drubin D, Smith JS, Liu W, et al. Comparison of cryopreservation and standard needle biopsy for gene expression profiling of human breast cancer specimens. Breast Cancer Res Treat. Mar. 2005;90(1):93-6. [pmid: 15770532].
9 Dutta Roy S, Kasipandian V, Scally J. Suspicious breast mass in an anticoagulated patient--is core biopsy safe?. Int J Clin Pract. Oct. 2008;62(10):1632-4. [pmid: 18822034].
10 Erdil I, Dursun M, Salmaslioglu A, et al. Pseudoaneurysm in the breast after core biopsy: doppler US and MRI findings. Breast J. Jul–Aug. 2010;16(4):427-9. [pmid: 20545941].
11 Fischman AM, Epelboym Y, Siegelbaum RH, et al. Emergent embolization of arterial bleeding after vacuum-assisted breast biopsy. Cardiovasc Intervent Radiol. Feb. 2012;35(1):194-7. [pmid: 21553162].
12 Fong CY, Mak WS, Lui CY, et al. Stereotactic biopsy of thin breasts: A previously unfeasible task. Hong Kong. 2011;14(1):4-9.
13 Kamer E, Unalp HR, Akguner T, et al. Thick-needle vacuum-assisted biopsy technique for inflammatory breast carcinoma diagnosis. Acta Cirurgica Brasileira. 2006;21(6):422-4. [pmid: 17160256].
14 Kamer E, Unalp HR, Akguner T, et al. Thick-needle vacuum-assisted biopsy technique for inflammatory breast carcinoma diagnosis. Acta Cir Bras. Nov–Dec. 2006;21(6):422-4. [pmid: 17160256].
15 Kiyoto S, Sugawara Y, Inoue T, et al. False-positive (18)F-fluorodeoxyglucose positron emission tomography/computed tomography caused by incidental injury in a bulky intracystic carcinoma of the breast. Jpn J Radiol. May. 2010;28(4):305-8. [pmid: 20512549].
16 Kuhl CK, Elevelt A, Leutner CC, et al. Interventional breast MR imaging: clinical use of a stereotactic localization and biopsy device. Radiology. Sep. 1997;204(3):667-75. [pmid: 9280242].
17 Magro G. Epithelioid-cell myofibroblastoma of the breast: expanding the morphologic spectrum. Am J Surg Pathol. Jul. 2009;33(7):1085-92. [pmid: 19390423].
18 Mendel JB, Long M, Slanetz PJ. CT-guided core needle biopsy of breast lesions visible only on MRI. AJR Am J Roentgenol. Jul. 2007;189(1):152-4. [pmid: 17579165].
19 Nath ME, Robinson TM, Tobon H, et al. Automated large-core needle biopsy of surgically removed breast lesions: comparison of samples obtained with 14-, 16-, and 18-gauge needles. Radiology. Dec. 1995;197(3):739-42. [pmid: 7480748].
20 O’Driscoll D, Britton P, Bobrow L, et al. Lobular carcinoma in situ on core biopsy-what is the clinical significance?. Clin Radiol. Mar. 2001;56(3):216-20. [pmid: 11247699].
21 Ogawa T, Tsuji E, Shirakawa K, et al. Primary non-Hodgkin’s lymphoma of the breast treated nonsurgically: report of three cases. Breast Cancer. Jan. 2011;18(1):68-72. [pmid: 19350354].
22 O’Sullivan-Mejia E, Idowu MO, Davis Masssey H, et al. Lymphoepithelioma-like carcinoma of the breast: diagnosis by core needle biopsy. Breast J. Nov–Dec. 2009;15(6):658-60. [pmid: 19824996].
23 Romero-Guadarrama MB, Hernandez-Gonzalez MM, Duran-Padilla MA, et al. Primary lymphomas of the breast: a report on 5 cases studied in a period of 5 years at the Hospital General de Mexico. Ann Diagn Pathol. Apr. 2009;13(2):78-81. [pmid: 19302954].
24 Roque DR, MacLaughlan S, Tejada-Berges T. Necrotizing infection of the breast after core needle biopsy. Breast J. Mar–Apr. 2013;19(2):201-2. [pmid: 23294339].
25 Ruiz Tovar J, Reguero Callejas ME, Alaez Chillaron AB, et al. Mammary hamartoma. Clin Transl Oncol. Apr. 2006;8(4):290-3. [pmid: 16648106].
26 Ruiz-Delgado ML, Lopez-Ruiz JA, Saiz-Lopez A. Abnormal mammography and sonography associated with foreign-body giant-cell reaction after stereotactic vacuum-assisted breast biopsy with carbon marking. Acta Radiol. Dec. 2008;49(10):1112-8. [pmid: 18932053].
27 Samimi M, Bonneau C, Lebas P, et al. Mastectomies after vacuum core biopsy procedure for microcalcification clusters: value of clip. Eur J Radiol. Feb. 2009;69(2):296-9. [pmid: 18178050].
28 Singh E, Selis JE. Ultrasound-guided percutaneous biopsy of the augmented breast using implant displacement: a new technique. Ultrasound Q. Sep. 2010;26(3):179-81. [pmid: 20823752].
29 Soo MS, Walsh R, Patton J. Prone table stereotactic breast biopsy: facilitating biopsy of posterior lesions using the arm-through-the-hole technique. AJR Am J Roentgenol. Sep. 1998;171(3):615-7. [pmid: 9725284].
30 Tilve A, Mallo R, Perez A, et al. Breast hemangiomas: correlation between imaging and pathologic findings. J Clin Ultrasound. Oct. 2012;40(8):512-7. [pmid: 22434703].
31 Wahner-Roedler DL, Whaley DH, Brandt KR, et al. Vacuum-assisted breast biopsy device (mammotome) malfunction simulating microcalcifications. Breast J. Nov–Dec. 2005;11(6):474-5. [pmid: 16297098].
32 Wang CF, Zhou Z, Yan YJ, et al. Clinical analyses of clustered microcalcifications after autologous fat injection for breast augmentation. Plast Reconstr Surg. Apr. 2011;127(4):1669-73. [pmid: 21187809].
33 Wei H, Jiayi F, Qinping Z, et al. Ultrasound-guided vacuum-assisted breast biopsy system for diagnosis and minimally invasive excision of intraductal papilloma without nipple discharge. World J Surg. Dec. 2009;33(12):2579-81. [pmid: 19777298].
34 Yalcin S, Ergul E, Ucar AE, et al. Glomus tumor of the breast: first report. Langenbecks Arch Surg. Mar. 2009;394(2):399-400. [pmid: 18446361].
35 Yoshida M, Kinoshita T. A case of ductal carcinoma in situ of the breast. Jpn J Clin Oncol. 2009;39(2):132. [pmid: 19155284].
36 Abe H, Schmidt RA, Shah RN, et al. MR-directed (“Second-Look”) ultrasound examination for breast lesions detected initially on MRI: MR and sonographic findings. AJR Am J Roentgenol. Feb. 2010;194(2):370-7. [pmid: 20093598].
37 Berg WA, Arnoldus CL, Teferra E, et al. Biopsy of Amorphous Breast Calcifications: Pathologic Outcome and Yield at Stereotactic Biopsy 1. Radiology. 2001;221(2):495-503. [pmid: 11687695].
38 Berg WA, Madsen KS, Schilling K, et al. Comparative effectiveness of positron emission mammography and MRI in the contralateral breast of women with newly diagnosed breast cancer. AJR Am J Roentgenol. Jan. 2012;198(1):219-32. [pmid: 22194501].
39 Bernik SF, Troob S, Ying BL, et al. Papillary lesions of the breast diagnosed by core needle biopsy: 71 cases with surgical follow-up. Am J Surg. Apr. 2009;197(4):473-8. [pmid: 18723154].
40 Brennan S, Liberman L, Dershaw DD, et al. Breast MRI screening of women with a personal history of breast cancer. AJR Am J Roentgenol. Aug. 2010;195(2):510-6. [pmid: 20651211].
41 Brennan SB, Sung JS, Dershaw DD, et al. Cancellation of MR imaging-guided breast biopsy due to lesion nonvisualization: frequency and follow-up. Radiology. Oct. 2011;261(1):92-9. [pmid: 21852565].
42 Britton PD, Provenzano E, Barter S, et al. Ultrasound guided percutaneous axillary lymph node core biopsy: how often is the sentinel lymph node being biopsied?. Breast. Feb. 2009;18(1):13-6. [pmid: 18993074].
43 Carbognin G, Girardi V, Brandalise A, et al. MR-guided vacuum-assisted breast biopsy in the management of incidental enhancing lesions detected by breast MR imaging. Radiol Med. Sep. 2011;116(6):876-85. [pmid: 21293942].
44 Chae EY, Cha JH, Kim HH, et al. Evaluation of residual disease using breast MRI after excisional biopsy for breast cancer. AJR Am J Roentgenol. May. 2013;200(5):1167-73. [pmid: 23617506].
45 Chan A, Morey A, Brown B, et al. A retrospective study investigating the rate of HER2 discordance between primary breast carcinoma and locoregional or metastatic disease. BMC Cancer. 2012;12:555. [pmid: 23176370].
46 Choi HY, Kim SM, Jang M, et al. MRI-guided intervention for breast lesions using the freehand technique in a 3.0-T closed-bore MRI scanner: feasibility and initial results. Korean J Radiol. Mar–Apr. 2013;14(2):171-8. [pmid: 23482868].
47 Crystal P, Sadaf A, Bukhanov K, et al. High-risk lesions diagnosed at MRI-guided vacuum-assisted breast biopsy: can underestimation be predicted?. Eur Radiol. Mar. 2011;21(3):582-9. [pmid: 20839000].
48 Davis KL, Barth RJ Jr, Gui J, et al. Use of MRI in preoperative planning for women with newly diagnosed DCIS: risk or benefit?. Ann Surg Oncol. Oct. 2012;19(10):3270-4. [pmid: 22911365].
49 Demartini WB, Eby PR, Peacock S, et al. Utility of targeted sonography for breast lesions that were suspicious on MRI. AJR Am J Roentgenol. Apr. 2009;192(4):1128-34. [pmid: 19304724].
50 DeMartini WB, Liu F, Peacock S, et al. Background parenchymal enhancement on breast MRI: impact on diagnostic performance. AJR Am J Roentgenol. Apr. 2012;198(4):W373-80. [pmid: 22451576].
51 Destounis S, Arieno A, Somerville PA, et al. Community-based practice experience of unsuspected breast magnetic resonance imaging abnormalities evaluated with second-look sonography. J Ultrasound Med. Oct. 2009;28(10):1337-46. [pmid: 19778880].
52 Deurloo EE, Sriram JD, Teertstra HJ, et al. MRI of the breast in patients with DCIS to exclude the presence of invasive disease. Eur Radiol. Jul. 2012;22(7):1504-11. [pmid: 22367470].
53 Dogan BE, Le-Petross CH, Stafford JR, et al. MRI-guided vacuum-assisted breast biopsy performed at 3 T with a 9-gauge needle: preliminary experience. AJR Am J Roentgenol. Nov. 2012;199(5):W651-3. [pmid: 23096211].
54 Eliahou R, Sella T, Allweis T, et al. Magnetic resonance-guided interventional procedures of the breast: initial experience. Isr Med Assoc J. May. 2009;11(5):275-9. [pmid: 19637504].
55 Elmore L, Margenthaler JA. Breast MRI surveillance in women with prior curative-intent therapy for breast cancer. J Surg Res. Sep. 2010;163(1):58-62. [pmid: 20605594].
56 Friedman P, Enis S, Pinyard J. Magnetic resonance imaging-guided vacuum-assisted breast biopsy: an initial experience in a community hospital. Can Assoc Radiol J. Oct. 2009;60(4):196-200. [pmid: 19782886].
57 Ginter PS, Winant AJ, Hoda SA. Cystic apocrine hyperplasia is the most common finding in MRI detected breast lesions. J Clin Pathol. Feb. 2014;67(2):182-6. [pmid: 24151291].
58 Grobmyer SR, Mortellaro VE, Marshall J, et al. Is there a role for routine use of MRI in selection of patients for breast-conserving cancer therapy?. J Am Coll Surg. May. 2008;206(5):1045-50. discussion 50-2. [pmid: 18471753].
59 Gutierrez RL, Demartini WB, Eby P, et al. Clinical indication and patient age predict likelihood of malignancy in suspicious breast MRI lesions. Acad Radiol. Oct. 2009;16(10):1281-5. [pmid: 19733804].
60 Gutierrez RL, DeMartini WB, Eby PR, et al. BI-RADS lesion characteristics predict likelihood of malignancy in breast MRI for masses but not for nonmasslike enhancement. AJR Am J Roentgenol. Oct. 2009;193(4):994-1000. [pmid: 19770321].
61 Han BK, Schnall MD, Orel SG, et al. Outcome of MRI-guided breast biopsy. AJR Am J Roentgenol. Dec. 2008;191(6):1798-804. [pmid: 19020252].
62 Hauth EA, Jaeger HJ, Lubnau J, et al. MR-guided vacuum-assisted breast biopsy with a handheld biopsy system: clinical experience and results in postinterventional MR mammography after 24 h. Eur Radiol. Jan. 2008;18(1):168-76. [pmid: 17609959].
63 He Q, Fan X, Guan Y, et al. Percutaneous excisional biopsy of impalpable breast lesions under ultrasound visualization. The Breast. 2008;17(6):666-70. [pmid: 18835778].
64 Heller SL, Moy L. Imaging features and management of high-risk lesions on contrast-enhanced dynamic breast MRI. AJR Am J Roentgenol. Feb. 2012;198(2):249-55. [pmid: 22268165].
65 Johnson KS, Baker JA, Lee SS, et al. Suspicious breast lesions detected at 3.0 T magnetic resonance imaging: clinical and histological outcomes. Acad Radiol. Jun. 2012;19(6):667-74. [pmid: 22459645].
66 Kalinyak JE, Schilling K, Berg WA, et al. PET-guided breast biopsy. Breast J. Mar–Apr. 2011;17(2):143-51. [pmid: 21276128].
67 Lee JH, Kim EK, Oh JY, et al. US screening for detection of nonpalpable locoregional recurrence after mastectomy. Eur J Radiol. Mar. 2013;82(3):485-9. [pmid: 23131395].
68 Lee JM, Kaplan JB, Murray MP, et al. Imaging histologic discordance at MRI-guided 9-gauge vacuum-assisted breast biopsy. AJR Am J Roentgenol. Oct. 2007;189(4):852-9. [pmid: 17885056].
69 Lee JM, Kaplan JB, Murray MP, et al. Underestimation of DCIS at MRI-guided vacuum-assisted breast biopsy. AJR Am J Roentgenol. Aug. 2007;189(2):468-74. [pmid: 17646475].
70 Lee J-M, Kaplan JB, Murray MP, et al. Imaging–histologic discordance at MRI-guided 9-gauge vacuum-assisted breast biopsy. American Journal of Roentgenology. 2007;189(4):852-9. [pmid: 17885056].
71 Liberman L, Bracero N, Morris E, et al. MRI-guided 9-gauge vacuum-assisted breast biopsy: initial clinical experience. AJR Am J Roentgenol. Jul. 2005;185(1):183-93. [pmid: 15972421].
72 Liberman L, Dershaw DD, Durfee S, et al. Recurrent carcinoma after breast conservation: diagnosis with stereotaxic core biopsy. Radiology. Dec. 1995;197(3):735-8. [pmid: 7480747].
73 Liberman L, Morris EA, Dershaw DD, et al. Fast MRI-guided vacuum-assisted breast biopsy: initial experience. American Journal of Roentgenology. 2003;181(5):1283-93. [pmid: 14573421].
74 Linda A, Zuiani C, Lorenzon M, et al. Hyperechoic lesions of the breast: not always benign. AJR Am J Roentgenol. May. 2011;196(5):1219-24. [pmid: 21512095].
75 Malhaire C, El Khoury C, Thibault F, et al. Vacuum-assisted biopsies under MR guidance: results of 72 procedures. Eur Radiol. Jul. 2010;20(7):1554-62. [pmid: 20119729].
76 Mameri CS, Kemp C, Goldman SM, et al. Impact of breast MRI on surgical treatment, axillary approach, and systemic therapy for breast cancer. Breast J. May–Jun. 2008;14(3):236-44. [pmid: 18476882].
77 Masroor I, Afzal S, Shafqat G, et al. Comparison of stereotactic core breast biopsy and open surgical biopsy results at a tertiary care hospital in Pakistan. Int J Womens Health. 2011;3:193-6. [pmid: 21792341].
78 Meeuwis C, Mann RM, Mus RD, et al. MRI-guided breast biopsy at 3T using a dedicated large core biopsy set: feasibility and initial results. Eur J Radiol. Aug. 2011;79(2):257-61. [pmid: 20541338].
79 Meeuwis C, Veltman J, van Hall HN, et al. MR-guided breast biopsy at 3T: diagnostic yield of large core needle biopsy compared with vacuum-assisted biopsy. Eur Radiol. Feb. 2012;22(2):341-9. [pmid: 21915606].
80 Meissnitzer M, Dershaw DD, Lee CH, et al. Targeted ultrasound of the breast in women with abnormal MRI findings for whom biopsy has been recommended. AJR Am J Roentgenol. Oct. 2009;193(4):1025-9. [pmid: 19770325].
81 Noroozian M, Gombos EC, Chikarmane S, et al. Factors that impact the duration of MRI-guided core needle biopsy. AJR Am J Roentgenol. Feb. 2010;194(2):W150-7. [pmid: 20093566].
82 Onega T, Weiss J, Diflorio R, et al. Evaluating surveillance breast imaging and biopsy in older breast cancer survivors. Int J Breast Cancer. 2012;2012:347646. [pmid: 23097709].
83 Orel SG, Rosen M, Mies C, et al. MR Imaging–guided 9-gauge Vacuum-assisted Core-Needle Breast Biopsy: Initial Experience 1. Radiology. 2006;238(1):54-61. [pmid: 16304093].
84 Oxner CR, Vora L, Yim J, et al. Magnetic resonance imaging-guided breast biopsy in lesions not visualized by mammogram or ultrasound. Am Surg. Oct. 2012;78(10):1087-90. [pmid: 23025947].
85 Parikh RP, Doren EL, Mooney B, et al. Differentiating fat necrosis from recurrent malignancy in fat-grafted breasts: an imaging classification system to guide management. Plast Reconstr Surg. Oct. 2012;130(4):761-72. [pmid: 23018689].
86 Perlet C, Heinig A, Prat X, et al. Multicenter study for the evaluation of a dedicated biopsy device for MR-guided vacuum biopsy of the breast. Eur Radiol. Jun. 2002;12(6):1463-70. [pmid: 12042955].
87 Perlet C, Heywang-Kobrunner SH, Heinig A, et al. Magnetic resonance-guided, vacuum-assisted breast biopsy. Cancer. 2006;106(5):982-90. [pmid: 16456807].
88 Perretta T, Pistolese CA, Bolacchi F, et al. MR imaging-guided 10-gauge vacuum-assisted breast biopsy: histological characterisation. Radiol Med. Sep. 2008;113(6):830-40. [pmid: 18633687].
89 Pfleiderer SO, Marx C, Vagner J, et al. Magnetic resonance-guided large-core breast biopsy inside a 1.5-T magnetic resonance scanner using an automatic system: in vitro experiments and preliminary clinical experience in four patients. Invest Radiol. Jul. 2005;40(7):458-63. [pmid: 15973138].
90 Pijnappel RM, Peeters PH, van den Donk M, et al. Diagnostic strategies in non-palpable breast lesions. Eur J Cancer. Mar. 2002;38(4):550-5. [pmid: 11872348].
91 Pijnappel RM, van den Donk M, Holland R, et al. Diagnostic accuracy for different strategies of image-guided breast intervention in cases of nonpalpable breast lesions. Br J Cancer. Feb. 9. 2004;90(3):595-600. [pmid: 14760370].
92 Popiela TJ, Herman-Sucharska I, Kleinrok K, et al. Core breast biopsy under MR control - Preliminary results. Pol Przegl Radiol. 2007;72(2):15-24.
93 Rauch GM, Dogan BE, Smith TB, et al. Outcome analysis of 9-gauge MRI-guided vacuum-assisted core needle breast biopsies. AJR Am J Roentgenol. Feb. 2012;198(2):292-9. [pmid: 22268171].
94 Raza S, Sekar M, Ong EM, et al. Small masses on breast MR: is biopsy necessary?. Acad Radiol. Apr. 2012;19(4):412-9. [pmid: 22277636].
95 Salem C, Sakr R, Chopier J, et al. Pain and complications of directional vacuum-assisted stereotactic biopsy: comparison of the Mammotome and Vacora techniques. Eur J Radiol. Nov. 2009;72(2):295-9. [pmid: 18755562].
96 Salem C, Sakr R, Chopier J, et al. Accuracy of stereotactic vacuum-assisted breast biopsy with a 10-gauge hand-held system. Breast. Jun. 2009;18(3):178-82. [pmid: 19364652].
97 Schneider JP, Schulz T, Horn LC, et al. MR-guided percutaneous core biopsy of small breast lesions: first experience with a vertically open 0.5T scanner. J Magn Reson Imaging. Apr. 2002;15(4):374-85. [pmid: 11948826].
98 Schrading S, Simon B, Braun M, et al. MRI-guided breast biopsy: influence of choice of vacuum biopsy system on the mode of biopsy of MRI-only suspicious breast lesions. AJR Am J Roentgenol. Jun. 2010;194(6):1650-7. [pmid: 20489109].
99 Sequeiros RB, Reinikainen H, Sequeiros AM, et al. MR-guided breast biopsy and hook wire marking using a low-field (0.23 T) scanner with optical instrument tracking. Eur Radiol. Mar. 2007;17(3):813-9. [pmid: 17021710].
100 Slanetz PJ, Wu SP, Mendel JB. Percutaneous excision: a viable alternative to manage benign breast lesions. Can Assoc Radiol J. Nov. 2011;62(4):265-71. [pmid: 20615659].
101 Sung JS, Malak SF, Bajaj P, et al. Screening breast MR imaging in women with a history of lobular carcinoma in situ. Radiology. Nov. 2011;261(2):414-20. [pmid: 21900617].
102 Thompson MO, Lipson J, Daniel B, et al. Why are patients noncompliant with follow-up recommendations after MRI-guided core needle biopsy of suspicious breast lesions?. AJR Am J Roentgenol. Dec. 2013;201(6):1391-400. [pmid: 24261382].
103 Tozaki M, Yamashiro N, Sakamoto M, et al. Magnetic resonance-guided vacuum-assisted breast biopsy: results in 100 Japanese women. Jpn J Radiol. Aug. 2010;28(7):527-33. [pmid: 20799018].
104 Tozaki M, Yamashiro N, Suzuki T, et al. MR-guided vacuum-assisted breast biopsy: is it an essential technique?. Breast Cancer. 2009;16(2):121-5. [pmid: 18807122].
105 van de Ven SM, Lin MC, Daniel BL, et al. Freehand MRI-guided preoperative needle localization of breast lesions after MRI-guided vacuum-assisted core needle biopsy without marker placement. J Magn Reson Imaging. Jul. 2010;32(1):101-9. [pmid: 20575077].
106 van den Bosch MA, Daniel BL, Pal S, et al. MRI-guided needle localization of suspicious breast lesions: results of a freehand technique. Eur Radiol. Aug. 2006;16(8):1811-7. [pmid: 16683117].
107 Wilhelm A, McDonough MD, DePeri ER. Malignancy rates of non-masslike enhancement on breast magnetic resonance imaging using American College of Radiology Breast Imaging Reporting and Data System descriptors. Breast J. Nov–Dec. 2012;18(6):523-6. [pmid: 23009294].
108 Wiratkapun C, Fusuwankaya E, Wibulpholprasert B, et al. Diagnostic accuracy of vacuum-assisted stereotactic core needle biopsy for breast lesions. J Med Assoc Thai. Sep. 2010;93(9):1058-64. [pmid: 20873078].
109 Zebic-Sinkovec M, Hertl K, Kadivec M, et al. Outcome of MRI-guided vacuum-assisted breast biopsy - initial experience at Institute of Oncology Ljubljana, Slovenia. Radiol Oncol. Jun. 2012;46(2):97-105. [pmid: 23077445].
110 Zografos G, Zagouri F, Sergentanis TN, et al. Vacuum-assisted breast biopsy in nonpalpable solid breast lesions without microcalcifications: the Greek experience. Diagn Interv Radiol. 2008;14(3):127-30. [pmid: 18814132].
111 Acheson MB, Patton RG, Howisey RL, et al. Three- to six-year followup for 379 benign image-guided large-core needle biopsies of nonpalpable breast abnormalities. J Am Coll Surg. Oct. 2002;195(4):462-6. [pmid: 12375750].
112 Agoff SN, Lawton TJ. Papillary lesions of the breast with and without atypical ductal hyperplasia: can we accurately predict benign behavior from core needle biopsy?. Am J Clin Pathol. Sep. 2004;122(3):440-3. [pmid: 15362376].
113 Arora N, Hill C, Hoda SA, et al. Clinicopathologic features of papillary lesions on core needle biopsy of the breast predictive of malignancy. Am J Surg. Oct. 2007;194(4):444-9. [pmid: 17826053].
114 Arpino G, Allred DC, Mohsin SK, et al. Lobular neoplasia on core-needle biopsy--clinical significance. Cancer. Jul. 15. 2004;101(2):242-50. [pmid: 15241819].
115 Ashkenazi I, Ferrer K, Sekosan M, et al. Papillary lesions of the breast discovered on percutaneous large core and vacuum-assisted biopsies: reliability of clinical and pathological parameters in identifying benign lesions. Am J Surg. Aug. 2007;194(2):183-8. [pmid: 17618801].
116 Baer HJ, Collins LC, Connolly JL, et al. Lobule type and subsequent breast cancer risk: results from the Nurses’ Health Studies. Cancer. Apr. 1. 2009;115(7):1404-11. [pmid: 19170235].
117 Bauer VP, Ditkoff BA, Schnabel F, et al. The management of lobular neoplasia identified on percutaneous core breast biopsy. Breast J. Jan–Feb. 2003;9(1):4-9. [pmid: 12558663].
118 Becker L, Trop I, David J, et al. Management of radial scars found at percutaneous breast biopsy. Can Assoc Radiol J. Apr. 2006;57(2):72-8. [pmid: 16944680].
119 Bedei L, Falcini F, Sanna PA, et al. Atypical ductal hyperplasia of the breast: the controversial management of a borderline lesion: experience of 47 cases diagnosed at vacuum-assisted biopsy. Breast. Apr. 2006;15(2):196-202. [pmid: 16055333].
120 Berg WA, Campassi CI, Ioffe OB. Cystic lesions of the breast: sonographic-pathologic correlation. Radiology. Apr. 2003;227(1):183-91. [pmid: 12668745].
121 Berg WA, Mrose HE, Ioffe OB. Atypical lobular hyperplasia or lobular carcinoma in situ at core-needle breast biopsy. Radiology. Feb. 2001;218(2):503-9. [pmid: 11161169].
122 Bode MK, Rissanen T, Apaja-Sarkkinen M. Ultrasonography and core needle biopsy in the differential diagnosis of fibroadenoma and tumor phyllodes. Acta Radiol. Sep. 2007;48(7):708-13. [pmid: 17728999].
123 Bonnett M, Wallis T, Rossmann M, et al. Histopathologic analysis of atypical lesions in image-guided core breast biopsies. Mod Pathol. Feb. 2003;16(2):154-60. [pmid: 12591968].
124 Bonnett M, Wallis T, Rossmann M, et al. Histologic and radiographic analysis of ductal carcinoma in situ diagnosed using stereotactic incisional core breast biopsy. Mod Pathol. Feb. 2002;15(2):95-101. [pmid: 11850537].
125 Brem R, Tran K, Rapelyea J, et al. Percutaneous Biopsy of Papillary Lesions of the Breast: Accuracy of Pathologic Diagnosis. JOURNAL OF WOMENS IMAGING. 2005;7(4):157.
126 Brem RF, Behrndt VS, Sanow L, et al. Atypical ductal hyperplasia: histologic underestimation of carcinoma in tissue harvested from impalpable breast lesions using 11-gauge stereotactically guided directional vacuum-assisted biopsy. AJR Am J Roentgenol. May. 1999;172(5):1405-7. [pmid: 10227526].
127 Brem RF, Lechner MC, Jackman RJ, et al. Lobular neoplasia at percutaneous breast biopsy: variables associated with carcinoma at surgical excision. AJR Am J Roentgenol. Mar. 2008;190(3):637-41. [pmid: 18287433].
128 Brenner RJ, Jackman RJ, Parker SH, et al. Percutaneous core needle biopsy of radial scars of the breast: when is excision necessary?. AJR Am J Roentgenol. Nov. 2002;179(5):1179-84. [pmid: 12388495].
129 Buchbender S, Obenauer S, Mohrmann S, et al. Arterial spin labelling perfusion MRI of breast cancer using FAIR TrueFISP: initial results. Clin Radiol. Mar. 2013;68(3):e123-7. [pmid: 23245275].
130 Burbank F. Stereotactic breast biopsy of atypical ductal hyperplasia and ductal carcinoma in situ lesions: improved accuracy with directional, vacuum-assisted biopsy. Radiology. 1997;202(3):843-7. [pmid: 9051043].
131 Carder PJ, Khan T, Burrows P, et al. Large volume “mammotome” biopsy may reduce the need for diagnostic surgery in papillary lesions of the breast. J Clin Pathol. Aug. 2008;61(8):928-33. [pmid: 18495791].
132 Cawson JN, Malara F, Kavanagh A, et al. Fourteen-gauge needle core biopsy of mammographically evident radial scars: is excision necessary?. Cancer. Jan. 15. 2003;97(2):345-51. [pmid: 12518358].
133 Chrzan R, Rudnicka L, Popiela T Jr, et al. The problems with histopathological verification of breast microcalcification clusters in the stereotactic mammotome biopsy specimens. Pol J Pathol. 2006;57(3):133-5. [pmid: 17219739].
134 Cox D, Bradley S, England D. The significance of mammotome core biopsy specimens without radiographically identifiable microcalcification and their influence on surgical management--a retrospective review with histological correlation. Breast. Apr. 2006;15(2):210-8. [pmid: 16081287].
135 Crisi GM, Mandavilli S, Cronin E, et al. Invasive mammary carcinoma after immediate and short-term follow-up for lobular neoplasia on core biopsy. Am J Surg Pathol. Mar. 2003;27(3):325-33. [pmid: 12604888].
136 Darling ML, Smith DN, Lester SC, et al. Atypical ductal hyperplasia and ductal carcinoma in situ as revealed by large-core needle breast biopsy: results of surgical excision. AJR Am J Roentgenol. Nov. 2000;175(5):1341-6. [pmid: 11044038].
137 Das S, Sen S, Mukherjee A, et al. Risk factors of breast cancer among women in eastern India: a tertiary hospital based case control study. Asian Pac J Cancer Prev. 2012;13(10):4979-81. [pmid: 23244094].
138 Day AC. Pilot study on the effect of smoking one cigarette on physiological postural tremors. Agressologie. 1977;18. Spec No:9–18. [pmid: 900365].
139 de Mascarel I, Brouste V, Asad-Syed M, et al. All atypia diagnosed at stereotactic vacuum-assisted breast biopsy do not need surgical excision. Mod Pathol. Sep. 2011;24(9):1198-206. [pmid: 21602816].
140 Deschryver K, Radford DM, Schuh ME. Pathology of large-caliber stereotactic biopsies in nonpalpable breast lesions. Semin Diagn Pathol. Aug. 1999;16(3):224-34. [pmid: 10490199].
141 Destounis S, Hanson S, Morgan R, et al. Computer-aided detection of breast carcinoma in standard mammographic projections with digital mammography. Int J Comput Assist Radiol Surg. Jun. 2009;4(4):331-6. [pmid: 20033580].
142 Dillon MF, McDermott EW, Hill AD, et al. Predictive value of breast lesions of “uncertain malignant potential” and “suspicious for malignancy” determined by needle core biopsy. Ann Surg Oncol. Feb. 2007;14(2):704-11. [pmid: 17151788].
143 Dillon MF, McDermott EW, Quinn CM, et al. Predictors of invasive disease in breast cancer when core biopsy demonstrates DCIS only. J Surg Oncol. Jun. 1. 2006;93(7):559-63. [pmid: 16705731].
144 Dillon MF, Quinn CM, McDermott EW, et al. Needle core biopsy in the diagnosis of phyllodes neoplasm. Surgery. Nov. 2006;140(5):779-84. [pmid: 17084721].
145 DiPiro PJ, Meyer JE, Denison CM, et al. Image-guided core breast biopsy of ductal carcinoma in situ presenting as a non-calcified abnormality. Eur J Radiol. Jun. 1999;30(3):231-6. [pmid: 10452723].
146 Dmytrasz K, Tartter PI, Mizrachy H, et al. The significance of atypical lobular hyperplasia at percutaneous breast biopsy. Breast J. Jan–Feb. 2003;9(1):10-2. [pmid: 12558664].
147 Doren E, Hulvat M, Norton J, et al. Predicting cancer on excision of atypical ductal hyperplasia. Am J Surg. Mar. 2008;195(3):358-61. discussion 61-2. [pmid: 18206849].
148 Douglas-Jones AG, Denson JL, Cox AC, et al. Radial scar lesions of the breast diagnosed by needle core biopsy: analysis of cases containing occult malignancy. J Clin Pathol. Mar. 2007;60(3):295-8. [pmid: 16731590].
149 Dupont WD, Breyer JP, Bradley KM, et al. Protein phosphatase 2A subunit gene haplotypes and proliferative breast disease modify breast cancer risk. Cancer. Jan. 1. 2010;116(1):8-19. [pmid: 19890961].
150 Easley S, Abdul-Karim FW, Klein N, et al. Segregation of radiographic calcifications in stereotactic core biopsies of breast: is it necessary?. Breast J. Sep–Oct. 2007;13(5):486-9. [pmid: 17760670].
151 Eby PR, Ochsner JE, DeMartini WB, et al. Is surgical excision necessary for focal atypical ductal hyperplasia found at stereotactic vacuum-assisted breast biopsy?. Ann Surg Oncol. Nov. 2008;15(11):3232-8. [pmid: 18696163].
152 Elsheikh TM, Silverman JF. Follow-up surgical excision is indicated when breast core needle biopsies show atypical lobular hyperplasia or lobular carcinoma in situ: a correlative study of 33 patients with review of the literature. Am J Surg Pathol. Apr. 2005;29(4):534-43. [pmid: 15767810].
153 Ely KA, Carter BA, Jensen RA, et al. Core biopsy of the breast with atypical ductal hyperplasia: a probabilistic approach to reporting. Am J Surg Pathol. Aug. 2001;25(8):1017-21. [pmid: 11474285].
154 Esserman LE, Lamea L, Tanev S, et al. Should the extent of lobular neoplasia on core biopsy influence the decision for excision?. Breast J. Jan–Feb. 2007;13(1):55-61. [pmid: 17214794].
155 Forgeard C, Benchaib M, Guerin N, et al. Is surgical biopsy mandatory in case of atypical ductal hyperplasia on 11-gauge core needle biopsy? A retrospective study of 300 patients. Am J Surg. Sep. 2008;196(3):339-45. [pmid: 18585676].
156 Foster MC, Helvie MA, Gregory NE, et al. Lobular carcinoma in situ or atypical lobular hyperplasia at core-needle biopsy: is excisional biopsy necessary?. Radiology. Jun. 2004;231(3):813-9. [pmid: 15105449].
157 Foxcroft LM, Evans EB, Porter AJ. Difficulties in the pre-operative diagnosis of phyllodes tumours of the breast: a study of 84 cases. Breast. Feb. 2007;16(1):27-37. [pmid: 16876413].
158 Gadzala DE, Cederbom GJ, Bolton JS, et al. Appropriate management of atypical ductal hyperplasia diagnosed by stereotactic core needle breast biopsy. Ann Surg Oncol. Jun. 1997;4(4):283-6. [pmid: 9181225].
159 Gal-Gombos EC, Esserman LE, Recine MA, et al. Large-needle core biopsy in atypical intraductal epithelial hyperplasia including immunohistochemical expression of high molecular weight cytokeratin: analysis of results of a single institution. Breast J. Sep–Oct. 2002;8(5):269-74. [pmid: 12199753].
160 Gatek J, Vrana D, Melichar B, et al. Significance of the resection margin and risk factors for close or positive resection margin in patients undergoing breast-conserving surgery. J BUON. Jul–Sep. 2012;17(3):452-6. [pmid: 23033280].
161 Gendler LS, Feldman SM, Balassanian R, et al. Association of breast cancer with papillary lesions identified at percutaneous image-guided breast biopsy. Am J Surg. Oct. 2004;188(4):365-70. [pmid: 15474427].
162 Georgian-Smith D, Kricun B, McKee G, et al. The mammary hamartoma: appreciation of additional imaging characteristics. J Ultrasound Med. Oct. 2004;23(10):1267-73. [pmid: 15448315].
163 Grady I, Gorsuch H, Wilburn-Bailey S. Ultrasound-guided, vacuum-assisted, percutaneous excision of breast lesions: an accurate technique in the diagnosis of atypical ductal hyperplasia. J Am Coll Surg. Jul. 2005;201(1):14-7. [pmid: 15978438].
164 Harvey JM, Sterrett GF, Frost FA. Atypical ductal hyperplasia and atypia of uncertain significance in core biopsies from mammographically detected lesions: correlation with excision diagnosis. Pathology. Oct. 2002;34(5):410-6. [pmid: 12408338].
165 Harvey SC, Denison CM, Lester SC, et al. Fibrous nodules found at large-core needle biopsy of the breast: imaging features. Radiology. May. 1999;211(2):535-40. [pmid: 10228539].
166 Hoorntje LE, Schipper ME, Peeters PH, et al. The finding of invasive cancer after a preoperative diagnosis of ductal carcinoma-in-situ: causes of ductal carcinoma-in-situ underestimates with stereotactic 14-gauge needle biopsy. Ann Surg Oncol. 2003;10(7):748-53. [pmid: 12900365].
167 Houssami N, Ciatto S, Bilous M, et al. Borderline breast core needle histology: predictive values for malignancy in lesions of uncertain malignant potential (B3). Br J Cancer. Apr. 23. 2007;96(8):1253-7. [pmid: 17438578].
168 Huo L, Sneige N, Hunt KK, et al. Predictors of invasion in patients with core-needle biopsy-diagnosed ductal carcinoma in situ and recommendations for a selective approach to sentinel lymph node biopsy in ductal carcinoma in situ. Cancer. Oct. 15. 2006;107(8):1760-8. [pmid: 16977650].
169 Hwang H, Barke LD, Mendelson EB, et al. Atypical lobular hyperplasia and classic lobular carcinoma in situ in core biopsy specimens: routine excision is not necessary. Mod Pathol. Oct. 2008;21(10):1208-16. [pmid: 18660792].
170 Ivan D, Selinko V, Sahin AA, et al. Accuracy of core needle biopsy diagnosis in assessing papillary breast lesions: histologic predictors of malignancy. Mod Pathol. Feb. 2004;17(2):165-71. [pmid: 14631369].
171 Jackman RJ, Birdwell RL, Ikeda DM. Atypical ductal hyperplasia: can some lesions be defined as probably benign after stereotactic 11-gauge vacuum-assisted biopsy, eliminating the recommendation for surgical excision?. Radiology. Aug. 2002;224(2):548-54. [pmid: 12147855].
172 Jackman RJ, Burbank F, Parker SH, et al. Stereotactic breast biopsy of nonpalpable lesions: determinants of ductal carcinoma in situ underestimation rates. Radiology. Feb. 2001;218(2):497-502. [pmid: 11161168].
173 Jang M, Cho N, Moon WK, et al. Underestimation of atypical ductal hyperplasia at sonographically guided core biopsy of the breast. AJR Am J Roentgenol. Nov. 2008;191(5):1347-51. [pmid: 18941067].
174 Johnson JM, Dalton RR, Wester SM, et al. Histological correlation of microcalcifications in breast biopsy specimens. Arch Surg. Jul. 1999;134(7):712-5. discussion 5-6. [pmid: 10401820].
175 Karabakhtsian RG, Johnson R, Sumkin J, et al. The clinical significance of lobular neoplasia on breast core biopsy. Am J Surg Pathol. May. 2007;31(5):717-23. [pmid: 17460455].
176 Kil WH, Cho EY, Kim JH, et al. Is surgical excision necessary in benign papillary lesions initially diagnosed at core biopsy?. Breast. Jun. 2008;17(3):258-62. [pmid: 18054232].
177 Kim MJ, Kim EK, Kwak JY, et al. Nonmalignant papillary lesions of the breast at US-guided directional vacuum-assisted removal: a preliminary report. Eur Radiol. Sep. 2008;18(9):1774-83. [pmid: 18446345].
178 Kim MY, Cho N, Yi A, et al. Sonoelastography in distinguishing benign from malignant complex breast mass and making the decision to biopsy. Korean J Radiol. Jul–Aug. 2013;14(4):559-67. [pmid: 23901312].
179 King TA, Cederbom GJ, Champaign JL, et al. A core breast biopsy diagnosis of invasive carcinoma allows for definitive surgical treatment planning. Am J Surg. Dec. 1998;176(6):497-501. [pmid: 9926778].
180 Kneeshaw PJ, Turnbull LW, Smith A, et al. Dynamic contrast enhanced magnetic resonance imaging aids the surgical management of invasive lobular breast cancer. Eur J Surg Oncol. Feb. 2003;29(1):32-7. [pmid: 12559074].
181 Ko ES, Cho N, Cha JH, et al. Sonographically-guided 14-gauge core needle biopsy for papillary lesions of the breast. Korean J Radiol. May–Jun. 2007;8(3):206-11. [pmid: 17554187].
182 Komenaka IK, El-Tamer M, Pile-Spellman E, et al. Core needle biopsy as a diagnostic tool to differentiate phyllodes tumor from fibroadenoma. Arch Surg. Sep. 2003;138(9):987-90. [pmid: 12963656].
183 Kunju LP, Kleer CG. Significance of flat epithelial atypia on mammotome core needle biopsy: Should it be excised?. Hum Pathol. Jan. 2007;38(1):35-41. [pmid: 17095049].
184 Lam WW, Chu WC, Tse GM, et al. Role of fine needle aspiration and tru cut biopsy in diagnosis of mucinous carcinoma of breast--from a radiologist’s perspective. Clin Imaging. Jan–Feb. 2006;30(1):6-10. [pmid: 16377477].
185 Lavoue V, Graesslin O, Classe JM, et al. Management of lobular neoplasia diagnosed by core needle biopsy: study of 52 biopsies with follow-up surgical excision. Breast. Oct. 2007;16(5):533-9. [pmid: 17629481].
186 Lee CH, Carter D, Philpotts LE, et al. Ductal carcinoma in situ diagnosed with stereotactic core needle biopsy: can invasion be predicted?. Radiology. Nov. 2000;217(2):466-70. [pmid: 11058647].
187 Leikola J, Heikkila P, Pamilo M, et al. Predicting invasion in patients with DCIS in the preoperative percutaneous biopsy. Acta Oncol. 2007;46(6):798-802. [pmid: 17653903].
188 Liberman L, Bracero N, Vuolo MA, et al. Percutaneous large-core biopsy of papillary breast lesions. AJR Am J Roentgenol. Feb. 1999;172(2):331-7. [pmid: 9930777].
189 Liberman L, Cohen MA, Dershaw DD, et al. Atypical ductal hyperplasia diagnosed at stereotaxic core biopsy of breast lesions: an indication for surgical biopsy. AJR Am J Roentgenol. May. 1995;164(5):1111-3. [pmid: 7717215].
190 Liberman L, Dershaw D, Rosen P, et al. Stereotaxic core biopsy of impalpable spiculated breast masses. AJR Am J Roentgenol. 1995;165(3):551-4. [pmid: 7645467].
191 Liberman L, Drotman M, Morris EA, et al. Imaging-histologic discordance at percutaneous breast biopsy. Cancer. Dec. 15. 2000;89(12):2538-46. [pmid: 11135213].
192 Liberman L, Sama M, Susnik B, et al. Lobular carcinoma in situ at percutaneous breast biopsy: surgical biopsy findings. AJR Am J Roentgenol. Aug. 1999;173(2):291-9. [pmid: 10430122].
193 Liberman L, Tornos C, Huzjan R, et al. Is surgical excision warranted after benign, concordant diagnosis of papilloma at percutaneous breast biopsy?. AJR Am J Roentgenol. May. 2006;186(5):1328-34. [pmid: 16632727].
194 Lim CN, Ho BC, Bay BH, et al. Nuclear morphometry in columnar cell lesions of the breast: is it useful?. J Clin Pathol. Dec. 2006;59(12):1283-6. [pmid: 16603646].
195 Lin PH, Clyde JC, Bates DM, et al. Accuracy of stereotactic core-needle breast biopsy in atypical ductal hyperplasia. Am J Surg. May. 1998;175(5):380-2. [pmid: 9600282].
196 Londero V, Zuiani C, Furlan A, et al. Role of ultrasound and sonographically guided core biopsy in the diagnostic evaluation of ductal carcinoma in situ (DCIS) of the breast. Radiol Med. Sep. 2007;112(6):863-76. [pmid: 17891529].
197 Londero V, Zuiani C, Linda A, et al. Lobular neoplasia: core needle breast biopsy underestimation of malignancy in relation to radiologic and pathologic features. Breast. Dec. 2008;17(6):623-30. [pmid: 18619840].
198 Lopez-Medina A, Cintora E, Mugica B, et al. Radial scars diagnosed at stereotactic core-needle biopsy: surgical biopsy findings. Eur Radiol. Aug. 2006;16(8):1803-10. [pmid: 16708220].
199 Lourenco AP, Mainiero MB, Lazarus E, et al. Stereotactic breast biopsy: comparison of histologic underestimation rates with 11- and 9-gauge vacuum-assisted breast biopsy. AJR Am J Roentgenol. Nov. 2007;189(5):W275-9. [pmid: 17954625].
200 Maganini RO, Klem DA, Huston BJ, et al. Upgrade rate of core biopsy-determined atypical ductal hyperplasia by open excisional biopsy. Am J Surg. Oct. 2001;182(4):355-8. [pmid: 11720670].
201 Makar AB, McMartin KE, Palese M, et al. Formate assay in body fluids: application in methanol poisoning. Biochem Med. Jun. 1975;13(2):117-26. [pmid: 1].
202 Martel M, Barron-Rodriguez P, Tolgay Ocal I, et al. Flat DIN 1 (flat epithelial atypia) on core needle biopsy: 63 cases identified retrospectively among 1,751 core biopsies performed over an 8-year period (1992–1999). Virchows Arch. Nov. 2007;451(5):883-91. [pmid: 17786469].
203 Masood S, Loya A, Khalbuss W. Is core needle biopsy superior to fine-needle aspiration biopsy in the diagnosis of papillary breast lesions?. Diagn Cytopathol. Jun. 2003;28(6):329-34. [pmid: 12768640].
204 McKian KP, Reynolds CA, Visscher DW, et al. Novel breast tissue feature strongly associated with risk of breast cancer. J Clin Oncol. Dec. 10. 2009;27(35):5893-8. [pmid: 19805686].
205 Mendez I, Andreu FJ, Saez E, et al. Ductal carcinoma in situ and atypical ductal hyperplasia of the breast diagnosed at stereotactic core biopsy. Breast J. Jan–Feb. 2001;7(1):14-8. [pmid: 11348410].
206 Menon S, Porter GJ, Evans AJ, et al. The significance of lobular neoplasia on needle core biopsy of the breast. Virchows Arch. May. 2008;452(5):473-9. [pmid: 18389278].
207 Mercado CL, Hamele-Bena D, Oken SM, et al. Papillary lesions of the breast at percutaneous core-needle biopsy. Radiology. Mar. 2006;238(3):801-8. [pmid: 16424237].
208 Mercado CL, Hamele-Bena D, Singer C, et al. Papillary lesions of the breast: evaluation with stereotactic directional vacuum-assisted biopsy. Radiology. Dec. 2001;221(3):650-5. [pmid: 11719659].
209 Middleton LP, Grant S, Stephens T, et al. Lobular carcinoma in situ diagnosed by core needle biopsy: when should it be excised?. Mod Pathol. Feb. 2003;16(2):120-9. [pmid: 12591964].
210 Miller KL, Marks LB, Barrier RC Jr, et al. Increased sectioning of pathologic specimens with ductal carcinoma in situ of the breast: are there clinical consequences?. Clin Breast Cancer. Aug. 2003;4(3):198-202. [pmid: 14499013].
211 Millos J, Costas-Rodriguez M, Lavilla I, et al. Multielemental determination in breast cancerous and non-cancerous biopsies by inductively coupled plasma-mass spectrometry following small volume microwave-assisted digestion. Anal Chim Acta. Aug. 1. 2008;622(1–2):77-84. [pmid: 18602537].
212 Mitnick JS, Gianutsos R, Pollack AH, et al. Tubular carcinoma of the breast: sensitivity of diagnostic techniques and correlation with histopathology. AJR Am J Roentgenol. Feb. 1999;172(2):319-23. [pmid: 9930775].
213 Mitnick JS, Gianutsos R, Pollack AH, et al. Comparative Value of Mammography, Fine-Needle Aspiration Biopsy, and Core Biopsy in the Diagnosis of Invasive Lobular Carcinoma. Breast J. 1998;4(2):75-83.
214 O’Hea B J, Tornos C. Mild ductal atypia after large-core needle biopsy of the breast: is surgical excision always necessary?. Surgery. Oct. 2000;128(4):738-43. [pmid: 11015109].
215 Pan J, Dogan BE, Carkaci S, et al. Comparing performance of the CADstream and the DynaCAD breast MRI CAD systems : CADstream vs. DynaCAD in breast MRI. J Digit Imaging. Oct. 2013;26(5):971-6. [pmid: 23589186].
216 Philpotts LE, Lee CH, Horvath LJ, et al. Underestimation of breast cancer with II-gauge vacuum suction biopsy. AJR Am J Roentgenol. Oct. 2000;175(4):1047-50. [pmid: 11000162].
217 Philpotts LE, Shaheen NA, Jain KS, et al. Uncommon high-risk lesions of the breast diagnosed at stereotactic core-needle biopsy: clinical importance. Radiology. Sep. 2000;216(3):831-7. [pmid: 10966718].
218 Puglisi F, Zuiani C, Bazzocchi M, et al. Role of mammography, ultrasound and large core biopsy in the diagnostic evaluation of papillary breast lesions. Oncology. 2003;65(4):311-5. [pmid: 14707450].
219 Rao A, Parker S, Ratzer E, et al. Atypical ductal hyperplasia of the breast diagnosed by 11-gauge directional vacuum-assisted biopsy. Am J Surg. Dec. 2002;184(6):534-7. discussion 7. [pmid: 12488158].
220 Renshaw AA. Adequate histologic sampling of breast core needle biopsies. Arch Pathol Lab Med. Aug. 2001;125(8):1055-7. [pmid: 11473457].
221 Renshaw AA. Can mucinous lesions of the breast be reliably diagnosed by core needle biopsy?. Am J Clin Pathol. Jul. 2002;118(1):82-4. [pmid: 12109860].
222 Renshaw AA, Cartagena N, Derhagopian RP, et al. Lobular neoplasia in breast core needle biopsy specimens is not associated with an increased risk of ductal carcinoma in situ or invasive carcinoma. Am J Clin Pathol. May. 2002;117(5):797-9. [pmid: 12090431].
223 Renshaw AA, Cartagena N, Schenkman RH, et al. Atypical ductal hyperplasia in breast core needle biopsies. Correlation of size of the lesion, complete removal of the lesion, and the incidence of carcinoma in follow-up biopsies. Am J Clin Pathol. Jul. 2001;116(1):92-6. [pmid: 11447758].
224 Renshaw AA, Derhagopian RP, Martinez P, et al. Lobular neoplasia in breast core needle biopsy specimens is associated with a low risk of ductal carcinoma in situ or invasive carcinoma on subsequent excision. Am J Clin Pathol. Aug. 2006;126(2):310-3. [pmid: 16891208].
225 Renshaw AA, Derhagopian RP, Tizol-Blanco DM, et al. Papillomas and atypical papillomas in breast core needle biopsy specimens: risk of carcinoma in subsequent excision. Am J Clin Pathol. Aug. 2004;122(2):217-21. [pmid: 15323138].
226 Renshaw AA, Gould EW. Comparison of disagreement and amendment rates by tissue type and diagnosis: identifying cases for directed blinded review. Am J Clin Pathol. Nov. 2006;126(5):736-9. [pmid: 17050070].
227 Rizzo M, Lund MJ, Oprea G, et al. Surgical follow-up and clinical presentation of 142 breast papillary lesions diagnosed by ultrasound-guided core-needle biopsy. Ann Surg Oncol. Apr. 2008;15(4):1040-7. [pmid: 18204989].
228 Gombos EC, Godinez J, Poppiti RJ. Significance of extent of lobular neoplasia on breast core biopsy. J Womens Imaging.
229 Rosen EL, Bentley RC, Baker JA, et al. Imaging-guided core needle biopsy of papillary lesions of the breast. AJR Am J Roentgenol. Nov. 2002;179(5):1185-92. [pmid: 12388496].
230 Rosen EL, Soo MS, Bentley RC. Focal fibrosis: a common breast lesion diagnosed at imaging-guided core biopsy. AJR Am J Roentgenol. Dec. 1999;173(6):1657-62. [pmid: 10584816].
231 Rutstein LA, Johnson RR, Poller WR, et al. Predictors of residual invasive disease after core needle biopsy diagnosis of ductal carcinoma in situ. Breast J. May–Jun. 2007;13(3):251-7. [pmid: 17461899].
232 Saxena A, Dhillon VS, Shahid M, et al. GSTP1 methylation and polymorphism increase the risk of breast cancer and the effects of diet and lifestyle in breast cancer patients. Exp Ther Med. Dec. 2012;4(6):1097-103. [pmid: 23226781].
233 Shepherd JA, Kerlikowske K, Ma L, et al. Volume of mammographic density and risk of breast cancer. Cancer Epidemiol Biomarkers Prev. Jul. 2011;20(7):1473-82. [pmid: 21610220].
234 Shin HJ, Kim HH, Kim SM, et al. Papillary lesions of the breast diagnosed at percutaneous sonographically guided biopsy: comparison of sonographic features and biopsy methods. AJR Am J Roentgenol. Mar. 2008;190(3):630-6. [pmid: 18287432].
235 Shin SJ, Rosen PP. Excisional biopsy should be performed if lobular carcinoma in situ is seen on needle core biopsy. Arch Pathol Lab Med. Jun. 2002;126(6):697-701. [pmid: 12033958].
236 Sie A, Bryan DC, Gaines V, et al. Multicenter evaluation of the breast lesion excision system, a percutaneous, vacuum-assisted, intact-specimen breast biopsy device. Cancer. Sep. 1. 2006;107(5):945-9. [pmid: 16874817].
237 Skandarajah AR, Field L, Yuen Larn Mou A, et al. Benign papilloma on core biopsy requires surgical excision. Ann Surg Oncol. Aug. 2008;15(8):2272-7. [pmid: 18473143].
238 Sklair-Levy M, Samuels TH, Catzavelos C, et al. Stromal fibrosis of the breast. AJR Am J Roentgenol. Sep. 2001;177(3):573-7. [pmid: 11517049].
239 Smetherman D, Dydynski P, Jackson P. Effect of breast core needle biopsy technique on detection of lobular intraepithelial neoplasia. Ochsner J. Fall. 2007;7(3):121-4. [pmid: 21603526].
240 Sneige N, Lim SC, Whitman GJ, et al. Atypical ductal hyperplasia diagnosis by directional vacuum-assisted stereotactic biopsy of breast microcalcifications. Considerations for surgical excision. Am J Clin Pathol. Feb. 2003;119(2):248-53. [pmid: 12579995].
241 Sohn V, Arthurs Z, Herbert G, et al. Atypical ductal hyperplasia: improved accuracy with the 11-gauge vacuum-assisted versus the 14-gauge core biopsy needle. Ann Surg Oncol. Sep. 2007;14(9):2497-501. [pmid: 17564749].
242 Sohn VY, Arthurs ZM, Kim FS, et al. Lobular neoplasia: is surgical excision warranted?. Am Surg. Feb. 2008;74(2):172-7. [pmid: 18306873].
243 Sydnor MK, Wilson JD, Hijaz TA, et al. Underestimation of the presence of breast carcinoma in papillary lesions initially diagnosed at core-needle biopsy. Radiology. Jan. 2007;242(1):58-62. [pmid: 17090707].
244 Tocino I, Garcia BM, Carter D. Surgical biopsy findings in patients with atypical hyperplasia diagnosed by stereotaxic core needle biopsy. Ann Surg Oncol. Sep. 1996;3(5):483-8. [pmid: 8876891].
245 Tse GM, Law BK, Ma TK, et al. Hamartoma of the breast: a clinicopathological review. J Clin Pathol. Dec. 2002;55(12):951-4. [pmid: 12461066].
246 Valdes EK, Tartter PI, Genelus-Dominique E, et al. Significance of papillary lesions at percutaneous breast biopsy. Ann Surg Oncol. Apr. 2006;13(4):480-2. [pmid: 16474908].
247 Verkooijen HM, Hoorntje LE, Peeters PH. False-negative core needle biopsies of the breast: an analysis of clinical, radiologic, and pathologic findings in 27 consecutive cases of missed breast cancer. Cancer. Mar. 1. 2004;100(5):1104-5. author reply 5–6. [pmid: 14983508].
248 Winchester DJ, Bernstein JR, Jeske JM, et al. Upstaging of atypical ductal hyperplasia after vacuum-assisted 11-gauge stereotactic core needle biopsy. Arch Surg. Jun. 2003;138(6):619-22. discussion 22-3. [pmid: 12799332].
249 Wiratkapun C, Wibulpholprasert B, Wongwaisayawan S, et al. Nondiagnostic core needle biopsy of the breast under imaging guidance: result of rebiopsy. J Med Assoc Thai. Mar. 2005;88(3):350-7. [pmid: 15962643].
250 Won B, Reynolds H, Lazaridis C, et al. Stereotactic biopsy of ductal carcinoma in situ of the breast using an 11-gauge vacuum-assisted device: persistent underestimation of disease. AJR Am J Roentgenol. 1999;173(1):227-9. [pmid: 10397131].
251 Won B, Reynolds HE, Lazaridis CL, et al. Stereotactic biopsy of ductal carcinoma in situ of the breast using an 11-gauge vacuum-assisted device: persistent underestimation of disease. AJR Am J Roentgenol. Jul. 1999;173(1):227-9. [pmid: 10397131].
252 Woolcott CG, SenGupta SK, Hanna WM, et al. Estrogen and progesterone receptor levels in nonneoplastic breast epithelium of breast cancer cases versus benign breast biopsy controls. BMC Cancer. 2008;8:130. [pmid: 18466613].
253 Worsham MJ, Raju U, Lu M, et al. Risk factors for breast cancer from benign breast disease in a diverse population. Breast Cancer Res Treat. Nov. 2009;118(1):1-7. [pmid: 18836828].
254 Xu HN, Tchou J, Li LZ. Redox imaging of human breast cancer core biopsies: a preliminary investigation. Acad Radiol. Jun. 2013;20(6):764-8. [pmid: 23664401].
255 Yeh IT, Dimitrov D, Otto P, et al. Pathologic review of atypical hyperplasia identified by image-guided breast needle core biopsy. Correlation with excision specimen. Arch Pathol Lab Med. Jan. 2003;127(1):49-54. [pmid: 12521366].
256 You JK, Kim EK, Kwak JY, et al. Focal fibrosis of the breast diagnosed by a sonographically guided core biopsy of nonpalpable lesions: imaging findings and clinical relevance. J Ultrasound Med. Oct. 2005;24(10):1377-84. [pmid: 16179621].
257 Youk JH, Gweon HM, Son EJ, et al. Three-dimensional shear-wave elastography for differentiating benign and malignant breast lesions: comparison with two-dimensional shear-wave elastography. Eur Radiol. Jun. 2013;23(6):1519-27. [pmid: 23212276].
258 Zagouri F, Sergentanis TN, Nonni A, et al. Vacuum-assisted breast biopsy: the value and limitations of cores with microcalcifications. Pathol Res Pract. 2007;203(8):563-6. [pmid: 17611039].
259 Zhao L, Freimanis R, Bergman S, et al. Biopsy needle technique and the accuracy of diagnosis of atypical ductal hyperplasia for mammographic abnormalities. Am Surg. Sep. 2003;69(9):757-62. discussion 62. [pmid: 14509322].
260 Zuiani C, Londero V, Bestagno A, et al. Proliferative high-risk lesions of the breast: contribution and limits of US-guided core biopsy. Radiol Med. Nov–Dec. 2005;110(5–6):589-602. [pmid: 16437044].
261 Adrales G, Turk P, Wallace T, et al. Is surgical excision necessary for atypical ductal hyperplasia of the breast diagnosed by Mammotome?. Am J Surg. Oct. 2000;180(4):313-5. [pmid: 11113443].
262 Brem RF, Schoonjans JM, Goodman SN, et al. Nonpalpable Breast Cancer: Percutaneous Diagnosis with 11-and 8-gauge Stereotactic Vacuum-assisted Biopsy Devices 1. Radiology. 2001;219(3):793-6. [pmid: 11376271].
263 Burns RP, Brown JP, Roe SM, et al. Stereotactic core-needle breast biopsy by surgeons: minimum 2-year follow-up of benign lesions. Ann Surg. Oct. 2000;232(4):542-8. [pmid: 10998652].
264 Caines JS, Chantziantoniou K, Wright BA, et al. Nova Scotia Breast Screening Program experience: use of needle core biopsy in the diagnosis of screening-detected abnormalities. Radiology. Jan. 1996;198(1):125-30. [pmid: 8539363].
265 Caines JS, McPhee MD, Konok GP, et al. Stereotaxic needle core biopsy of breast lesions using a regular mammographic table with an adaptable stereotaxic device. AJR Am J Roentgenol. Aug. 1994;163(2):317-21. [pmid: 8037022].
266 Cerwenka H, Hoff M, Rosanelli G, et al. Experience with a high speed biopsy gun in breast cancer diagnosis. Eur J Surg Oncol. Jun. 1997;23(3):206-7. [pmid: 9236891].
267 Chen X, Lehman CD, Dee KE. MRI-guided breast biopsy: clinical experience with 14-gauge stainless steel core biopsy needle. AJR Am J Roentgenol. Apr. 2004;182(4):1075-80. [pmid: 15039191].
268 Choo KS, Kwak HS, Tae Bae Y, et al. The value of a combination of wire localization and ultrasound-guided vacuum-assisted breast biopsy for clustered microcalcifications. Breast. Dec. 2008;17(6):611-6. [pmid: 18653339].
269 Cilotti A, Iacconi C, Marini C, et al. Contrast-enhanced MR imaging in patients with BI-RADS 3-5 microcalcifications. Radiol Med. Mar. 2007;112(2):272-86. [pmid: 17361370].
270 Costantini R, Sardellone A, Marino C, et al. Vacuum-assisted core biopsy (Mammotome) for the diagnosis of non-palpable breast lesions: four-year experience in an Italian center. Tumori. Jul–Aug. 2005;91(4):351-4. [pmid: 16277103].
271 Crowe JP Jr, Rim A, Patrick RJ, et al. Does core needle breast biopsy accurately reflect breast pathology?. Surgery. Oct. 2003;134(4):523-6. discussion 6-8. [pmid: 14605609].
272 Daniel BL, Birdwell RL, Butts K, et al. Freehand iMRI-guided large-gauge core needle biopsy: a new minimally invasive technique for diagnosis of enhancing breast lesions. J Magn Reson Imaging. Jun. 2001;13(6):896-902. [pmid: 11382950].
273 Dronkers DJ. Stereotaxic core biopsy of breast lesions. Radiology. Jun. 1992;183(3):631-4. [pmid: 1584909].
274 Evans AJ, Whitlock JP, Burrell HC, et al. A comparison of 14 and 12 gauge needles for core biopsy of suspicious mammographic calcification. Br J Radiol. Dec. 1999;72(864):1152-4. [pmid: 10703470].
275 Fures R, Bukovic D, Lez C, et al. Large-gauge needle biopsy in diagnosing malignant breast neoplasia. Coll Antropol. Jun. 2003;27(1):259-62. [pmid: 12974154].
276 Ghate SV, Rosen EL, Soo MS, et al. MRI-guided vacuum-assisted breast biopsy with a handheld portable biopsy system. AJR Am J Roentgenol. Jun. 2006;186(6):1733-6. [pmid: 16714667].
277 Giardina C, Guerrieri A, Ingravallo G, et al. Mammary stereotaxic core-biopsy by Mammotome: an alternative to frozen section examination. Pathologica. 2002;94(4):182-9. [pmid: 12325416].
278 Giardina C, Guerrieri AM, Ingravallo G, et al. The stereotaxic core breast biopsy using the Mammotome: an alternative to intraoperative examination. Pathologica. Aug. 2002;94(4):182-9. [pmid: 12325416].
279 Hirst C, Davis N. Core biopsy for microcalcifications in the breast. Aust N Z J Surg. Jun. 1997;67(6):320-4. [pmid: 9193263].
280 Hoorntje LE, Peeters PH, Borel Rinkes IH, et al. Stereotactic large core needle biopsy for all nonpalpable breast lesions?. Breast Cancer Res Treat. May. 2002;73(2):177-82. [pmid: 12088119].
281 Israel PZ, Fine RE. Stereotactic needle biopsy for occult breast lesions: a minimally invasive alternative. Am Surg. Jan. 1995;61(1):87-91. [pmid: 7832390].
282 Jackman RJ, Nowels KW, Shepard MJ, et al. Stereotaxic large-core needle biopsy of 450 nonpalpable breast lesions with surgical correlation in lesions with cancer or atypical hyperplasia. Radiology. Oct. 1994;193(1):91-5. [pmid: 8090927].
283 Joshi M, Duva-Frissora A, Padmanabhan R, et al. Atypical ductal hyperplasia in stereotactic breast biopsies: enhanced accuracy of diagnosis with the mammotome. Breast J. Jul–Aug. 2001;7(4):207-13. [pmid: 11678796].
284 Kikuchi M, Tsunoda-Shimizu H, Kawasaki T, et al. Indications for stereotactically-guided vacuum-assisted breast biopsy for patients with category 3 microcalcifications. Breast Cancer. 2007;14(3):285-91. [pmid: 17690506].
285 Kim MJ, Kim EK, Park SY, et al. Imaging-histologic discordance at sonographically guided percutaneous biopsy of breast lesions. Eur J Radiol. Jan. 2008;65(1):163-9. [pmid: 17466478].
286 Klar RM. National health insurance: the federal perspective. ASHA. Jun. 1975;17(6):388-91. [pmid: 1137627].
287 Klem D, Jacobs HK, Jorgensen R, et al. Stereotactic breast biopsy in a community hospital setting. Am Surg. Aug. 1999;65(8):737-40. discussion 40-1. [pmid: 10432083].
288 Kumaroswamy V, Liston J, Shaaban AM. Vacuum assisted stereotactic guided mammotome biopsies in the management of screen detected microcalcifications: experience of a large breast screening centre. J Clin Pathol. Jun. 2008;61(6):766-9. [pmid: 18326021].
289 Lee JM, Kaplan JB, Murray MP, et al. Complete excision of the MRI target lesion at MRI-guided vacuum-assisted biopsy of breast cancer. AJR Am J Roentgenol. Oct. 2008;191(4):1198-202. [pmid: 18806165].
290 Łuczyńska E, Kocurek A, Dyczek S, et al. Ultrasound-guided, vacuum-assisted biopsy in evaluation of breast lesions. NOWOTWORY. 2008;58.
291 Łuczyńska E, Skotnicki P, Kocurek A, et al. Vacuum mammotomy under ultrasound guidance. Polish Journal of Radiology. 2007;72(3):15-8.
292 McCombs MM, Bassett LW, Jahan R, et al. Imaging-Guided Core Biopsy of the Breast. The Breast Journal. 1995;1(1):9-16.
293 Mendez A, Cabanillas F, Echenique M, et al. Evaluation of Breast Imaging Reporting and Data System Category 3 mammograms and the use of stereotactic vacuum-assisted breast biopsy in a nonacademic community practice. Cancer. Feb. 15. 2004;100(4):710-4. [pmid: 14770425].
294 Morrow M, Schmidt R, Cregger B, et al. Preoperative evaluation of abnormal mammographic findings to avoid unnecessary breast biopsies. Arch Surg. Oct. 1994;129(10):1091-6. [pmid: 7944941].
295 Newman MR, Frost FA, Sterrett GF, et al. Diagnosis of breast microcalcifications: a comparison of stereotactic FNA and core imprint cytology as adjuncts to core biopsy. Pathology. Nov. 2001;33(4):449-53. [pmid: 11827411].
296 Nisbet AP, Borthwick-Clarke A, Scott N. 11-gauge vacuum assisted directional biopsy of breast calcifications, using upright stereotactic guidance. Eur J Radiol. Dec. 2000;36(3):144-6. [pmid: 11091014].
297 Pillsbury SG Jr, Haugen JA, Roux S. Reliability of multimodal evaluation of abnormal screening mammogram results. Am J Obstet Gynecol. Jun. 1996;174(6):1683-6. discussion 6-7. [pmid: 8678127].
298 Rich PM, Michell MJ, Humphreys S, et al. Stereotactic 14G core biopsy of non-palpable breast cancer: what is the relationship between the number of core samples taken and the sensitivity for detection of malignancy?. Clin Radiol. Jun. 1999;54(6):384-9. [pmid: 10406340].
299 Schneider E, Rohling KW, Schnall MD, et al. An apparatus for MR-guided breast lesion localization and core biopsy: Design and preliminary results. Journal of Magnetic Resonance Imaging. 2001;14(3):243-53. [pmid: 11536401].
300 Senn Bahls E, Dupont Lampert V, Oelschlegel C, et al. Multitarget stereotactic core-needle breast biopsy (MSBB)--an effective and safe diagnostic intervention for non-palpable breast lesions: a large prospective single institution study. Breast. Jun. 2006;15(3):339-46. [pmid: 16488609].
301 Seoudi H, Mortier J, Basile R, et al. Stereotactic core needle biopsy of nonpalpable breast lesions: initial experience with a promising technique. Arch Surg. Apr. 1998;133(4):366-72. [pmid: 9565115].
302 Shin JH, Han BK, Ko EY, et al. Probably benign breast masses diagnosed by sonography: is there a difference in the cancer rate according to palpability?. AJR Am J Roentgenol. Apr. 2009;192(4):W187-91. [pmid: 19304679].
303 Smyczek-Gargya B, Krainick U, Muller-Schimpfle M, et al. Large-core needle biopsy for diagnosis and treatment of breast lesions. Arch Gynecol Obstet. Aug. 2002;266(4):198-200. [pmid: 12192478].
304 Soo MS, Baker JA, Rosen EL, et al. Sonographically guided biopsy of suspicious microcalcifications of the breast: a pilot study. AJR Am J Roentgenol. Apr. 2002;178(4):1007-15. [pmid: 11906892].
305 Taft R, Chao K, Dear P, et al. The role of core biopsy in the diagnosis of mammographically detected lesions. Aust N Z J Surg. Oct. 1996;66(10):664-7. [pmid: 8855919].
306 Taourel P, Hoa D, Chaveron C, et al. Stereotactic vacuum biopsy of calcifications with a handheld portable biopsy system: a validation study. Eur Radiol. Jul. 2008;18(7):1319-25. [pmid: 18351352].
307 Teh WL, Wilson AR, Evans AJ, et al. Ultrasound guided core biopsy of suspicious mammographic calcifications using high frequency and power Doppler ultrasound. Clin Radiol. May. 2000;55(5):390-4. [pmid: 10816407].
308 Vega A, Garijo F, Ortega E. Core needle aspiration biopsy of palpable breast masses. Acta Oncol. 1995;34(1):31-4. [pmid: 7865233].
309 Velanovich V, Lewis FR Jr, Nathanson SD, et al. Comparison of mammographically guided breast biopsy techniques. Ann Surg. May. 1999;229(5):625-30. discussion 30-3. [pmid: 10235520].
310 Wallace JE, Sayler C, McDowell NG, et al. The role of stereotactic biopsy in assessment of nonpalpable breast lesions. Am J Surg. May. 1996;171(5):471-3. [pmid: 8651387].
311 Wong T-T, Cheung PS, Ma MK, et al. Experience of stereotactic breast biopsy using the vacuum-assisted core needle biopsy device and the advanced breast biopsy instrumentation system in Hong Kong women. Asian Journal of Surgery. 2005;28(1):18-23. [pmid: 15691792].
312 Woodcock NP, Glaves I, Morgan DR, et al. Ultrasound-guided Tru-cut biopsy of the breast. Ann R Coll Surg Engl. Jul. 1998;80(4):253-6. [pmid: 9771224].
313 Zardawi IM. Fine needle aspiration cytology vs. core biopsy in a rural setting. Acta Cytol. Jul–Aug. 1998;42(4):883-7. [pmid: 9684572].
314 Zografos GC, Zagouri F, Sergentanis TN, et al. Is zero underestimation feasible? Extended Vacuum-Assisted Breast Biopsy in solid lesions - a blind study. World J Surg Oncol. 2007;5:53. [pmid: 17501997].
315 Zografos GC, Zagouri F, Sergentanis TN, et al. Pain during vacuum-assisted breast biopsy: are there any predictors?. Breast. Dec. 2008;17(6):592-5. [pmid: 18657974].
316 Lifrange E, Dondelinger RF, Quatresooz P, et al. Stereotactic breast biopsy with an 8-gauge, directional, vacuum-assisted probe: initial experience. Eur Radiol. Sep. 2002;12(9):2180-7. [pmid: 12195467].
317 Abramovici G, Mainiero MB. Screening breast MR imaging: comparison of interpretation of baseline and annual follow-up studies. Radiology. Apr. 2011;259(1):85-91. [pmid: 21285337].
318 Acheson MB, Patton RG, Howisey RL, et al. Histologic correlation of image-guided core biopsy with excisional biopsy of nonpalpable breast lesions. Arch Surg. Aug. 1997;132(8):815-8. discussion 9-21. [pmid: 9267263].
319 Ahmed HG, Ali AS, Almobarak AO. Utility of fine-needle aspiration as a diagnostic technique in breast lumps. Diagn Cytopathol. Dec. 2009;37(12):881-4. [pmid: 19760761].
320 Andreu FJ, Saez A, Sentis M, et al. Breast core biopsy reporting categories--An internal validation in a series of 3054 consecutive lesions. Breast. Feb. 2007;16(1):94-101. [pmid: 16982194].
321 Aryal KR, Lengyel AJ, Purser N, et al. Nipple core biopsy for the deformed or scaling nipple. Breast. Aug. 2004;13(4):350-2. [pmid: 15325673].
322 Berner A, Davidson B, Sigstad E, et al. Fine-needle aspiration cytology vs. core biopsy in the diagnosis of breast lesions. Diagn Cytopathol. Dec. 2003;29(6):344-8. [pmid: 14648793].
323 Bick U, Engelken F, Diederichs G, et al. MRI of the breast as part of the assessment in population-based mammography screening. Rofo. Sep. 2013;185(9):849-56. [pmid: 23740312].
324 Brancato B, Scialpi M, Pusiol T, et al. Needle core biopsy should replace fine needle aspiration cytology in ultrasound-guided sampling of breast lesions. Pathologica. Apr. 2011;103(2):52. [pmid: 21797145].
325 Brunner AH, Sagmeister T, Kremer J, et al. The accuracy of frozen section analysis in ultrasound- guided core needle biopsy of breast lesions. BMC Cancer. 2009;9:341. [pmid: 19778424].
326 Burak WE Jr, Owens KE, Tighe MB, et al. Vacuum-assisted stereotactic breast biopsy: histologic underestimation of malignant lesions. Arch Surg. Jun. 2000;135(6):700-3. [pmid: 10843367].
327 Carmichael AR, Berresford A, Sami A, et al. Imprint cytology of needle core-biopsy specimens of breast lesion: is it best of both worlds?. Breast. Jun. 2004;13(3):232-4. [pmid: 15177427].
328 Cupido BD, Vawda F, Sabri A, et al. Evaluation and correlation of mammographically suspicious lesions with histopathology at Addington Hospital, Durban. S Afr Med J. Apr. 2013;103(4):251-4. [pmid: 23547702].
329 Duijm LE, Groenewoud JH, Roumen RM, et al. A decade of breast cancer screening in The Netherlands: trends in the preoperative diagnosis of breast cancer. Breast Cancer Res Treat. Nov. 2007;106(1):113-9. [pmid: 17219049].
330 Duncan JL 3rd, Cederbom GJ, Champaign JL, et al. Benign diagnosis by image-guided core-needle breast biopsy. Am Surg. Jan. 2000;66(1):5-9. discussion -10. [pmid: 10651339].
331 Fotou M, Oikonomou V, Zagouri F, et al. Imprint cytology on microcalcifications excised by vacuum-assisted breast biopsy: a rapid preliminary diagnosis. World J Surg Oncol. 2007;5:40. [pmid: 17407604].
332 Gebauer B, Bostanjoglo M, Moesta KT, et al. Magnetic resonance-guided biopsy of suspicious breast lesions with a handheld vacuum biopsy device. Acta Radiol. Nov. 2006;47(9):907-13. [pmid: 17077039].
333 Green RS, Mathew S. The contribution of cytologic imprints of stereotactically guided core needle biopsies of the breast in the management of patients with mammographic abnormalities. Breast J. Jul–Aug. 2001;7(4):214-8. [pmid: 11678797].
334 James JJ, Wilson AR, Evans AJ, et al. The use of a short-acting benzodiazepine to reduce the risk of syncopal episodes during upright stereotactic breast biopsy. Clin Radiol. Mar. 2005;60(3):394-6. [pmid: 15710145].
335 Joulaee A, Kalantari M, Kadivar M, et al. Trucut biopsy of breast lesions: the first step toward international standards in developing countries. Eur J Cancer. Mar. 2012;48(5):648-54. [pmid: 22244803].
336 Kam JK, Naidu P, Rose AK, et al. Five-year analysis of magnetic resonance imaging as a screening tool in women at hereditary risk of breast cancer. J Med Imaging Radiat Oncol. Aug. 2013;57(4):400-6. [pmid: 23870334].
337 Kang SS, Ko EY, Han BK, et al. Breast US in patients who had microcalcifications with low concern of malignancy on screening mammography. Eur J Radiol. Aug. 2008;67(2):285-91. [pmid: 17703906].
338 Kim MJ, Kim EK, Lee JY, et al. Breast lesions with imaging-histologic discordance during US-guided 14G automated core biopsy: can the directional vacuum-assisted removal replace the surgical excision? Initial findings. Eur Radiol. Sep. 2007;17(9):2376-83. [pmid: 17361422].
339 Kumaraswamy V, Carder PJ. Examination of breast needle core biopsy specimens performed for screen-detected microcalcification. J Clin Pathol. Jun. 2007;60(6):681-4. [pmid: 16882700].
340 Mak WS, Fong CY, Lui CY. Ultrasound-guided biopsy of solid breast lesions: Should fine-needle aspiration be replaced by core biopsy?. Hong Kong. 2012;15(1):10-4.
341 Mohr Z, Hirche C, Klein T, et al. Vacuum-assisted minimally invasive biopsy of soft-tissue tumors. J Bone Joint Surg Am. Jan. 18. 2012;94(2):103-9. [pmid: 22257995].
342 Olaya W, Bae W, Wong J, et al. Accuracy and upgrade rates of percutaneous breast biopsy: the surgeon’s role. Am Surg. Oct. 2010;76(10):1084-7. [pmid: 21105615].
343 Parker SH, Klaus AJ, McWey PJ, et al. Sonographically guided directional vacuum-assisted breast biopsy using a handheld device. AJR Am J Roentgenol. Aug. 2001;177(2):405-8. [pmid: 11461871].
344 Peter D, Grunhagen J, Wenke R, et al. False-negative results after stereotactically guided vacuum biopsy. Eur Radiol. Jan. 2008;18(1):177-82. [pmid: 17637996].
345 Popiela TJ, Tabor J, Chrzan R, et al. Mammotome biopsy in the diagnostic management of non-palpable breast pathologies. Pol Przegl Radiol. 2006;71(3):48-56.
346 Sakamoto N, Tozaki M, Higa K, et al. False-negative ultrasound-guided vacuum-assisted biopsy of the breast: difference with US-detected and MRI-detected lesions. Breast Cancer. Apr. 2010;17(2):110-7. [pmid: 19434473].
347 Sakamoto N, Tozaki M, Higa K, et al. Categorization of non-mass-like breast lesions detected by MRI. Breast Cancer. 2008;15(3):241-6. [pmid: 18224381].
348 Sarff M, Schmidt K, Vetto JT. Targeted breast cancer screening in women younger than 40: results from a statewide program. Am J Surg. May. 2008;195(5):626-30. discussion 30. [pmid: 18374894].
349 Schoonjans JM, Brem RF. Fourteen-gauge ultrasonographically guided large-core needle biopsy of breast masses. J Ultrasound Med. Sep. 2001;20(9):967-72. [pmid: 11549157].
350 Schur EA, Elmore JE, Onega T, et al. The impact of obesity on follow-up after an abnormal screening mammogram. Cancer Epidemiol Biomarkers Prev. Feb. 2012;21(2):327-36. [pmid: 22144503].
351 Sigal-Zafrani B, Muller K, El Khoury C, et al. Vacuum-assisted large-core needle biopsy (VLNB) improves the management of patients with breast microcalcifications - analysis of 1009 cases. Eur J Surg Oncol. Apr. 2008;34(4):377-81. [pmid: 17604937].
352 Simon JR, Kalbhen CL, Cooper RA, et al. Accuracy and complication rates of US-guided vacuum-assisted core breast biopsy: initial results. Radiology. Jun. 2000;215(3):694-7. [pmid: 10831686].
353 Smith GE, Burrows P. Ultrasound diagnosis of fibroadenoma - is biopsy always necessary?. Clin Radiol. May. 2008;63(5):511-5. discussion 6-7. [pmid: 18374713].
354 Sohn YM, Kim MJ, Kim EK, et al. Sonographic elastography combined with conventional sonography: how much is it helpful for diagnostic performance?. J Ultrasound Med. Apr. 2009;28(4):413-20. [pmid: 19321669].
355 Sonmez G, Cuce F, Mutlu H, et al. Value of diffusion-weighted MRI in the differentiation of benign and malign breast lesions. Wien Klin Wochenschr. Nov. 2011;123(21–22):655-61. [pmid: 21922210].
356 Stijven S, Gielen E, Bevernage C, et al. Magnetic resonance imaging: value of diffusion-weighted imaging in differentiating benign from malignant breast lesions. Eur J Obstet Gynecol Reprod Biol. Feb. 2013;166(2):215-20. [pmid: 23219320].
357 Sung JS, Lee CH, Morris EA, et al. Screening breast MR imaging in women with a history of chest irradiation. Radiology. Apr. 2011;259(1):65-71. [pmid: 21325032].
358 Tabrizian P, Moezzi M, Menes TS. Synchronous benign-appearing calcifications in patients with ductal carcinoma in situ may not be benign. Breast Cancer. Oct. 2011;18(4):314-8. [pmid: 20602184].
359 Tadwalkar RV, Rapelyea JA, Torrente J, et al. Breast-specific gamma imaging as an adjunct modality for the diagnosis of invasive breast cancer with correlation to tumour size and grade. Br J Radiol. Jun. 2012;85(1014):e212-6. [pmid: 21712429].
360 Tozaki M. BI-RADS-MRI terminology and evaluation of intraductal carcinoma and ductal carcinoma in situ. Breast Cancer. Jan. 2013;20(1):13-20. [pmid: 22109641].
361 Weigert JM, Bertrand ML, Lanzkowsky L, et al. Results of a multicenter patient registry to determine the clinical impact of breast-specific gamma imaging, a molecular breast imaging technique. AJR Am J Roentgenol. Jan. 2012;198(1):W69-75. [pmid: 22194518].
362 Weinstein SP, Hanna LG, Gatsonis C, et al. Frequency of malignancy seen in probably benign lesions at contrast-enhanced breast MR imaging: findings from ACRIN 6667. Radiology. Jun. 2010;255(3):731-7. [pmid: 20501712].
363 Whitlock JP, Evans AJ, Burrell HC, et al. Digital imaging improves upright stereotactic core biopsy of mammographic microcalcifications. Clin Radiol. May. 2000;55(5):374-7. [pmid: 10816404].
364 Whitworth PW. Intact Percutaneous Excision (IPEX) for Definitive Diagnosis of High-Risk Breast Lesions. Ann Surg Oncol. Oct. 2011;18(11):3095. [pmid: 21904961].
365 Wu YC, Chen DR, Kuo SJ. Personal experience of ultrasound-guided 14-gauge core biopsy of breast tumor. Eur J Surg Oncol. Sep. 2006;32(7):715-8. [pmid: 16769196].
366 Xu H, Rao M, Varghese T, et al. Axial-shear strain imaging for differentiating benign and malignant breast masses. Ultrasound Med Biol. Nov. 2010;36(11):1813-24. [pmid: 20800948].
367 Xu X, Gifford-Hollingsworth C, Sensenig R, et al. Breast tumor detection using piezoelectric fingers: first clinical report. J Am Coll Surg. Jun. 2013;216(6):1168-73. [pmid: 23623223].
368 Yi A, Cho N, Chang JM, et al. Sonoelastography for 1,786 non-palpable breast masses: diagnostic value in the decision to biopsy. Eur Radiol. May. 2012;22(5):1033-40. [pmid: 22116557].
369 Yoon JH, Jung HK, Lee JT, et al. Shear-wave elastography in the diagnosis of solid breast masses: what leads to false-negative or false-positive results?. Eur Radiol. Sep. 2013;23(9):2432-40. [pmid: 23673572].
370 Yoon JH, Kim EK, Kwak JY, et al. Is US-guided core needle biopsy (CNB) enough in probably benign nodules with interval growth?. Ultraschall Med. Dec. 2012;33(7):E145-50. [pmid: 23023453].
371 Yoon JH, Kim MJ, Moon HJ, et al. Subcategorization of ultrasonographic BI-RADS category 4: positive predictive value and clinical factors affecting it. Ultrasound Med Biol. May. 2011;37(5):693-9. [pmid: 21458145].
372 Youk JH, Kim EK, Kim MJ, et al. Performance of hand-held whole-breast ultrasound based on BI-RADS in women with mammographically negative dense breast. Eur Radiol. Apr. 2011;21(4):667-75. [pmid: 20853108].
373 A mammographic screening pilot project in Victoria 1988–1990. The Essendon Breast X-ray Program Collaborative Group. Med J Aust. Nov. 16. 1992;157(10):670-3. [pmid: 1435408].
374 Hereditary breast and ovarian cancer syndrome. Gynecol Oncol. Apr. 2009;113(1):6-11. [pmid: 19309638].
375 National Guideline Clearinghouse (NGC). Guideline summary: American Society of Clinical Oncology/College of American Pathologists guideline recommendations for immunohistochemical testing of estrogen and progesterone receptors in breast cancer. National Guideline Clearinghouse (NGC) [Web site]. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). [cited 2013 June 25]. Available: http://www.guideline.gov.
376 National Guideline Clearinghouse (NGC). Guideline summary: Use of tumor markers in clinical practice: quality requirements. National Guideline Clearinghouse (NGC) [Web site]. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). [cited 2013 June 25]. Available: http://www.guideline.gov.
377 Abbas S, Miller G, Doyle T. Specimen Radiography Following Hook Wire Localization and Excision of Screen Detected Breast Abnormality. International Journal of Cancer Research. 2007;3(1):39-42.
378 Abe H, Schmidt RA, Kulkarni K, et al. Axillary lymph nodes suspicious for breast cancer metastasis: sampling with US-guided 14-gauge core-needle biopsy--clinical experience in 100 patients. Radiology. Jan. 2009;250(1):41-9. [pmid: 18955508].
379 Abrahamson PE, Dunlap LA, Amamoo MA, et al. Factors predicting successful needle-localized breast biopsy. Acad Radiol. Jun. 2003;10(6):601-6. [pmid: 12809412].
380 Abrahamsson A, Morad V, Saarinen NM, et al. Estradiol, tamoxifen, and flaxseed alter IL-1beta and IL-1Ra levels in normal human breast tissue in vivo. J Clin Endocrinol Metab. Nov. 2012;97(11):E2044-54. [pmid: 22930784].
381 Acosta JA, Greenlee JA, Gubler KD, et al. Surgical margins after needle-localization breast biopsy. Am J Surg. Dec. 1995;170(6):643-5. discussion 5-6. [pmid: 7492018].
382 Agodirin SO, Ojemakinde OM, Bello TO, et al. Ultrasound-guided wire localization of lesions detected on screening mammography in Osogbo, Nigeria and its impact on breast conservative surgery. Ann Afr Med. Apr–Jun. 2012;11(2):91-5. [pmid: 22406668].
383 Aitken RJ, MacDonald HL, Kirkpatrick AE, et al. Outcome of surgery for non-palpable mammographic abnormalities. Br J Surg. Jun. 1990;77(6):673-6. [pmid: 2383738].
384 Al Ayyan M, Bu Ali O, Al Sharri S, et al. Negative axillary ultrasonography with biopsy may predict non-involvement of the non-sentinel lymph nodes in operable breast cancer patients. Asia Pac J Clin Oncol. 2012. Nov. 21. [pmid: 23167952].
385 Albert MP, Sachsse E, Coe NP, et al. Correlation between mammography and the pathology of nonpalpable breast lesions. J Surg Oncol. May. 1990;44(1):44-6. [pmid: 2342374].
386 Alexander HR, Candela FC, Dershaw DD, et al. Needle-localized mammographic lesions. Results and evolving treatment strategy. Arch Surg. Nov. 1990;125(11):1441-4. [pmid: 2241554].
387 Alhabshi SMI, Rahmat K, Abdul Halim N, et al. Semi-quantitative and qualitative assessment of breast ultrasound elastography in differentiating between malignant and benign lesions. Ultrasound Med Biol. 2013;39(4):568-78. [pmid: 23384468].
388 Al-Harethee W, Theodoropoulos G, Filippakis GM, et al. Complications of percutaneous stereotactic vacuum assisted breast biopsy system utilizing radio frequency. Eur J Radiol. Apr. 2013;82(4):623-6. [pmid: 22227260].
389 Alicioglu B, Yucesoy C. A simple method to decrease surgical trauma in wire localization procedures. Diagn Interv Radiol. Sep. 2008;14(3):131-2. [pmid: 18814133].
390 Al-Khawari H, Athyal R, Kovacs A, et al. Accuracy of the Fischer scoring system and the Breast Imaging Reporting and Data System in identification of malignant breast lesions. Ann Saudi Med. Jul–Aug. 2009;29(4):280-7. [pmid: 19584584].
391 Allen SD, Nerurkar A, Della Rovere GU. The breast lesion excision system (BLES): a novel technique in the diagnostic and therapeutic management of small indeterminate breast lesions?. Eur Radiol. May. 2011;21(5):919-24. [pmid: 21240608].
392 Al-Thobhani AK, Raja’a YA, Noman TA, et al. Profile of breast lesions among women with positive biopsy findings in Yemen. East Mediterr Health J. Sep. 2006;12(5):599-604. [pmid: 17333799].
393 Amitkumar K, Srigayathri S, Praburaj AR, et al. Immunohistochemical analysis and correlation of p53, Ki-67 and PCNA in core needle Biopsy specimens of carcinoma breast. Res J Pharm, Biol Chem Sci. 2012;3(4):1446-58.
394 Aoyama K, Kamio T, Hirano A, et al. Granular cell tumors: a report of six cases. World J Surg Oncol. 2012;10:204. [pmid: 23021251].
395 Arambula Cosio F, Lira Berra E, Hevia Montiel N, et al. Computer assisted biopsy of breast tumors. Conf Proc IEEE Eng Med Biol Soc. 2010;2010:5995-8. [pmid: 21097108].
396 Armstrong K, Handorf EA, Chen J, et al. Breast cancer risk prediction and mammography biopsy decisions: a model-based study. Am J Prev Med. Jan. 2013;44(1):15-22. [pmid: 23253645].
397 Arora R, El Hameed AA, Al Ajrawi T, et al. The accuracy of abnormal cytology report in breast fine needle aspiration alone and in combination with clinical and imaging findings - a hospital based five year study in Kuwait. Gulf J Oncolog. Jul. 2008;(4):33-8. [pmid: 20084773].
398 Asadi M, Shobeiri H, Aliakbarian M, et al. Reproducibility of lymphoscintigraphy before and after excisional biopsy of primary breast lesions: a study using superficial peri-areolar injection of the radiotracer. Rev Esp Med Nucl Imagen Mol. May–Jun. 2013;32(3):152-5. [pmid: 23044070].
399 Ashraf M, Biswas J, Gupta S, et al. Determinants of wound infections for breast procedures: assessment of the risk of wound infection posed by an invasive procedure for subsequent operation. Int J Surg. Dec. 2009;7(6):543-6. [pmid: 19748602].
400 Asoglu O, Ozmen V, Karanlik H, et al. The role of sentinel lymph node biopsy with blue dye alone in breast cancer patients with excisional biopsy. Acta Chir Belg. May–Jun. 2005;105(3):291-6. [pmid: 16018523].
401 Ball CG, Butchart M, MacFarlane JK. Effect on biopsy technique of the breast imaging reporting and data system (BI-RADS) for nonpalpable mammographic abnormalities. Can J Surg. Aug. 2002;45(4):259-63. [pmid: 12174979].
402 Barbalaco Neto G, Rossetti C, Fonseca FL, et al. Ductal carcinoma in situ in core needle biopsies and its association with extensive in situ component in the surgical specimen. Int Arch Med. 2012;5(1):19. [pmid: 22715888].
403 Bassiouny RH, Youssef T, Hassan O. Diagnostic performance of breast MRI with and without the addition of quantitative diffusion weighted imaging. Egypt J Radiol Nucl Med. 2012;43(2):311-23.
404 Bauer TL, Pandelidis SM, Rhoads JE Jr, et al. Mammographically detected carcinoma of the breast. Surg Gynecol Obstet. Dec. 1991;173(6):482-6. [pmid: 1948608].
405 Baute PB, Thibodeau ME, Newstead G. Improving the yield of biopsy for nonpalpable lesions of the breast. Surg Gynecol Obstet. Feb. 1992;174(2):93-6. [pmid: 1734582].
406 Baykara M, Özkan Z, Gül Y, et al. Effectiveness of the Triple Test and Its Alternatives for Breast Mass Evaluation.
407 Bellantone R, Rossi S, Lombardi CP, et al. Excisional breast biopsy: when, why and how?. Int Surg. Jan–Mar. 1995;80(1):75-8. [pmid: 7657498].
408 Bender JS, Magnuson TH, Smith-Meek MA, et al. Will stereotactic breast biopsy achieve results as good as current techniques?. Am Surg. Aug. 1996;62(8):637-9. discussion 9-40. [pmid: 8712560].
409 Benedict S, Williams RD, Baron PL. Recalled anxiety: from discovery to diagnosis of a benign breast mass. Oncol Nurs Forum. Nov–Dec. 1994;21(10):1723-7. [pmid: 7854934].
410 Benedict S, Williams RD, Baron PL. The effect of benign breast biopsy on subsequent breast cancer detection practices. Oncol Nurs Forum. Oct. 1994;21(9):1467-75. [pmid: 7816674].
411 Benson SR, Harrison NJ, Lengyel J, et al. Combined image guidance excision of non-palpable breast lesions. Breast. Apr. 2004;13(2):110-4. [pmid: 15019690].
412 Berkey CS, Willett WC, Frazier AL, et al. Prospective study of adolescent alcohol consumption and risk of benign breast disease in young women. Pediatrics. May. 2010;125(5):e1081-7. [pmid: 20385629].
413 Berkey CS, Willett WC, Tamimi RM, et al. Dairy intakes in older girls and risk of benign breast disease in young women. Cancer Epidemiol Biomarkers Prev. Apr. 2013;22(4):670-4. [pmid: 23542805].
414 Bianchini G, Qi Y, Alvarez RH, et al. Molecular anatomy of breast cancer stroma and its prognostic value in estrogen receptor-positive and -negative cancers. J Clin Oncol. Oct. 1. 2010;28(28):4316-23. [pmid: 20805453].
415 Bird D, Hart S. Early experience with needle localization and biopsy of mammographic lesions. Aust N Z J Surg. May. 1990;60(5):337-40. [pmid: 2334355].
416 Bluvol N, Kornecki A, Shaikh A, et al. Freehand versus guided breast biopsy: comparison of accuracy, needle motion, and biopsy time in a tissue model. AJR Am J Roentgenol. Jun. 2009;192(6):1720-5. [pmid: 19457840].
417 Bluvol N, Sheikh A, Kornecki A, et al. A needle guidance system for biopsy and therapy using two-dimensional ultrasound. Med Phys. Feb. 2008;35(2):617-28. [pmid: 18383683].
418 Bohndiek SE, Royle GJ, Speller RD. An active pixel sensor x-ray diffraction (APXRD) system for breast cancer diagnosis. Phys Med Biol. Jun. 7. 2009;54(11):3513-27. [pmid: 19443951].
419 Bojia F, Demisse M, Dejane A, et al. Comparison of fine-needle aspiration cytology and excisional biopsy of breast lesions. East Afr Med J. May. 2001;78(5):226-8. [pmid: 12002079].
420 Bosch AM, Beets GL, Kessels AG, et al. A needle-localised open-breast biopsy for nonpalpable breast lesions should not be performed for diagnosis. Breast. Dec. 2004;13(6):476-82. [pmid: 15563854].
421 Bouton ME, Wilhelmson KL, Komenaka IK. Intraoperative ultrasound can facilitate the wire guided breast procedure for mammographic abnormalities. Am Surg. May. 2011;77(5):640-6. [pmid: 21679601].
422 Bowa K, Jewel J, Mudenda V. Fine needle aspiration cytology in the investigation of breast lumps at the University Teaching Hospital in Lusaka, Zambia. Trop Doct. Oct. 2008;38(4):245-7. [pmid: 18820201].
423 Brenner RJ. Lesions entirely removed during stereotactic biopsy: preoperative localization on the basis of mammographic landmarks and feasibility of freehand technique--initial experience. Radiology. Feb. 2000;214(2):585-90. [pmid: 10671616].
424 Brenner RJ, Pfaff JM. Mammographic changes after excisional breast biopsy for benign disease. AJR Am J Roentgenol. Oct. 1996;167(4):1047-52. [pmid: 8819410].
425 Brett J, Austoker J. Women who are recalled for further investigation for breast screening: psychological consequences 3 years after recall and factors affecting re-attendance. J Public Health Med. Dec. 2001;23(4):292-300. [pmid: 11873891].
426 Brett J, Austoker J, Ong G. Do women who undergo further investigation for breast screening suffer adverse psychological consequences? A multi-centre follow-up study comparing different breast screening result groups five months after their last breast screening appointment. J Public Health Med. Dec. 1998;20(4):396-403. [pmid: 9923945].
427 Budczies J, Weichert W, Noske A, et al. Genome-wide gene expression profiling of formalin-fixed paraffin-embedded breast cancer core biopsies using microarrays. J Histochem Cytochem. Feb. 2011;59(2):146-57. [pmid: 21339180].
428 Burnside ES, Chhatwal J, Alagoz O. What is the optimal threshold at which to recommend breast biopsy?. PLoS One. 2012;7(11):e48820. [pmid: 23144986].
429 Burrell H, Murphy C, Wilson A, et al. Wire localization biopsies of non-palpable breast lesions: the use of the Nottingham localization device. The Breast. 1997;6(2):79-83.
430 Burrell HC, Pinder SE, Wilson AR, et al. The positive predictive value of mammographic signs: a review of 425 non-palpable breast lesions. Clin Radiol. Apr. 1996;51(4):277-81. [pmid: 8617041].
431 Carswell H. Minimally invasive FNAB versus surgical biopsy. Diagn Imaging (San Franc). Jun. 1991;13(6):97-104. [pmid: 10149914].
432 Castells X, Roman M, Romero A, et al. Breast cancer detection risk in screening mammography after a false-positive result. Cancer Epidemiol. Feb. 2013;37(1):85-90. [pmid: 23142338].
433 Caya JG. Breast Frozen Section Outcome in the Community Hospital Setting A Detailed Analysis of 932 Cases. International Journal of Surgical Pathology. 1995;2(3):215-9.
434 Chadwick DR, Shorthouse AJ. Wire-directed localization biopsy of the breast: an audit of results and analysis of factors influencing therapeutic value in the treatment of breast cancer. Eur J Surg Oncol. Apr. 1997;23(2):128-33. [pmid: 9158186].
435 Chang CB, Lvoff NM, Leung JW, et al. Solitary dilated duct identified at mammography: outcomes analysis. AJR Am J Roentgenol. Feb. 2010;194(2):378-82. [pmid: 20093599].
436 Chen L, Abbey CK, Nosratieh A, et al. Anatomical complexity in breast parenchyma and its implications for optimal breast imaging strategies. Med Phys. Mar. 2012;39(3):1435-41. [pmid: 22380376].
437 Chimenti F, Vomero S. Synthesis of N-substituted isoindolines. Farmaco Sci. Nov. 1975;30(11):884-90. [pmid: 251].
438 Chinyama CN, Davies JD, Rayter Z, et al. Factors affecting surgical margin clearance in screen-detected breast cancer and the effect of cavity biopsies on residual disease. Eur J Surg Oncol. Apr. 1997;23(2):123-7. [pmid: 9158185].
439 Chlebowski RT, Anderson G, Manson JE, et al. Estrogen alone in postmenopausal women and breast cancer detection by means of mammography and breast biopsy. J Clin Oncol. Jun. 1. 2010;28(16):2690-7. [pmid: 20439627].
440 Ciatto S, Bonardi R, Ravaioli A, et al. Benign breast surgical biopsies: are they always justified?. Tumori. Sep–Oct. 1998;84(5):521-4. [pmid: 9862509].
441 Cleverley JR, Jackson AR, Bateman AC. Pre-operative localization of breast microcalcification using high-frequency ultrasound. Clin Radiol. Dec. 1997;52(12):924-6. [pmid: 9413966].
442 Coady MS, Benson EA, Hartley MN. Provision and acceptability of day case breast biopsy: an audit of current practice. Ann R Coll Surg Engl. Jul. 1993;75(4):281-4. discussion 5. [pmid: 8379634].
443 Colbert ST, O’Hanlon DM, McDonnell C, et al. Analgesia in day case breast biopsy--the value of pre-emptive tenoxicam. Can J Anaesth. Mar. 1998;45(3):217-22. [pmid: 9579258].
444 Collins JC, Liao S, Wile AG. Surgical management of breast masses in pregnant women. J Reprod Med. Nov. 1995;40(11):785-8. [pmid: 8592313].
445 Cooper RA. Dual technique for preoperative localization of nonpalpable breast lesions. Can Assoc Radiol J. Dec. 1991;42(6):439-40. [pmid: 1751909].
446 Coskun G, Dogan L, Karaman N, et al. Value of sentinel lymph node biopsy in breast cancer patients with previous excisional biopsy. J Breast Cancer. Mar. 2012;15(1):87-90. [pmid: 22493633].
447 Cox CE, Reintgen DS, Nicosia SV, et al. Analysis of residual cancer after diagnostic breast biopsy: an argument for fine-needle aspiration cytology. Ann Surg Oncol. May. 1995;2(3):201-6. [pmid: 7641015].
448 Cox G, Didlake R, Powers C, et al. Choice of anesthetic technique for needle localized breast biopsy. Am Surg. Jul. 1991;57(7):414-8. [pmid: 1647712].
449 Crawford MD, Biankin AV, Rickard MT, et al. The operative management of screen-detected breast cancers. Aust N Z J Surg. Mar. 2000;70(3):168-73. [pmid: 10765897].
450 D’Alfonso TM, Liu YF, Chen Z, et al. SP3, a reliable alternative to HercepTest in determining HER-2/neu status in breast cancer patients. J Clin Pathol. May. 2013;66(5):409-14. [pmid: 23386665].
451 Davies AH, Cowan A, Jones P, et al. Ultrasound localization of screen detected impalpable breast tumours. J R Coll Surg Edinb. Dec. 1994;39(6):353-4. [pmid: 7869290].
452 Davies RJ, A’Hern RP, Parsons CA, et al. Mammographic accuracy and patient age: a study of 297 patients undergoing breast biopsy. Clin Radiol. Jan. 1993;47(1):23-5. [pmid: 8280193].
453 Day JC, Stone N. A subcutaneous Raman needle probe. Appl Spectrosc. Mar. 2013;67(3):349-54. [pmid: 23452501].
454 Dayal S, Murray J, Wilson K, et al. Imprint cytology from core biopsies increases the sensitivity of fine needle aspiration (FNA) in breast cancer patients. Magy Seb. Apr. 2011;64(2):59-62. [pmid: 21504853].
455 De Koning HJ, Fracheboud J, Boer R, et al. Nation-wide breast cancer screening in The Netherlands: support for breast-cancer mortality reduction. National Evaluation Team for Breast Cancer Screening (NETB). Int J Cancer. Mar. 16. 1995;60(6):777-80. [pmid: 7896444].
456 Deane KA, Degner LF. Information needs, uncertainty, and anxiety in women who had a breast biopsy with benign outcome. Cancer Nurs. Apr. 1998;21(2):117-26. [pmid: 9556938].
457 Degnim AC, Miller J, Hoskin TL, et al. A prospective study of breast lymphedema: frequency, symptoms, and quality of life. Breast Cancer Res Treat. Aug. 2012;134(3):915-22. [pmid: 22415476].
458 della Rovere GQ, Benson JR, Morgan M, et al. Localization of impalpable breast lesions--a surgical approach. Eur J Surg Oncol. Oct. 1996;22(5):478-82. [pmid: 8903489].
459 Di Giorgio A, Alessi G, Arnone P, et al. Ultrasonographically guided excisional biopsy of non-palpable breast lesions. Br J Surg. Jan. 1996;83(1):103. [pmid: 8653327].
460 Diepstraten SC, Verkooijen HM, van Diest PJ, et al. Radiofrequency-assisted intact specimen biopsy of breast tumors: critical evaluation according to the IDEAL recommendations. Cancer Imaging. 2011;11:247-52. [pmid: 22201702].
461 Domanski AM, Monsef N, Domanski HA, et al. Comparison of the oestrogen and progesterone receptor status in primary breast carcinomas as evaluated by immunohistochemistry and immunocytochemistry: a consecutive series of 267 patients. Cytopathology. Feb. 2013;24(1):21-5. [pmid: 22783929].
462 Dominguez WG, Nardi H, Montero H, et al. HER2/neu protein expression and fine needle breast aspiration from Argentinean patients with non-palpable breast lesions. Exp Ther Med. Jul. 2010;1(4):597-602. [pmid: 22993582].
463 Dowlatshahi K, Jokich PM, Kluskens LF, et al. A prospective study of double diagnosis of nonpalpable lesions of the breast. Surg Gynecol Obstet. Feb. 1991;172(2):121-4. [pmid: 1846452].
464 Drosos Y, Kouloukoussa M, Ostvold AC, et al. NUCKS overexpression in breast cancer. Cancer Cell Int. 2009;9:19. [pmid: 19664271].
465 Du J, Wang L, Wan CF, et al. Differentiating benign from malignant solid breast lesions: combined utility of conventional ultrasound and contrast-enhanced ultrasound in comparison with magnetic resonance imaging. Eur J Radiol. Dec. 2012;81(12):3890-9. [pmid: 23062280].
466 Dyess DL, Lorino CO, Grieco A, et al. Selective nonoperative management of solid breast masses. Am Surg. Jul. 1992;58(7):435-40. [pmid: 1616189].
467 Ebeed SA, Abd El-Moneim NA, Saad A, et al. Diagnostic and prognostic value of circulating tumor cells in female breast cancer patients. Alex J Med. 2012;48(3):197-206.
468 Egyed Z, Pentek Z, Jaray B, et al. Radial scar-significant diagnostic challenge. Pathol Oncol Res. Jun. 2008;14(2):123-9. [pmid: 18409019].
469 Erguvan-Dogan B, Whitman GJ, Nguyen VA, et al. Specimen radiography in confirmation of MRI-guided needle localization and surgical excision of breast lesions. AJR Am J Roentgenol. Aug. 2006;187(2):339-44. [pmid: 16861535].
470 Estourgie SH, Valdes Olmos RA, Nieweg OE, et al. Excision biopsy of breast lesions changes the pattern of lymphatic drainage. Br J Surg. Sep. 2007;94(9):1088-91. [pmid: 17514636].
471 Ezer SS, Oguzkurt P, Ince E, et al. Surgical treatment of the solid breast masses in female adolescents. J Pediatr Adolesc Gynecol. Feb. 2013;26(1):31-5. [pmid: 23158756].
472 Fedoruk LM, Bojm MA, Bugis SP. Fine-wire localization for nonpalpable mammographic abnormalities. Can J Surg. Apr. 1995;38(2):173-7. [pmid: 7728673].
473 Feng XZ, Song YH, Zhang FX, et al. Diagnostic accuracy of fiberoptic ductoscopy plus in vivo iodine staining for intraductal proliferative lesions. Chin Med J (Engl). Aug. 2013;126(16):3124-9. [pmid: 23981624].
474 Feoli F, Ameye L, Van Eeckhout P, et al. Liquid-based cytology of the breast: pitfalls unrecognized before specific liquid-based cytology training - proposal for a modification of the diagnostic criteria. Acta Cytol. 2013;57(4):369-76. [pmid: 23860126].
475 Ferno M, Baldetorp B, Fallenius G, et al. Preoperative fine needle aspiration from human breast cancer is a valuable sampling material for progesterone receptor and cytometric DNA analysis. Acta Oncol. 1996;35(Suppl 8):19-25. [pmid: 9073045].
476 Ferreiro JA, Gisvold JJ, Bostwick DG. Accuracy of frozen-section diagnosis of mammographically directed breast biopsies. Results of 1,490 consecutive cases. Am J Surg Pathol. Nov. 1995;19(11):1267-71. [pmid: 7573688].
477 Flanagan JJ, Conry BG, Rubin G, et al. Short communication: Prospective assessment of a new graduated hookwire for the localization of impalpable breast lesions. Br J Radiol. Apr. 1996;69(820):341-3. [pmid: 8665134].
478 de Fleury EF, Fleury JC, Piato S, et al. New elastographic classification of breast lesions during and after compression. Diagn Interv Radiol. Jun. 2009;15(2):96-103. [pmid: 19517379].
479 Florentine BD, Kirsch D, Carroll-Johnson RM, et al. Conservative excision of wire-bracketed breast carcinomas: a community hospital’s experience. Breast J. Sep–Oct. 2004;10(5):398-404. [pmid: 15327492].
480 Franceschi D, Crowe J, Zollinger R, et al. Biopsy of the breast for mammographically detected lesions. Surg Gynecol Obstet. Dec. 1990;171(6):449-55. [pmid: 2244276].
481 Frank JL, Lynch K, Barrows G. Nipple smear cytology is of no value in the management of women with nipple discharge. Conn Med. Apr. 2010;74(4):207-10. [pmid: 20441001].
482 Frattini V, Ghisoni L, Teodoro A, et al. Clinical approach with optical imaging instrument. perspective analysis on 617 young females: Studio clinico mediante dinamica ottica mammaria per immagini. analisi prospettica in 617 donne con eta inferiore a 40 anni. Ital J Gynaecol Obstet. 2011;23(2–3):101-6.
483 Fukutomi T, Yamamoto H, Nanasawa T, et al. Prognostic factors for local recurrence in breast conservation therapy: residual cancers after lumpectomy. Surg Today. 1993;23(5):402-6. [pmid: 8324333].
484 Garcia-Ortega MJ, Benito MA, Vahamonde EF, et al. Pretreatment axillary ultrasonography and core biopsy in patients with suspected breast cancer: diagnostic accuracy and impact on management. Eur J Radiol. Jul. 2011;79(1):64-72. [pmid: 20047809].
485 Garcia-Vilanova-Comas A, Fuster-Diana C, Cubells-Parrilla M, et al. Nicolau syndrome after lidocaine injection and cold application: a rare complication of breast core needle biopsy. Int J Dermatol. Jan. 2011;50(1):78-80. [pmid: 21182507].
486 Geelhoed GW, Barr HM, Curtis DJ, et al. Radiologic recommendation for breast biopsy on screening mammography reports. Am Surg. Jul. 1991;57(7):419-24. [pmid: 2058848].
487 Giacalone PL, Bourdon A, Trinh PD, et al. Radioguided occult lesion localization plus sentinel node biopsy (SNOLL) versus wire-guided localization plus sentinel node detection: a case control study of 129 unifocal pure invasive non-palpable breast cancers. Eur J Surg Oncol. Mar. 2012;38(3):222-9. [pmid: 22231127].
488 Giagounidis EM, Markus R, Josef L, et al. CT-guided preoperative needle localization of MRI-detected breast lesions. Eur J Radiol. Aug. 2001;39(2):100-3. [pmid: 11522418].
489 Goedde TA, Frykberg ER, Crump JM, et al. The impact of mammography on breast biopsy. Am Surg. Nov. 1992;58(11):661-6. [pmid: 1485695].
490 Goff JM, Molloy M, Debbas MT, et al. Long-term impact of previous breast biopsy on breast cancer screening modalities. J Surg Oncol. May. 1995;59(1):18-20. [pmid: 7745971].
491 Goldberg JA, Scott RN, Davidson PM, et al. Psychological morbidity in the first year after breast surgery. Eur J Surg Oncol. Aug. 1992;18(4):327-31. [pmid: 1521623].
492 Gossmann A, Bangard C, Warm M, et al. Real-time MR-guided wire localization of breast lesions by using an open 1.0-T imager: initial experience. Radiology. May. 2008;247(2):535-42. [pmid: 18349317].
493 Gouin F, Tournigand T, Moisan D, et al. Preparation of the patient for reoperation. Ann Anesthesiol Fr. Jul. 1975;16(4):237-40. [pmid: 2040].
494 Grannan KJ, Lamping K. Impact of method of anesthesia on the accuracy of needle-localized breast biopsies. Am J Surg. Feb. 1993;165(2):218-20. [pmid: 8427399].
495 Gray RJ, Salud C, Nguyen K, et al. Randomized prospective evaluation of a novel technique for biopsy or lumpectomy of nonpalpable breast lesions: radioactive seed versus wire localization. Ann Surg Oncol. Oct. 2001;8(9):711-5. [pmid: 11597011].
496 Green B, Dowley A, Turnbull LS, et al. Impact of fine-needle aspiration cytology, ultrasonography and mammography on open biopsy rate in patients with benign breast disease. Br J Surg. Nov. 1995;82(11):1509-11. [pmid: 8535805].
497 Griffen MM, Welling RE. Needle-localized biopsy of the breast. Surg Gynecol Obstet. Feb. 1990;170(2):145-8. [pmid: 2154039].
498 Guarneri V, Barbieri E, Piacentini F, et al. Predictive and prognostic role of p53 according to tumor phenotype in breast cancer patients treated with preoperative chemotherapy: a single-institution analysis. Int J Biol Markers. Apr–Jun. 2010;25(2):104-11. [pmid: 20544688].
499 Gupta A, Subhas G, Dubay L, et al. Review of re-excision for narrow or positive margins of invasive and intraductal carcinoma. Am Surg. Jul. 2010;76(7):731-4. [pmid: 20698380].
500 Gwin JL Jr, King B, Hudson KB, et al. Interval mammography after needle localization biopsy of breast abnormalities that are pathologically benign. Am J Surg. Oct. 1995;170(4):323-6. [pmid: 7573722].
501 Hall JA, Murphy DC, Hall BR, et al. Open surgical biopsy for nonpalpable mammographic abnormalities: still an option compared with core needle biopsy. Am J Obstet Gynecol. Jun. 1998;178(6):1245-50. [pmid: 9662308].
502 Halladay JR, Yankaskas BC, Bowling JM, et al. Positive predictive value of mammography: comparison of interpretations of screening and diagnostic images by the same radiologist and by different radiologists. AJR Am J Roentgenol. Sep. 2010;195(3):782-5. [pmid: 20729460].
503 Hamby LS, McGrath PC, Stelling CB, et al. Management of mammographic indeterminate lesions. First place winner of the Conrad Jobst Award in the Gold Medal paper competition. Am Surg. Jan. 1993;59(1):4-8. [pmid: 8386912].
504 Hashemzadeh SH, Kumar PV, Malekpour N, et al. Diagnostic accuracy of fine needle aspiration cytology: Comparison of results in Tabriz Imam Khomeini Hospital and Shiraz University of Medical Sciences. Iran J Cancer Prev. 2009;2(3):133-6.
505 Hasselgren PO, Hummel RP, Georgian-Smith D, et al. Breast biopsy with needle localization: accuracy of specimen x-ray and management of missed lesions. Surgery. Oct. 1993;114(4):836-40. discussion 40-2. [pmid: 8211702].
506 Haupt LM, Irving RE, Weinstein SR, et al. Matrix metalloproteinase localisation by in situ-RT-PCR in archival human breast biopsy material. Mol Cell Probes. Apr. 2008;22(2):83-9. [pmid: 17669621].
507 Hewes JC, Imkampe A, Haji A, et al. Importance of routine cavity sampling in breast conservation surgery. Br J Surg. Jan. 2009;96(1):47-53. [pmid: 19108003].
508 Higgins G, Abdulkareen A, Loutfi A, et al. Productivity of needle localization to facilitate excision of nonpalpable, mammographically suspicious lesions. Can J Surg. Jun. 1991;34(3):287-9. [pmid: 2054762].
509 Hizukuri A, Nakayama R, Kashikura Y, et al. Computerized determination scheme for histological classification of breast mass using objective features corresponding to clinicians’ subjective impressions on ultrasonographic images. J Digit Imaging. Oct. 2013;26(5):958-70. [pmid: 23546774].
510 Homer MJ. Nonpalpable breast microcalcifications: frequency, management, and results of incisional biopsy. Radiology. Nov. 1992;185(2):411-3. [pmid: 1410347].
511 Hong JY, Kang YS, Kil HK. Anaesthesia for day case excisional breast biopsy: propofol-remifentanil compared with sevoflurane-nitrous oxide. Eur J Anaesthesiol. Jun. 2008;25(6):460-7. [pmid: 18298873].
512 Howe JR, Monsees B, Destouet J, et al. Needle localization breast biopsy: a model for multidisciplinary quality assurance. J Surg Oncol. Apr. 1995;58(4):233-9. [pmid: 7723366].
513 Hubbard R, Kerlikowske K, Buist D, et al. Evaluation of breast cancer screening strategies must be based on comparison of harms and benefits. AJR Am J Roentgenol. Oct. 2011;197(4):W793. author reply 4. [pmid: 21940562].
514 Hughes JH, Mason MC, Gray RJ, et al. A multi-site validation trial of radioactive seed localization as an alternative to wire localization. Breast J. Mar–Apr. 2008;14(2):153-7. [pmid: 18248562].
515 Iggo R, Rudewicz J, Monceau E, et al. Validation of a yeast functional assay for p53 mutations using clonal sequencing. J Pathol. Dec. 2013;231(4):441-8. [pmid: 23897043].
516 Irabor D, Okolo C. An audit of 149 consecutive breast biopsies in Ibadan, Nigeria. PAKISTAN JOURNAL OF MEDICAL SCIENCES. 2008;24(2):257.
517 Jacquemier J, Spyratos F, Esterni B, et al. SISH/CISH or qPCR as alternative techniques to FISH for determination of HER2 amplification status on breast tumors core needle biopsies: a multicenter experience based on 840 cases. BMC Cancer. 2013;13:351. [pmid: 23875536].
518 Jardines L, Fowble B, Schultz D, et al. Factors associated with a positive reexcision after excisional biopsy for invasive breast cancer. Surgery. Nov. 1995;118(5):803-9. [pmid: 7482265].
519 Javid SH, Carlson JW, Garber JE, et al. Breast MRI wire-guided excisional biopsy: specimen size as compared to mammogram wire-guided excisional biopsy and implications for use. Ann Surg Oncol. Dec. 2007;14(12):3352-8. [pmid: 17849165].
520 Javid SH, Kirstein LJ, Rafferty E, et al. Outcome of multiple-wire localization for larger breast cancers: do multiple wires translate into additional imaging, biopsies, and recurrences?. Am J Surg. Sep. 2009;198(3):368-72. [pmid: 19716884].
521 Jeter DD, Vest GR, Buday SJ. Mammographic guidewire localization of nonpalpable breast lesions. Am Surg. Jul. 1991;57(7):431-3. [pmid: 1647713].
522 Johnston JA, Clee CZ. Analysis of 308 localisation breast biopsies in a New Zealand hospital. Australas Radiol. May. 1991;35(2):148-51. [pmid: 1930011].
523 Johnston S, Trudeau M, Kaufman B, et al. Phase II study of predictive biomarker profiles for response targeting human epidermal growth factor receptor 2 (HER-2) in advanced inflammatory breast cancer with lapatinib monotherapy. J Clin Oncol. Mar. 1. 2008;26(7):1066-72. [pmid: 18212337].
524 Johnstone AJ, John TG, Thompson AM, et al. PDS II (polydioxanone) is the monofilament suture of choice for subcuticular wound closure following breast biopsy. J R Coll Surg Edinb. Apr. 1992;37(2):94-6. [pmid: 1377271].
525 Johnstone AJ, Thompson AM, Charles M, et al. Wound compression pads are of no value after local anaesthetic breast biopsy. Ann R Coll Surg Engl. Sep. 1991;73(5):303-4. [pmid: 1929132].
526 Joo JD, In JH, Kim DW, et al. The comparison of sedation quality, side effect and recovery profiles on different dosage of remifentanil patient-controlled sedation during breast biopsy surgery. Korean J Anesthesiol. Nov. 2012;63(5):431-5. [pmid: 23198037].
527 Kaelin CM, Smith TJ, Homer MJ, et al. Safety, accuracy, and diagnostic yield of needle localization biopsy of the breast performed using local anesthesia. J Am Coll Surg. Sep. 1994;179(3):267-72. [pmid: 8069420].
528 Kalu ON, Chow C, Wheeler A, et al. The diagnostic value of nipple discharge cytology: breast imaging complements predictive value of nipple discharge cytology. J Surg Oncol. Sep. 15. 2012;106(4):381-5. [pmid: 22396104].
529 Kanchwala SK, Bucky LP. Precision transverse rectus abdominis muscle flap breast reconstruction: a reliable technique for efficient preoperative planning. Ann Plast Surg. May. 2008;60(5):521-6. [pmid: 18434826].
530 Kanjer K, Tatic S, Neskovic-Konstantinovic Z, et al. Treatment response to preoperative anthracycline-based chemotherapy in locally advanced breast cancer: the relevance of proliferation and apoptosis rates. Pathol Oncol Res. Jul. 2013;19(3):577-88. [pmid: 23526163].
531 Kapp JM, Walker R, Haneuse S, et al. Are there racial/ethnic disparities among women younger than 40 undergoing mammography?. Breast Cancer Res Treat. Nov. 2010;124(1):213-22. [pmid: 20204501].
532 Karp G, Abu-Ghanem S, Novack V, et al. Localization of PKCeta in cell membranes as a predictor for breast cancer response to treatment. Onkologie. 2012;35(5):260-6. [pmid: 22868505].
533 Kaviani A, Fateh M, Ataie-Fashtami L, et al. Comparison of carbon dioxide laser and scalpel for breast lumpectomy: a randomized controlled trial. Photomed Laser Surg. Jun. 2008;26(3):257-62. [pmid: 18588441].
534 Kearney TJ, Morrow M. Effect of reexcision on the success of breast-conserving surgery. Ann Surg Oncol. Jul. 1995;2(4):303-7. [pmid: 7552618].
535 Kelly P, Winslow EH. Needle wire localization for nonpalpable breast lesions: sensations, anxiety levels, and informational needs. Oncol Nurs Forum. May. 1996;23(4):639-45. [pmid: 8735322].
536 Kim J, Lee J, Chang E, et al. Selective Sentinel Node Plus Additional Non-Sentinel Node Biopsy Based on an FDG-PET/CT Scan in Early Breast Cancer Patients: Single Institutional Experience. World J Surg. May. 2009;33(5):943-9. [pmid: 19259728].
537 Kim JA, Son EJ, Kim EK, et al. Postexcisional breast magnetic resonance imaging in patients with breast cancer: predictable findings of residual cancer. J Comput Assist Tomogr. Nov–Dec. 2009;33(6):940-5. [pmid: 19940664].
538 Kinsella MD, Nassar A, Siddiqui MT, et al. Estrogen receptor (ER), progesterone receptor (PR), and HER2 expression pre- and post- neoadjuvant chemotherapy in primary breast carcinoma: a single institutional experience. Int J Clin Exp Pathol. 2012;5(6):530-6. [pmid: 22949935].
539 Kishen R, Bartlett JM, Dixon JM, et al. Constructing tissue microarrays from core needle biopsies of breast cancers. Histopathology. Oct. 2011;59(4):794-6. [pmid: 21906129].
540 Klimberg VS, Westbrook KC, Korourian S. Use of touch preps for diagnosis and evaluation of surgical margins in breast cancer. Ann Surg Oncol. Apr–May. 1998;5(3):220-6. [pmid: 9607622].
541 Knutzen AM, Gisvold JJ. Likelihood of malignant disease for various categories of mammographically detected, nonpalpable breast lesions. Mayo Clin Proc. May. 1993;68(5):454-60. [pmid: 8479209].
542 Ko ES, Han H, Lee BH, et al. Sonographic changes after removing all benign breast masses with sonographically guided vacuum-assisted biopsy. Acta Radiol. Nov. 2009;50(9):968-74. [pmid: 19863404].
543 Kochli OR. Available stereotactic systems for breast biopsy. Recent Results Cancer Res. 2009;173:105-13. [pmid: 19763450].
544 Kombar OR, Fahmy DM, Brown MV, et al. Sonomammographic characteristics of invasive lobular carcinoma. Breast Cancer: Target Ther. 2012;4:115-24.
545 Kowal M, Filipczuk P, Obuchowicz A, et al. Computer-aided diagnosis of breast cancer based on fine needle biopsy microscopic images. Comput Biol Med. Oct. 1. 2013;43(10):1563-72. [pmid: 24034748].
546 Kruger JM, Thomas M, Korn R, et al. Detection of truncated HER2 forms in formalin-fixed, paraffin-embedded breast cancer tissue captures heterogeneity and is not affected by HER2-targeted therapy. Am J Pathol. Aug. 2013;183(2):336-43. [pmid: 23727348].
547 Kumar N, Sayed S, Moloo Z, et al. Fine-needle aspiration in suspected inflammatory breast cancer: case series with emphasis on approach to specimen adequacy. Acta Cytol. 2011;55(3):239-44. [pmid: 21525734].
548 Kuo SJ. Evaluation of the CO2 laser in performance of breast surgery. Zhonghua Yi Xue Za Zhi (Taipei). May. 1994;53(5):288-92. [pmid: 8039042].
549 Kyle DJ, Harvey AG, Shih B, et al. Identification of molecular phenotypic descriptors of breast capsular contracture formation using informatics analysis of the whole genome transcriptome. Wound Repair Regen. Sep–Oct. 2013;21(5):762-9. [pmid: 23941504].
550 Lai YC, Huang YS, Wang DW, et al. Computer-aided diagnosis for 3-d power Doppler breast ultrasound. Ultrasound Med Biol. Apr. 2013;39(4):555-67. [pmid: 23384464].
551 Laird-Fick HS, Gardiner JC, Tokala H, et al. HER2 status in elderly women with breast cancer. Journal of geriatric oncology. 2013;4(4):362-7. [pmid: 24472480].
552 Landheer ML, Klinkenbijl JH, Pasker-de Jong PC, et al. Residual disease after excision of non-palpable breast tumours: analysis of tumour characteristics. Eur J Surg Oncol. Oct. 2004;30(8):824-8. [pmid: 15336726].
553 Landheer ML, Veltman J, van Eekeren R, et al. MRI-guided preoperative wire localization of nonpalpable breast lesions. Clin Imaging. Jul–Aug. 2006;30(4):229-33. [pmid: 16814136].
554 Langlois SL, Carter ML. Carbon localisation of impalpable mammographic abnormalities. Australas Radiol. Aug. 1991;35(3):237-41. [pmid: 1763986].
555 Lantsberg L, Kirshtein B, Koretz M, et al. Role of wire-guided breast biopsy for diagnosis of malignant nonpalpable mammographic lesions. World J Surg. Dec. 1999;23(12):1279-81. [pmid: 10552121].
556 Law MT, Bennett IC. Structured ultrasonography workshop for breast surgeons: is it an effective training tool?. World J Surg. Mar. 2010;34(3):549-54. [pmid: 20054545].
557 Law NW, Johnson CD, Lamont PM, et al. Drainage or suture of the cavity after breast biopsy. Ann R Coll Surg Engl. Jan. 1990;72(1):11-3. [pmid: 2405764].
558 Lay SF, Crump JM, Frykberg ER, et al. Breast biopsy. Changing patterns during a five-year period. Am Surg. Feb. 1990;56(2):79-85. [pmid: 2306056].
559 Layfield LJ, Chrischilles EA, Cohen MB, et al. The palpable breast nodule. A cost-effectiveness analysis of alternate diagnostic approaches. Cancer. Sep. 1. 1993;72(5):1642-51. [pmid: 8348496].
560 Lazarus E, Mainiero MB, Gareen IF. Effect of referring physician specialty and practice type on referral for image-guided breast biopsy. J Am Coll Radiol. Jun. 2005;2(6):488-93. [pmid: 17411865].
561 Lee AH, Hodi Z, Ellis IO. False-negative assessment of oestrogen receptor on needle core biopsy of invasive carcinoma of the breast. J Clin Pathol. Feb. 2008;61(2):239-40. [pmid: 18223101].
562 Lee CH, Carter D. Detecting residual tumor after excisional biopsy of impalpable breast carcinoma: efficacy of comparing preoperative mammograms with radiographs of the biopsy specimen. AJR Am J Roentgenol. Jan. 1995;164(1):81-6. [pmid: 7998574].
563 Lee EJ, Oh SM. The efficacy of stereotactic vacuum-assisted biopsy and needle localization vacuum-assisted biopsy for diagnosing breast microcalcification. J Breast Cancer. 2010;13(1):53-8.
564 Lehr HA, Rochat C, Schaper C, et al. Mitotic figure counts are significantly overestimated in resection specimens of invasive breast carcinomas. Mod Pathol. Mar. 2013;26(3):336-42. [pmid: 23041831].
565 Lein BC, Alex WR, Zebley DM, et al. Results of needle localized breast biopsy in women under age 50. Am J Surg. Mar. 1996;171(3):356-9. [pmid: 8615472].
566 Leung TK, Huang PJ, Liang HH, et al. Retrospective Study of False-positive Breast Magnetic Resonance Images and Pathological Results in Taiwan. J Exp Clin Med. 2012;4(5):284-8.
567 Liberman L, Mason G, Morris EA, et al. Does size matter? Positive predictive value of MRI-detected breast lesions as a function of lesion size. AJR Am J Roentgenol. Feb. 2006;186(2):426-30. [pmid: 16423948].
568 Linda A, Zuiani C, Londero V, et al. Magnetic resonance imaging of radial sclerosing lesions (radial scars) of the breast. Eur J Radiol. Nov. 2012;81(11):3201-7. [pmid: 22386132].
569 Liu X, Li L, Chen F, et al. An intraoperative localization technique for a postexcision specimen of nonpalpable breast calcifications: a pilot study. Am Surg. Nov. 2011;77(11):1467-71. [pmid: 22196659].
570 London SJ, Connolly JL, Schnitt SJ, et al. A prospective study of benign breast disease and the risk of breast cancer. JAMA. Feb. 19. 1992;267(7):941-4. [pmid: 1734106].
571 Lopes-Costa PV, dos Santos AR, da Silva BB. The effect of raloxifene on Bax protein expression in breast carcinomas of postmenopausal women. Diagn Cytopathol. Jul. 2012;40(7):570-4. [pmid: 22707322].
572 Lorenzen J, Finck-Wedel AK, Lisboa B, et al. Second opinion assessment in diagnostic mammography at a breast cancer centre. Geburtshilfe Frauenheilkd. 2012;72(8):734-9. [pmid: 25258466].
573 Loubeyre P, Bodmer A, Tille JC, et al. Concordance between core needle biopsy and surgical excision specimens for tumour hormone receptor profiling according to the 2011 St. Gallen Classification, in clinical practice. Breast J. Nov–Dec. 2013;19(6):605-10. [pmid: 24165313].
574 Loukas C, Kostopoulos S, Tanoglidi A, et al. Breast cancer characterization based on image classification of tissue sections visualized under low magnification. Comput Math Methods Med. 2013;2013:829461. [pmid: 24069067].
575 Lu P, Zhu XQ, Xu ZL, et al. Increased infiltration of activated tumor-infiltrating lymphocytes after high intensity focused ultrasound ablation of human breast cancer. Surgery. Mar. 2009;145(3):286-93. [pmid: 19231581].
576 Luciani ML, Pediconi F, Telesca M, et al. Incidental enhancing lesions found on preoperative breast MRI: management and role of second-look ultrasound. Radiol Med. Sep. 2011;116(6):886-904. [pmid: 21293943].
577 Luini A, Sacchini V, Galimberti V, et al. Preoperative localization and surgical approach in 344 cases of non-palpable breast lesions. Eur J Surg Oncol. Oct. 1991;17(5):480-4. [pmid: 1936294].
578 Luo HJ, Chen X, Tu G, et al. Therapeutic application of ultrasound-guided 8-gauge Mammotome system in presumed benign breast lesions. Breast J. Sep–Oct. 2011;17(5):490-7. [pmid: 21762243].
579 Lyng MB, Laenkholm AV, Pallisgaard N, et al. Identification of genes for normalization of real-time RT-PCR data in breast carcinomas. BMC Cancer. 2008;8:20. [pmid: 18211679].
580 Ma K, Fenster A, Kornecki A, et al. A new lateral guidance device for stereotactic breast biopsy using an add-on unit to an upright mammography system. Conf Proc IEEE Eng Med Biol Soc. 2008;2008:3653-6. [pmid: 19163502].
581 Madeira M, Mattar A, Logullo AF, et al. Estrogen receptor alpha/beta ratio and estrogen receptor beta as predictors of endocrine therapy responsiveness-a randomized neoadjuvant trial comparison between anastrozole and tamoxifen for the treatment of postmenopausal breast cancer. BMC Cancer. 2013;13:425. [pmid: 24047421].
582 Mallapragada VG, Sarkar N, Podder TK. Robotic system for tumor manipulation and ultrasound image guidance during breast biopsy. Conf Proc IEEE Eng Med Biol Soc. 2008;2008:5589-92. [pmid: 19163984].
583 Mansour SM, Abolfotooh A. Does MRI help in the assessment of inflammatory breast disorders?. The Egyptian Journal of Radiology and Nuclear Medicine. 2012;43(3):487-97.
584 Markopoulos C, Kakisis J, Kouskos S, et al. Management of nonpalpable, mammographically detectable breast lesions. World J Surg. May. 1999;23(5):434-8. [pmid: 10085389].
585 Markopoulos C, Kouskos E, Revenas K, et al. Open surgical biopsy for nonpalpable breast lesions detected on screening mammography. Eur J Gynaecol Oncol. 2005;26(3):311-4. [pmid: 15991535].
586 Masroor I, Afzal S, Sakhawat S, et al. Negative predictive value of mammography and sonography in mastalgia with negative physical findings. J Pak Med Assoc. Sep. 2009;59(9):598-601. [pmid: 19750852].
587 Masroor I, Afzal S, Shafqat G, et al. Usefulness of hook wire localization biopsy under imaging guidance for nonpalpable breast lesions detected radiologically. Int J Womens Health. 2012;4:445-9. [pmid: 23071414].
588 Maxwell AJ. Ultrasound-guided vacuum-assisted excision of breast papillomas: review of 6-years experience. Clin Radiol. Aug. 2009;64(8):801-6. [pmid: 19589419].
589 Maxwell AJ, Pearson JM, Bishop HM. Crude open biopsy rates for benign screen detected lesions no longer reflect breast screening quality--time to change the standard. J Med Screen. 2002;9(2):83-5. [pmid: 12133928].
590 McCreery BR, Frankl G, Frost DB. An analysis of the results of mammographically guided biopsies of the breast. Surg Gynecol Obstet. Mar. 1991;172(3):223-6. [pmid: 1847244].
591 McGhan LJ, McKeever SC, Pockaj BA, et al. Radioactive seed localization for nonpalpable breast lesions: review of 1,000 consecutive procedures at a single institution. Ann Surg Oncol. Oct. 2011;18(11):3096-101. [pmid: 21947587].
592 McMahon MA, James JJ, Cornford EJ, et al. Does the insertion of a gel-based marker at stereotactic breast biopsy allow subsequent wire localizations to be carried out under ultrasound guidance?. Clin Radiol. Sep. 2011;66(9):840-4. [pmid: 21658688].
593 McManus V, Desautels JE, Benediktsson H, et al. Enhancement of true-positive rates for nonpalpable carcinoma of the breast through mammographic selection. Surg Gynecol Obstet. Sep. 1992;175(3):212-8. [pmid: 1514155].
594 Medjhoul A, Canale S, Mathieu MC, et al. Breast lesion excision sample (BLES biopsy) combining stereotactic biopsy and radiofrequency: is it a safe and accurate procedure in case of BIRADS 4 and 5 breast lesions?. Breast J. Nov–Dec. 2013;19(6):590-4. [pmid: 24102869].
595 Meeuwis C, Peters NH, Mali WP, et al. Targeting difficult accessible breast lesions: MRI-guided needle localization using a freehand technique in a 3.0 T closed bore magnet. Eur J Radiol. May. 2007;62(2):283-8. [pmid: 17218074].
596 Melanson GF, Otchy DP, Walters MJ, et al. The importance of stabilizing the specimen taken at needle localized biopsy of the breast for microcalcifications. Surg Gynecol Obstet. May. 1992;174(5):376-8. [pmid: 1570614].
597 Memis A, Ustun EE, Orguc S. Mammographic and ultrasonographic evaluation of breast after excisional biopsy. European journal of ultrasound. 1997;5(1):47-51.
598 Menet E, Becette V, Briffod M. Cytologic diagnosis of lobular carcinoma of the breast: experience with 555 patients in the Rene Huguenin Cancer Center. Cancer. Apr. 25. 2008;114(2):111-7. [pmid: 18300231].
599 Meng W, Zhang G, Wu C, et al. Preliminary results of acoustic radiation force impulse (ARFI) ultrasound imaging of breast lesions. Ultrasound Med Biol. Sep. 2011;37(9):1436-43. [pmid: 21767903].
600 Meyer JE, Eberlein TJ, Stomper PC, et al. Biopsy of occult breast lesions. Analysis of 1261 abnormalities. JAMA. May. 2. 1990;263(17):2341-3. [pmid: 2157903].
601 Meyer JE, Kopans DB. Analysis of mammographically obvious carcinomas of the breast with benign results upon initial biopsy. Surg Gynecol Obstet. Oct. 1981;153(4):570-2. [pmid: 6269239].
602 Meyer JE, Smith DN, Kaelin C, et al. Surgical breast biopsy after wire localization: The impact of large core needle biopsy. JOURNAL OF WOMENS IMAGING. 2004;6(3):125-31.
603 Miller RS, Adelman RW, Espinosa MH, et al. The early detection of nonpalpable breast carcinoma with needle localization. Experience with 500 patients in a community hospital. Am Surg. Mar. 1992;58(3):193-8. [pmid: 1313665].
604 Mok PM, Keepin Y. Stereotactic breast biopsies for lesions discovered on routine mammography: experience at the North Shore Hospital. N Z Med J. Jul. 14. 2000;113(1113):273-4. [pmid: 10935565].
605 Mokbel K, Ahmed M, Nash A, et al. Re-excision operations in nonpalpable breast cancer. J Surg Oncol. Apr. 1995;58(4):225-8. discussion 9-32. [pmid: 7723365].
606 Monostori Z, Herman PG, Carmody DP, et al. Limitations in distinguishing malignant from benign lesions of the breast by systematic review of mammograms. Surg Gynecol Obstet. Dec. 1991;173(6):438-42. [pmid: 1948599].
607 Montgomery GH, Weltz CR, Seltz M, et al. Brief presurgery hypnosis reduces distress and pain in excisional breast biopsy patients. Int J Clin Exp Hypn. Jan. 2002;50(1):17-32. [pmid: 11778705].
608 Montrey JS, Levy JA, Brenner RJ. Wire fragments after needle localization. AJR Am J Roentgenol. Nov. 1996;167(5):1267-9. [pmid: 8911193].
609 Moreno M, Wiltgen JE, Bodanese B, et al. Radioguided breast surgery for occult lesion localization - correlation between two methods. J Exp Clin Cancer Res. 2008;27:29. [pmid: 18706096].
610 Morris EA, Liberman L, Dershaw DD, et al. Preoperative MR imaging-guided needle localization of breast lesions. AJR Am J Roentgenol. May. 2002;178(5):1211-20. [pmid: 11959734].
611 Morris KT, Pommier RF, Vetto JT. Office-based wire-guided open breast biopsy under local anesthesia is accurate and cost effective. Am J Surg. May. 2000;179(5):422-5. [pmid: 10930494].
612 Mueller X, Amery A, Lallemand RC. Biopsy of mammographically-detected breast lesions in a district hospital. Eur J Surg Oncol. Oct. 1993;19(5):415-9. [pmid: 8405476].
613 Mujtaba S, Haroon S, Faridi N, et al. Correlation of human epidermal growth factor receptor 2 (HER-2/neu) receptor status with hormone receptors Oestrogen Receptor, Progesterone Receptor status and other prognostic markers in breast cancer: an experience at tertiary care hospital in Karachi. J Pak Med Assoc. Jul. 2013;63(7):854-8. [pmid: 23901708].
614 Murgo S, Wyshoff H, Faverly D, et al. Computed tomography-guided localization of breast lesions. Breast J. Mar–Apr. 2008;14(2):169-75. [pmid: 18248560].
615 Muslumanoglu M, Dolay K, Ozmen V, et al. Comparison of fine needle aspiration cytology and excisional biopsy in palpable breast cancers. Radiol Med. Mar. 1995;89(3):225-8. [pmid: 7754112].
616 Nair A, Jaleel S, Sathya V, et al. The role of freehand needle core biopsy in the diagnosis of isolated axillary lymphadenopathy. Breast. Jun. 2009;18(3):175-7. [pmid: 19362840].
617 Nassar A, Radhakrishnan A, Cabrero IA, et al. Intratumoral heterogeneity of immunohistochemical marker expression in breast carcinoma: a tissue microarray-based study. Appl Immunohistochem Mol Morphol. Oct. 2010;18(5):433-41. [pmid: 20485156].
618 National Guideline Clearinghouse (NGC). Guideline summary: Advanced breast cancer Diagnosis and treatment. National Guideline Clearinghouse (NGC) [Web site]. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). [cited 2013 June 25]. Available: http://www.guideline.gov.
619 National Guideline Clearinghouse (NGC). Guideline summary: Staging. Management of early breast cancer. National Guideline Clearinghouse (NGC) [Web site]. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). [cited 2013 June 25]. Available: http://www.guideline.gov.
620 National Guideline Clearinghouse (NGC). Guideline summary: Use of tumor markers in testicular, prostate, colorectal, breast, and ovarian cancers. National Guideline Clearinghouse (NGC) [Web site]. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). [cited 2013 June 25]. Available: http://www.guideline.gov.
621 National Guideline Clearinghouse (NGC). Guideline summary: General principles of care In: Management of early breast cancer. National Guideline Clearinghouse (NGC) [Web site]. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). [cited 2013 June 25]. Available: http://www.guideline.gov.
622 National Guideline Clearinghouse (NGC). Guideline summary: Breast cancer screening clinical practice guideline. National Guideline Clearinghouse (NGC) [Web site]. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). [cited 2013 June 25]. Available: http://www.guideline.gov.
623 Nggada HA, Yawe KD, Abdulazeez J, et al. Breast cancer burden in Maiduguri, North eastern Nigeria. Breast J. May–Jun. 2008;14(3):284-6. [pmid: 18476884].
624 Niemann TH, Lucas JG, Marsh WL Jr. To freeze or not to freeze. A comparison of methods for the handling of breast biopsies with no palpable abnormality. Am J Clin Pathol. Aug. 1996;106(2):225-8. [pmid: 8712178].
625 Nishikawa RM, Pesce LL. Estimating sensitivity and specificity for technology assessment based on observer studies. Acad Radiol. Jul. 2013;20(7):825-30. [pmid: 23660073].
626 Ocal K, Dag A, Turkmenoglu O, et al. Radioguided occult lesion localization versus wire-guided localization for non-palpable breast lesions: randomized controlled trial. Clinics (Sao Paulo). 2011;66(6):1003-7. [pmid: 21808866].
627 O’Hanlon DM, Colbert ST, Keane PW, et al. Preemptive bupivacaine offers no advantages to postoperative wound infiltration in analgesia for outpatient breast biopsy. Am J Surg. Jul. 2000;180(1):29-32. [pmid: 11036135].
628 Ohi Y, Umekita Y, Rai Y, et al. Mucocele-like lesions of the breast: a long-term follow-up study. Diagn Pathol. 2011;6:29. [pmid: 21466711].
629 Ohlsson-Wilhelm BM, Wang G. Circulating killer cells in women undergoing needle-directed excisional breast biopsy. Eur J Histochem. 1994;38(Suppl 1):77-82. [pmid: 8547715].
630 Ohtake E, Asaga T, Inaba M. Sentinel lymphoscintigraphy in patients with breast cancer undergoing excisional biopsy. Ann Nucl Med. Dec. 2005;19(8):671-5. [pmid: 16444992].
631 Omranipour R, Alipour S, Hadji M, et al. Accuracy of estrogen and progesterone receptor assessment in core needle biopsy specimens of breast cancer. Iran Red Crescent Med J. Jun. 2013;15(6):515-8. [pmid: 24349751].
632 Opie H, Estes NC, Jewell WR, et al. Breast biopsy for nonpalpable lesions: a worthwhile endeavor?. Am Surg. Aug. 1993;59(8):490-3. discussion 3-4. [pmid: 8393310].
633 Orel SG, Kay N, Reynolds C, et al. BI-RADS categorization as a predictor of malignancy. Radiology. Jun. 1999;211(3):845-50. [pmid: 10352614].
634 Orel SG, Schnall MD, Powell CM, et al. Staging of suspected breast cancer: effect of MR imaging and MR-guided biopsy. Radiology. Jul. 1995;196(1):115-22. [pmid: 7784554].
635 Osako T, Iwase T, Akiyama F. Reply: Isolated tumour cells and micrometastases in intraductal breast cancer: a simple mechanical question in some cases. Br J Cancer. May. 14. 2013;108(9):1921. [pmid: 23538389].
636 Owings DV, Hann L, Schnitt SJ. How thoroughly should needle localization breast biopsies be sampled for microscopic examination? A prospective mammographic/pathologic correlative study. Am J Surg Pathol. Jun. 1990;14(6):578-83. [pmid: 2337206].
637 Ozumba BC, Nzegwu MA, Anyikam A, et al. Breast disease in children and adolescents in eastern Nigeria--a five-year study. J Pediatr Adolesc Gynecol. Jun. 2009;22(3):169-72. [pmid: 19539203].
638 Palmedo H, Schomburg A, Grunwald F, et al. Technetium-99m-MIBI scintimammography for suspicious breast lesions. J Nucl Med. Apr. 1996;37(4):626-30. [pmid: 8691253].
639 Palmer ML, Tsangaris TN. Breast biopsy in women 30 years old or less. Am J Surg. Jun. 1993;165(6):708-12. [pmid: 8506971].
640 Palmieri FM, DePeri ER, Mincey BA, et al. Comprehensive diagnostic program for medically underserved women with abnormal breast screening evaluations in an urban population. Mayo Clin Proc. Apr. 2009;84(4):317-22. [pmid: 19339648].
641 Parlakgumus A, Karakoc D, Ozenc A. Nine years’ experience of needle localized breast biopsy in a university hospital: results and evaluation of the role of the surgeon in decision making. Acta Chir Belg. Sep–Oct. 2008;108(5):548-51. [pmid: 19051464].
642 Patchefsky AS, Potok J, Hoch WS, et al. Increased detection of occult breast carcinoma after more thorough histologic examination of breast biopsies. Am J Clin Pathol. Dec. 1973;60(6):799-804. [pmid: 4357121].
643 Paterson ML, Nathanson SD, Havstad S. Hematomas following excisional breast biopsies for invasive breast carcinoma: the influence of deep suture approximation of breast parenchyma. Am Surg. Nov. 1994;60(11):845-8. [pmid: 7978679].
644 Pathmanathan P, Gavaghan DJ, Whiteley JP, et al. Predicting tumor location by modeling the deformation of the breast. IEEE Trans Biomed Eng. Oct. 2008;55(10):2471-80. [pmid: 18838373].
645 Patton ML, Haith LR Jr, Goldman WT. An improved technique for needle localized biopsy of occult lesions of the breast. Surg Gynecol Obstet. Jan. 1993;176(1):25-9. [pmid: 8381241].
646 Pegolo E, Puppin C, Gerometta A, et al. One-step nucleic acid amplification (OSNA) for intraoperative evaluation of sentinel lymph node status in breast cancer: a comparative study between CK19 protein expression and CK19 mRNA level in primary tumors and lymph node metastasis. Virchows Arch. Jul. 2013;463(1):7-15. [pmid: 23779101].
647 Perdue P, Page D, Nellestein M, et al. Early detection of breast carcinoma: a comparison of palpable and nonpalpable lesions. Surgery. Jun. 1992;111(6):656-9. [pmid: 1595061].
648 Perdue PW, Galbo C, Ghosh BC. Stratification of palpable and nonpalpable breast cancer by method of detection and age. Ann Surg Oncol. Nov. 1995;2(6):512-5. [pmid: 8591081].
649 Perfetto F, Fiorentino F, Urbano F, et al. Adjunctive diagnostic value of MRI in the breast radial scar. Radiol Med. Aug. 2009;114(5):757-70. [pmid: 19484584].
650 Petit JY, Veronesi U, Rey P, et al. Nipple-sparing mastectomy: risk of nipple-areolar recurrences in a series of 579 cases. Breast Cancer Res Treat. Mar. 2009;114(1):97-101. [pmid: 18360773].
651 Petrik DW, McCready DR, Goel V, et al. The rate of breast-conserving surgery for early breast cancer is not influenced by the surgical strategy of excisional biopsy followed by the definitive procedure. Breast J. May–Jun. 2001;7(3):158-65. [pmid: 11469928].
652 Platt R, Zucker JR, Zaleznik DF, et al. Perioperative antibiotic prophylaxis and wound infection following breast surgery. J Antimicrob Chemother. Feb. 1993;31(Suppl B):43-8. [pmid: 8449845].
653 Popiela TJ, Kibil W, Herman-Sucharska I, et al. The use of magnetic resonance mammography in women at increased risk for developing breast cancer. Wideochir Inne Tech Malo Inwazyjne. Mar. 2013;8(1):55-62. [pmid: 23630555].
654 Purnell CA, Arnold RM. Retrospective analysis of communication with patients undergoing radiological breast biopsy. J Support Oncol. Nov–Dec. 2010;8(6):259-63. [pmid: 21265393].
655 Qi CJ, Ning YL, Zhu YL, et al. In vitro chemosensitivity in breast cancer using ATP-tumor chemosensitivity assay. Arch Pharm Res. Dec. 2009;32(12):1737-42. [pmid: 20162402].
656 Raghavan K, Shah AK, Cosgrove JM. Intraoperative breast problem--focused sonography a valuable tool in the training of surgical residents. J Surg Educ. Sep–Oct. 2008;65(5):350-3. [pmid: 18809164].
657 Raju U. Mammographic Localization Biopsy for Ductal Carcinoma In Situ: A Simple Mapping Technique for Sampling and Size Estimation. Breast J. Nov. 2000;6(6):379-87. [pmid: 11348396].
658 Ramsey-Stewart G, Lauer CS. Use of a specimen-evaluation device for the diagnosis of impalpable breast lesions detected by mammography. Med J Aust. Feb. 17. 1992;156(4):244-6. [pmid: 1310796].
659 Rao R, Lilley L, Andrews V, et al. Axillary staging by percutaneous biopsy: sensitivity of fine-needle aspiration versus core needle biopsy. Ann Surg Oncol. May. 2009;16(5):1170-5. [pmid: 19263171].
660 Rappaport W, Thompson S, Wong R, et al. Complications associated with needle localization biopsy of the breast. Surg Gynecol Obstet. Apr. 1991;172(4):303-6. [pmid: 2006456].
661 Raptopoulos V, Baum JK, Hochman M, et al. High resolution CT mammography of surgical biopsy specimens. J Comput Assist Tomogr. Mar–Apr. 1996;20(2):179-84. [pmid: 8606220].
662 Reeves MJ, Osuch JR, Pathak DR. Development of a clinical decision rule for triage of women with palpable breast masses. J Clin Epidemiol. Jul. 2003;56(7):636-45. [pmid: 12921932].
663 Reid SE Jr, Scanlon EF, Bernstein JR, et al. An alternative approach to nonpalpable breast biopsies. J Surg Oncol. Jun. 1990;44(2):93-6. [pmid: 2162454].
664 Rey JE, Gardner SM, Cushing RD. Determinants of surgical site infection after breast biopsy. Am J Infect Control. Mar. 2005;33(2):126-9. [pmid: 15761414].
665 Reynolds HE, Jackson VP, Musick BS. Preoperative needle localization in the breast: utility of local anesthesia. Radiology. May. 1993;187(2):503-5. [pmid: 8475298].
666 Ricci MD, Calvano Filho, Oliveira CM, Filho HR, et al. Analysis of the concordance rates between core needle biopsy and surgical excision in patients with breast cancer. Rev Assoc Med Bras. Sep–Oct. 2012;58(5):532-6. [pmid: 23090222].
667 Rickard MT, Lee W, Read JW, et al. Breast cancer diagnosis by screening mammography: early results of the Central Sydney Area Health Service Breast X-ray Programme. Med J Aust. Jan. 21. 1991;154(2):126-31. [pmid: 1986190].
668 Rikabi A, Hussain S. Diagnostic usefulness of tru-cut biopsy in the diagnosis of breast lesions. Oman Med J. Mar. 2013;28(2):125-7. [pmid: 23599882].
669 Rimm DL, Stastny JF, Rimm EB, et al. Comparison of the costs of fine-needle aspiration and open surgical biopsy as methods for obtaining a pathologic diagnosis. Cancer. Feb. 25. 1997;81(1):51-6. [pmid: 9100542].
670 Roses DF, Mitnick J, Harris MN, et al. The risk of carcinoma in wire localization biopsies for mammographically detected clustered microcalcifications. Surgery. Nov. 1991;110(5):877-86. [pmid: 1658957].
671 Rosner D, Lane WW, Penetrante R. Ductal carcinoma in situ with microinvasion. A curable entity using surgery alone without need for adjuvant therapy. Cancer. Mar. 15. 1991;67(6):1498-503. [pmid: 1848153].
672 Rubin P, O’Hanlon D, Browell D, et al. Tumour bed biopsy detects the presence of multifocal disease in patients undergoing breast conservation therapy for primary breast carcinoma. Eur J Surg Oncol. Feb. 1996;22(1):23-6. [pmid: 8846861].
673 Ruckhaberle E, Karn T, Denkert C, et al. Predictive value of sphingosine kinase 1 expression in neoadjuvant treatment of breast cancer. J Cancer Res Clin Oncol. Oct. 2013;139(10):1681-9. [pmid: 23955546].
674 Saarela AO, Kiviniemi HO, Rissanen TJ, et al. Cosmetic results after wire-guided biopsy of benign breast lesions. J Am Coll Surg. Dec. 1998;187(6):610-5. [pmid: 9849734].
675 Sadeghi R, Forghani MN, Memar B, et al. Comparison of pre-operative lymphoscintigraphy with inter-operative gamma probe and dye technique regarding the number of detected sentinel lymph nodes. Hell J Nucl Med. Jan–Apr. 2009;12(1):30-2. [pmid: 19330179].
676 Sailors DM, Crabtree JD, Land RL, et al. Needle localization for nonpalpable breast lesions. Am Surg. Mar. 1994;60(3):186-9. [pmid: 8116978].
677 Sakakibara E, Kimachi S, Hashimoto K, et al. An aspiration material preparation system: application of a new liquid-based cytology technique for fine-needle aspiration of the breast. Acta Cytol. 2011;55(1):92-9. [pmid: 21135528].
678 Sanders LM, Lacz NL, Lara J. 16 year experience with aspiration of noncomplex breast cysts: cytology results with focus on positive cases. Breast J. Sep. 2012;18(5):443-52. [pmid: 22845618].
679 Sangoi A, Vose J, Atmodjo D, et al. A randomized controlled trial of the PEAK PlasmaBlade in open breast biopsy compared to scalpel and traditional electrosurgery. 2010:S186.
680 A randomized controlled trial of the PEAK PlasmaBlade in open breast biopsy compared to scalpel and traditional electrosurgery. Ann Surg Oncol. SPRINGER. 233 SPRING ST, NEW YORK, NY 10013 USA. 2010:17.
681 Sari AA, Mobinizadeh M, Azadbakht M. A systematic review of the effects of diffuse optical imaging in breast diseases. Iran J Cancer Prev. 2013;6(1):44-51. [pmid: 25250109].
682 Sauer G, Schneiderhan-Marra N, Kazmaier C, et al. Prediction of nodal involvement in breast cancer based on multiparametric protein analyses from preoperative core needle biopsies of the primary lesion. Clin Cancer Res. Jun. 1. 2008;14(11):3345-53. [pmid: 18519762].
683 Saunders G, Lakra Y, Libcke J. Comparison of needle aspiration cytologic diagnosis with excisional biopsy tissue diagnosis of palpable tumors of the breast in a community hospital. Surg Gynecol Obstet. Jun. 1991;172(6):437-40. [pmid: 1852078].
684 Saura C, Tseng L-M, Chan S, et al. Neoadjuvant Doxorubicin/Cyclophosphamide Followed by Ixabepilone or Paclitaxel in Early Stage Breast Cancer and Evaluation of βIII-Tubulin Expression as a Predictive Marker. Oncologist. 2013;18(7).
685 Scaperrotta G, Ferranti C, Costa C, et al. Role of sonoelastography in non-palpable breast lesions. Eur Radiol. Nov. 2008;18(11):2381-9. [pmid: 18523780].
686 Scheiden R, Sand J, Tanous AM, et al. Accuracy of frozen section diagnoses of breast lesions after introduction of a national programme in mammographic screening. Histopathology. Jul. 2001;39(1):74-84. [pmid: 11454047].
687 Schnur JB, Montgomery GH, Hallquist MN, et al. Anticipatory psychological distress in women scheduled for diagnostic and curative breast cancer surgery. Int J Behav Med. Jan–Mar. 2008;15(1):21-8. [pmid: 18444017].
688 Schwab FD, Burger H, Isenschmid M, et al. Suspicious axillary lymph nodes in patients with unremarkable imaging of the breast. Eur J Obstet Gynecol Reprod Biol. May. 2010;150(1):88-91. [pmid: 20189710].
689 Seah DS, Scott SM, Najita J, et al. Attitudes of patients with metastatic breast cancer toward research biopsies. Ann Oncol. Jul. 2013;24(7):1853-9. [pmid: 23493137].
690 Seltzer MH. Preoperative prediction of open breast biopsy results. Cancer. May. 1. 1997;79(9):1822-7. [pmid: 9129002].
691 Sewell RF, Brenchley PE. Coupling of mono- and polyamino ligands to solid phases by nucleophilic attack on coupling groups that may be spontaneously hydrolysed. J Chromatogr. Jan. 26. 1990;525(1):246-8. [pmid: 2338446].
692 Shaheen E, Van Ongeval C, Zanca F, et al. The simulation of 3D microcalcification clusters in 2D digital mammography and breast tomosynthesis. Med Phys. Dec. 2011;38(12):6659-71. [pmid: 22149848].
693 Shaikh A, Fatima S, Shaikh SM. Diagnostic value of needle-localization biopsy in the management of non-palpable breast lesions. Rawal Medical Journal. 2013;38(1):59-60.
694 Sharma H, Alekseychuk A, Leskovsky P, et al. Determining similarity in histological images using graph-theoretic description and matching methods for content-based image retrieval in medical diagnostics. Diagn Pathol. 2012;7:134. [pmid: 23035717].
695 Sheikh HE, Abdulaziz NY. Intraoperative ultrasound localization of nonpalpable breast cancers: A valuable aid during breast-conserving surgery. The Egyptian Journal of Radiology and Nuclear Medicine. 2013;44(2):411-5.
696 Shigekawa T, Ijichi N, Ikeda K, et al. FOXP1, an estrogen-inducible transcription factor, modulates cell proliferation in breast cancer cells and 5-year recurrence-free survival of patients with tamoxifen-treated breast cancer. Horm Cancer. Oct. 2011;2(5):286-97. [pmid: 21901488].
697 Shimauchi A, Jansen SA, Abe H, et al. Breast cancers not detected at MRI: review of false-negative lesions. AJR Am J Roentgenol. Jun. 2010;194(6):1674-9. [pmid: 20489112].
698 Shin HJ, Kim HH, Ko MS, et al. BI-RADS descriptors for mammographically detected microcalcifications verified by histopathology after needle-localized open breast biopsy. AJR Am J Roentgenol. Dec. 2010;195(6):1466-71. [pmid: 21098211].
699 Shroff JH, Lloyd LR, Schroder DM. Open breast biopsy. A critical analysis. Am Surg. Aug. 1991;57(8):481-5. [pmid: 1928989].
700 Singhal H, Potter C, Osborne MP. No effect of timing of biopsy in the menstrual cycle on incidence of bone marrow micrometastasis in patients with breast cancer. Ann Surg Oncol. Sep. 1997;4(6):503-5. [pmid: 9309341].
701 Skliris GP, Rowan BG, Al-Dhaheri M, et al. Immunohistochemical validation of multiple phospho-specific epitopes for estrogen receptor alpha (ERalpha) in tissue microarrays of ERalpha positive human breast carcinomas. Breast Cancer Res Treat. Dec. 2009;118(3):443-53. [pmid: 19104930].
702 Skotnicki P, Łuczyńska E, Herman K, et al. USG-guided excision biopsy in case of ambiguous breast USG images. Polish Journal of Radiology. 2007;72(3):29-31.
703 Skripenova S, Layfield LJ. Initial margin status for invasive ductal carcinoma of the breast and subsequent identification of carcinoma in reexcision specimens. Arch Pathol Lab Med. Jan. 2010;134(1):109-14. [pmid: 20073613].
704 Smith M, Zhai X, Harter R, et al. A novel MR-guided interventional device for 3D circumferential access to breast tissue. Med Phys. Aug. 2008;35(8):3779-86. [pmid: 18777937].
705 Snell MJ, Ostrow LB, DuBois JJ, et al. Needle-localized biopsy of occult breast lesions: an update. Mil Med. Feb. 1992;157(2):61-4. [pmid: 1318524].
706 Soluri A, Scopinaro F, De Vincentis G, et al. 99MTC [13LEU] bombesin and a new gamma camera, the imaging probe, are able to guide mammotome breast biopsy. Anticancer Res. May–Jun. 2003;23(3A):2139-42. [pmid: 12894588].
707 Son BK, Bong JG, Park SH, et al. Ductal carcinoma in situ and sentinel lymph node biopsy. J Breast Cancer. Dec. 2011;14(4):301-7. [pmid: 22323917].
708 SONUÇ MLSB-R, İÇİN K, DEĞERLERİ PÖ. POSITIVE PREDICTIVE VALUES OF THE SONOGRAPHIC BI-RADS FINAL ASSESSMENT CATEGORIES FOR BREAST LESIONS.
709 Stein MA, Karlan MS. Calcifications in breast biopsy specimens: discrepancies in radiologic-pathologic identification. Radiology. Apr. 1991;179(1):111-4. [pmid: 2006260].
710 Stein T, Cosimo E, Yu X, et al. Loss of reelin expression in breast cancer is epigenetically controlled and associated with poor prognosis. Am J Pathol. Nov. 2010;177(5):2323-33. [pmid: 20847288].
711 Steinberg JL, Trudeau ME, Ryder DE, et al. Combined fine-needle aspiration, physical examination and mammography in the diagnosis of palpable breast masses: their relation to outcome for women with primary breast cancer. Can J Surg. Aug. 1996;39(4):302-11. [pmid: 8697321].
712 Steri V, Farnedi A, Montinari E, et al. Fast track biopsy method: a rapid approach to preoperative diagnoses. Pathologica. Apr. 2010;102(2):41-5. [pmid: 23596755].
713 Tafra L, Guenther JM, Giuliano AE. Planned segmentectomy. A necessity for breast carcinoma. Arch Surg. Sep. 1993;128(9):1014-8. discussion 8-20. [pmid: 8396387].
714 Takagi K, Ishida T, Miki Y, et al. Intratumoral concentration of estrogens and clinicopathological changes in ductal carcinoma in situ following aromatase inhibitor letrozole treatment. Br J Cancer. Jul. 9. 2013;109(1):100-8. [pmid: 23756858].
715 Takhellambam YS, Lourembam SS, Sapam OS, et al. Comparison of Ultrasonography and Fine Needle Aspiration Cytology in the Diagnosis of Malignant Breast Lesions. 2013.
716 Tanaka K, Komoike Y, Egawa C, et al. Indeterminate calcification and clustered cystic lesions are strongly predictive of the presence of mucocele-like tumor of the breast: a report of six cases. Breast Cancer. 2009;16(1):77-82. [pmid: 18478314].
717 Tang J, Wang X, Wu YP, et al. Significance of methylene blue dye for localization biopsy of nonpalpable breast lesions. Ai Zheng. Jan. 2009;28(1):79-81. [pmid: 19448424].
718 Tang J, Xie XM, Wang X, et al. Radiocolloid in combination with methylene dye localization, rather than wire localization, is a preferred procedure for excisional biopsy of nonpalpable breast lesions. Ann Surg Oncol. Jan. 2011;18(1):109-13. [pmid: 20680696].
719 Tartter PI, Kaplan J, Bleiweiss I, et al. Lumpectomy margins, reexcision, and local recurrence of breast cancer. Am J Surg. Feb. 2000;179(2):81-5. [pmid: 10773138].
720 Taxin A, Tartter PI, Zappetti D. Breast cancer diagnosis by fine needle aspiration and excisional biopsy. Recurrence and survival. Acta Cytol. Mar–Apr. 1997;41(2):302-6. [pmid: 9100758].
721 Taylor L, Basro S, Apffelstaedt JP, et al. Time for a re-evaluation of mammography in the young? Results of an audit of mammography in women younger than 40 in a resource restricted environment. Breast Cancer Res Treat. Aug. 2011;129(1):99-106. [pmid: 21698411].
722 Tez S, Dener C, Koktener A, et al. The value of fine needle aspiration and cytologic examination of impalpable complicated breast cysts. Bratisl Lek Listy. 2008;109(9):387-90. [pmid: 19040143].
723 Tezuka K, Onoda N, Takashima T, et al. Clinical significance of intra-tumoral sinusoidal structures showing lympho-endothelial immunoreactivity in breast cancer. Oncol Rep. Jul. 2008;20(1):25-32. [pmid: 18575714].
724 Thomas PA, Vazquez MF, Waisman J. Comparison of fine-needle aspiration and frozen section of palpable mammary lesions. Mod Pathol. Sep. 1990;3(5):570-4. [pmid: 2235982].
725 Thomassin-Naggara I, Trop I, Chopier J, et al. Nonmasslike enhancement at breast MR imaging: the added value of mammography and US for lesion categorization. Radiology. Oct. 2011;261(1):69-9. [pmid: 21771958].
726 Thompson WR, Bowen JR, Dorman BA, et al. Mammographic localization and biopsy of nonpalpable breast lesions. A 5-year study. Arch Surg. Jun. 1991;126(6):730-3. discussion 3-4. [pmid: 1645516].
727 Thurley P, Evans A, Hamilton L, et al. Patient satisfaction and efficacy of vacuum-assisted excision biopsy of fibroadenomas. Clin Radiol. Apr. 2009;64(4):381-5. [pmid: 19264182].
728 Tisi P, Langham-Brown J, Jackson A, et al. Localization biopsy for impalpable breast lesions in a district general hospital. Eur J Surg Oncol. Apr. 1994;20(2):115-7. [pmid: 8181574].
729 Torres-Tabanera M, Alonso-Bartolome P, Vega-Bolivar A, et al. Percutaneous microductectomy with a directional vacuum-assisted system guided by ultrasonography for the treatment of breast discharge: experience in 63 cases. Acta Radiol. Apr. 2008;49(3):271-6. [pmid: 18365813].
730 Troxel DB. Medicolegal aspects of error in pathology. Arch Pathol Lab Med. May. 2006;130(5):617-9. [pmid: 16683874].
731 Tsai YM, Hsu HM, Chen CJ, et al. Association of estrogen receptor, progesterone receptor and HER2 following neoadjuvant systemic treatment in breast cancer patients undergoing surgery. Ir J Med Sci. Mar. 2014;183(1):71-5. [pmid: 23757214].
732 Ueno E, Aiyoshi Y, Imamura A, et al. Ultrasonically guided biopsy of nonpalpable lesions of the breast by the spot method. Surg Gynecol Obstet. Feb. 1990;170(2):153-5. [pmid: 2405524].
733 Uhercik M, Kybic J, Liebgott H, et al. Model fitting using RANSAC for surgical tool localization in 3-D ultrasound images. IEEE Trans Biomed Eng. Aug. 2010;57(8):1907-16. [pmid: 20483680].
734 van Breest Smallenburg V, Duijm LE, Voogd AC, et al. Lower sensitivity of screening mammography after previous benign breast surgery. Int J Cancer. Jan. 1. 2012;130(1):122-8. [pmid: 21328339].
735 van Vlymen JM, Sa Rego MM, White PF. Benzodiazepine premedication: can it improve outcome in patients undergoing breast biopsy procedures?. Anesthesiology. Mar. 1999;90(3):740-7. [pmid: 10078675].
736 Venter A, Rosca E, Mutiu G, et al. The value of ultrasounds exam correlated with frozen section diagnosis in the breast tumors. Rom J Morphol Embryol. 2010;51(4):745-50. [pmid: 21103636].
737 Verkooijen HM, Peeters PH, Pijnappel RM, et al. Diagnostic accuracy of needle-localized open breast biopsy for impalpable breast disease. Br J Surg. Mar. 2000;87(3):344-7. [pmid: 10718805].
738 Volynskaya Z, Haka AS, Bechtel KL, et al. Diagnosing breast cancer using diffuse reflectance spectroscopy and intrinsic fluorescence spectroscopy. J Biomed Opt. Mar–Apr. 2008;13(2):024012. [pmid: 18465975].
739 Wachter DL, Fasching PA, Haeberle L, et al. Prognostic molecular markers and neoadjuvant therapy response in anthracycline-treated breast cancer patients. Arch Gynecol Obstet. Feb. 2013;287(2):337-44. [pmid: 22955249].
740 Wahner-Roedler DL, Hruska CB, O’Connor MK, et al. Molecular breast imaging for women presenting with a history of non-reproducible bloody nipple discharge and negative findings on routine imaging studies: A pilot study. J Surg Radiol. 2011;2(1):92-9.
741 Wakefield SE, Powis SJ. Benign breast surgery: is there a need for outpatient follow-up?. Ann R Coll Surg Engl. Nov. 1995;77(6):457-9. [pmid: 8540668].
742 Wang HY, Jiang YX, Zhu QL, et al. Differentiation of benign and malignant breast lesions: a comparison between automatically generated breast volume scans and handheld ultrasound examinations. Eur J Radiol. Nov. 2012;81(11):3190-200. [pmid: 22386134].
743 Wang J, Chang KJ, Chen CY, et al. Evaluation of the diagnostic performance of infrared imaging of the breast: a preliminary study. Biomed Eng Online. 2010;9:3. [pmid: 20055999].
744 Wang J, Xu B, Yuan P, et al. TOP2A amplification in breast cancer is a predictive marker of anthracycline-based neoadjuvant chemotherapy efficacy. Breast Cancer Res Treat. Sep. 2012;135(2):531-7. [pmid: 22864769].
745 Wang T, Wang K, Yao Q, et al. Prospective study on combination of electrical impedance scanning and ultrasound in estimating risk of development of breast cancer in young women. Cancer Invest. Mar. 2010;28(3):295-303. [pmid: 19857040].
746 Wang X, Lederman D, Tan J, et al. Computerized detection of breast tissue asymmetry depicted on bilateral mammograms: a preliminary study of breast risk stratification. Acad Radiol. Oct. 2010;17(10):1234-41. [pmid: 20619697].
747 Wang ZL, Liu G, Li JL, et al. Sonographically guided percutaneous excision of clinically benign breast masses. J Clin Ultrasound. Jan. 2011;39(1):1-5. [pmid: 20957735].
748 Warren HW, Griffith CD, McLean L, et al. Should breast biopsy cavities be drained?. Ann R Coll Surg Engl. Jan. 1994;76(1):39-41. [pmid: 8117018].
749 Weaver M. Breast cancer in nonpalpable lesions: can mammographic parenchymal pattern improve the predictive value of biopsy?. Am Surg. Nov. 1992;58(11):692-4. [pmid: 1485702].
750 Weise LM, Bruder M, Eibach S, et al. Efficacy and safety of local versus general anesthesia in stereotactic biopsies: a matched-pairs cohort study. J Neurosurg Anesthesiol. Apr. 2013;25(2):148-53. [pmid: 23103527].
751 Weyant M, Carroccio A, Tartter PI, et al. Determinants of success with spot localization biopsy of the breast. J Am Coll Surg. Dec. 1995;181(6):521-4. [pmid: 7582226].
752 Wiksell H, Schassburger KU, Janicijevic M, et al. Prevention of tumour cell dissemination in diagnostic needle procedures. Br J Cancer. Nov. 23. 2010;103(11):1706-9. [pmid: 21045831].
753 Wilkinson J, Appleton CM, Margenthaler JA. Utility of breast MRI for evaluation of residual disease following excisional biopsy. J Surg Res. Oct. 2011;170(2):233-9. [pmid: 21550064].
754 Wilson R, Kavia S. Comparison of large-core vacuum-assisted breast biopsy and excision systems. Recent Results Cancer Res. 2009;173:23-41. [pmid: 19763447].
755 Wiratkapun C, Bunyapaiboonsri W, Wibulpolprasert B, et al. Biopsy rate and positive predictive value for breast cancer in BI-RADS category 4 breast lesions. J Med Assoc Thai. Jul. 2010;93(7):830-7. [pmid: 20649064].
756 Woodward S, Daly CP, Patterson SK, et al. Ensuring excision of intraductal lesions: marker placement at time of ductography. Acad Radiol. Nov. 2010;17(11):1444-8. [pmid: 20650666].
757 Wulfkuhle JD, Berg D, Wolff C, et al. Molecular analysis of HER2 signaling in human breast cancer by functional protein pathway activation mapping. Clin Cancer Res. Dec. 1. 2012;18(23):6426-35. [pmid: 23045247].
758 Xiong J, Yu D, Wei N, et al. An estrogen receptor alpha suppressor, microRNA-22, is downregulated in estrogen receptor alpha-positive human breast cancer cell lines and clinical samples. FEBS J. Apr. 2010;277(7):1684-94. [pmid: 20180843].
759 Yang JH, Lee WS, Kim SW, et al. Effect of core-needle biopsy vs fine-needle aspiration on pathologic measurement of tumor size in breast cancer. Arch Surg. Feb. 2005;140(2):125-8. [pmid: 15723992].
760 Yang WT, Whitman GJ, Johnson MM, et al. Needle localization for excisional biopsy of breast lesions: comparison of effect of use of full-field digital versus screen-film mammographic guidance on procedure time. Radiology. Apr. 2004;231(1):277-81. [pmid: 15068954].
761 Yararbas U, Argon AM, Yeniay L, et al. Problematic aspects of sentinel lymph node biopsy and its relation to previous excisional biopsy in breast cancer. Clin Nucl Med. Dec. 2009;34(12):854-8. [pmid: 20139816].
762 Yom CK, Han W, Kim SW, et al. Clinical significance of annexin A1 expression in breast cancer. J Breast Cancer. Dec. 2011;14(4):262-8. [pmid: 22323911].
763 Yom CK, Moon BI, Choe KJ, et al. Long-term results after excision of breast mass using a vacuum-assisted biopsy device. ANZ J Surg. Nov. 2009;79(11):794-8. [pmid: 20078528].
764 Yoshinaga Y, Enomoto Y, Fujimitsu R, et al. Image and pathological changes after radiofrequency ablation of invasive breast cancer: a pilot study of nonsurgical therapy of early breast cancer. World J Surg. Feb. 2013;37(2):356-63. [pmid: 23052813].
765 You SS, Jiang YX, Zhu QL, et al. US-guided diffused optical tomography: a promising functional imaging technique in breast lesions. Eur Radiol. Feb. 2010;20(2):309-17. [pmid: 19707770].
766 Youk JH, Son EJ, Kim JA, et al. Scoring system based on BI-RADS lexicon to predict probability of malignancy in suspicious microcalcifications. Ann Surg Oncol. May. 2012;19(5):1491-8. [pmid: 22173328].
767 Zhi W, Gu X, Qin J, et al. Solid breast lesions: clinical experience with US-guided diffuse optical tomography combined with conventional US. Radiology. Nov. 2012;265(2):371-8. [pmid: 23012460].
768 Zhu Q, You S, Jiang Y, et al. Detecting angiogenesis in breast tumors: comparison of color Doppler flow imaging with ultrasound-guided diffuse optical tomography. Ultrasound Med Biol. Jun. 2011;37(6):862-9. [pmid: 21531497].
769 Zografos GC, Zagouri F, Sergentanis TN, et al. Excisional breast biopsy under local anesthesia: stress-related neuroendocrine, metabolic and immune reactions during the procedure. In Vivo. Jul–Aug. 2009;23(4):649-52. [pmid: 19567403].
770 National Guideline Clearinghouse (NGC). Guideline summary: ACR Appropriateness Criteria® palpable breast masses. National Guideline Clearinghouse (NGC) [Web site]. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). [cited 2013 June 25]. Available: http://www.guideline.gov.
771 Albarracin CT, Nguyen CV, Whitman GJ, et al. Identifying patients with atypical ductal hyperplasia diagnosed at core-needle biopsy who are at low risk of malignancy. Radiology. Dec. 2010;257(3):893-4. author reply 984. [pmid: 21084420].
772 Amir E, Bedard PL, Ocana A, et al. Benefits and harms of detecting clinically occult breast cancer. J Natl Cancer Inst. Oct. 17. 2012;104(20):1542-7. [pmid: 22988040].
773 Bond M, Pavey T, Welch K, et al. Psychological consequences of false-positive screening mammograms in the UK. Evid Based Med. Apr. 2013;18(2):54-61. [pmid: 22859786].
774 Bowman K, Munoz A, Mahvi DM, et al. Lobular neoplasia diagnosed at core biopsy does not mandate surgical excision. J Surg Res. Oct. 2007;142(2):275-80. [pmid: 17662303].
775 Brant W. Percutaneous core biopsy of the breast. West J Med. Jul–Aug. 1996;165(1–2):52-3. [pmid: 8855685].
776 Carkaci S, Santiago L, Adrada BE, et al. Screening for breast cancer with sonography. Semin Roentgenol. Oct. 2011;46(4):285-91. [pmid: 22035671].
777 Cohen Y, Gekhtman D, Strano S. Mammography-sonography concordance. AJR Am J Roentgenol. Sep. 2011;197(3):765. author reply 6. [pmid: 21862823].
778 Cooney CS, Khouri NF, Tsangaris TN. The role of breast MRI in the management of patients with breast disease. Adv Surg. 2008;42:299-312. [pmid: 18953825].
779 Cusumano P, Polkowski WP, Liu H, et al. Percutaneous tissue acquisition: a treatment for breast cancer? Vacuum-assisted biopsy devices are not indicated for extended tissue removal. Eur J Cancer Prev. Aug. 2008;17(4):323-30. [pmid: 18562956].
780 Damron TA. Vacuum-assisted biopsy is useful for breast tissue, but how useful is it for soft-tissue tumors in orthopaedics? Commentary on an article by Zarah Mohr, MD, et al.: “Vacuum-assisted minimally invasive biopsy of soft-tissue tumors”. J Bone Joint Surg Am. Jan. 18. 2012;94(2):e11. [pmid: 22258008].
781 Dershaw DD. Stereotaxic breast biopsy. Semin Ultrasound CT MR. Oct. 1996;17(5):444-59. [pmid: 8896110].
782 Eby PR, Lehman CD. Magnetic resonance imaging--guided breast interventions. Top Magn Reson Imaging. Jun. 2008;19(3):151-62. [pmid: 18941395].
783 Giordano L, Giorgi D, Ventura L, et al. Time trends of process and impact indicators in Italian breast screening programmes 1999–2009. Epidemiol Prev. Sep–Dec. 2011;35(5–6 Suppl 5):28-38. [pmid: 22166348].
784 Haid A, Knauer M, Dunzinger S, et al. Intra-operative sonography: a valuable aid during breast-conserving surgery for occult breast cancer. Ann Surg Oncol. Nov. 2007;14(11):3090-101. [pmid: 17593330].
785 Hashimoto BE. New sonographic breast technologies. Semin Roentgenol. Oct. 2011;46(4):292-301. [pmid: 22035672].
786 Kaiser WA, Pfleiderer SO, Baltzer PA. MRI-guided interventions of the breast. J Magn Reson Imaging. Feb. 2008;27(2):347-55. [pmid: 18219688].
787 Karamouzis MV, Likaki-Karatza E, Ravazoula P, et al. Non-palpable breast carcinomas: correlation of mammographically detected malignant-appearing microcalcifications and molecular prognostic factors. Int J Cancer. Nov. 1. 2002;102(1):86-90. [pmid: 12353238].
788 Kettritz U. Modern concepts of ductal carcinoma in situ (DCIS) and its diagnosis through percutaneous biopsy. Eur Radiol. Feb. 2008;18(2):343-50. [pmid: 17899107].
789 King V, Dershaw DD. Combining MRI with mammography: a more effective approach to breast cancer detection. Expert Rev Anticancer Ther. Aug. 2011;11(8):1155-8. [pmid: 21916568].
790 Kluttig A, Trocchi P, Heinig A, et al. Reliability and validity of needle biopsy evaluation of breast-abnormalities using the B-categorization--design and objectives of the Diagnosis Optimisation Study (DIOS). BMC Cancer. 2007;7:100. [pmid: 17570833].
791 Kontos M, Felekouras E, Fentiman IS. Radiofrequency ablation in the treatment of primary breast cancer: no surgical redundancies yet. Int J Clin Pract. May. 2008;62(5):816-20. [pmid: 18412934].
792 Kopans DB. Review of stereotaxic large-core needle biopsy and surgical biopsy results in nonpalpable breast lesions. Radiology. Dec. 1993;189(3):665-6. [pmid: 8234687].
793 Kopans DB. Caution on core. Radiology. Nov. 1994;193(2):325-6. discussion 6-8. [pmid: 7972737].
794 Krupinski EA, Borders M, Fitzpatrick K. Processing stereotactic breast biopsy specimens: impact of specimen radiography system on workflow. Breast J. Jul–Aug. 2013;19(4):455-6. [pmid: 23701431].
795 Marshall D, Laberge JM, Firetag B, et al. The changing face of percutaneous image-guided biopsy: molecular profiling and genomic analysis in current practice. J Vasc Interv Radiol. Aug. 2013;24(8):1094-103. [pmid: 23806383].
796 Masood S. Reproducibility of breast biopsy. Eur J Radiol. Sep. 2012;81(Suppl 1):S95-6. [pmid: 23083620].
797 Masood S, Vass L, Ibarra JA Jr, et al. Breast pathology guideline implementation in low- and middle-income countries. Cancer. Oct. 15. 2008;113(8 Suppl):2297-304. [pmid: 18837021].
798 Mattheis J. Breast-cancer screening. N Engl J Med. Jan. 12. 2012;366(2):190-1. author reply 1-2. [pmid: 22236238].
799 Molleran V. Postbiopsy management. Semin Roentgenol. Jan. 2011;46(1):40-50. [pmid: 21134527].
800 Monticciolo DL. Postbiopsy confirmation of MR-detected lesions biopsied using ultrasound. AJR Am J Roentgenol. Jun. 2012;198(6):W618-20. [pmid: 22623580].
801 Morris EA, Kuhl CK, Lehman CD. Ensuring high-quality breast MR imaging technique and interpretation. Radiology. Mar. 2013;266(3):996-7. [pmid: 23431233].
802 National Guideline Clearinghouse (NGC). Guideline summary: Diagnosis of breast disease. National Guideline Clearinghouse (NGC) [Web site]. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). [cited 2013 June 25]. Available: http://www.guideline.gov.
803 National Guideline Clearinghouse (NGC). Guideline summary: Breast cancer In: Suspected cancer in primary care: guidelines for investigation, referral and reducing ethnic disparities. National Guideline Clearinghouse (NGC) [Web site]. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). [cited 2013 June 25]. Available: http://www.guideline.gov.
804 National Guideline Clearinghouse (NGC). Guideline summary: ACR Appropriateness Criteria® nonpalpable mammographic findings (excluding calcifications). National Guideline Clearinghouse (NGC) [Web site]. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). [cited 2013 June 25]. Available: http://www.guideline.gov.
805 National Guideline Clearinghouse (NGC). Guideline summary: Gynaecological cancer In: Suspected cancer in primary care: guidelines for investigation, referral and reducing ethnic disparities. National Guideline Clearinghouse (NGC) [Web site]. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). [cited 2013 June 25]. Available: http://www.guideline.gov.
806 National Guideline Clearinghouse (NGC). Guideline summary: ACR Appropriateness Criteria® breast microcalcifications - initial diagnostic workup. National Guideline Clearinghouse (NGC) [Web site]. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). [cited 2013 June 25]. Available: http://www.guideline.gov.
807 National Guideline Clearinghouse (NGC). Guideline summary: Early and locally advanced breast cancer Diagnosis and treatment. National Guideline Clearinghouse (NGC) [Web site]. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). [cited 2013 June 25]. Available: http://www.guideline.gov.
808 Nields MW. Cost-effectiveness of image-guided core needle biopsy versus surgery in diagnosing breast cancer. Acad Radiol. Apr. 1996;3(Suppl 1):S138-40. [pmid: 8796544].
809 Orel S. Who should have breast magnetic resonance imaging evaluation?. J Clin Oncol. Feb. 10. 2008;26(5):703-11. [pmid: 18258977].
810 Park JM, Yang L, Laroia A, et al. Missed and/or misinterpreted lesions in breast ultrasound: reasons and solutions. Can Assoc Radiol J. Feb. 2011;62(1):41-9. [pmid: 20947291].
811 Sardanelli F, Giuseppetti GM, Canavese G, et al. Indications for breast magnetic resonance imaging. Consensus document “Attualita in senologia”, Florence 2007. Radiol Med. Dec. 2008;113(8):1085-95. [pmid: 18953635].
812 Schousboe JT, Kerlikowske K, Loh A, et al. Personalizing mammography by breast density and other risk factors for breast cancer: analysis of health benefits and cost-effectiveness. Ann Intern Med. Jul. 5. 2011;155(1):10-20. [pmid: 21727289].
813 Schulz-Wendtl R. The vacora biopsy system. Recent Results Cancer Res. 2009;173:97-103. [pmid: 19763449].
814 Sedgwick EL. Ultrasound-guided breast biopsy. Ultrasound Cln. 2011;6(3):327-33.
815 Sung JS, Lee CH, Morris EA, et al. Patient follow-up after concordant histologically benign imaging-guided biopsy of MRI-detected lesions. AJR Am J Roentgenol. Jun. 2012;198(6):1464-9. [pmid: 22623564].
816 Trop I, Labelle M, David J, et al. Second-look targeted studies after breast magnetic resonance imaging: practical tips to improve lesion identification. Curr Probl Diagn Radiol. Sep–Oct. 2010;39(5):200-11. [pmid: 20674767].
817 Tsang YY, Yau KK, Tang CN. Vacuum-assisted excision for benign breast lesions. Surgical Practice. 2013;17(3):129.
818 Tse GM, Tan PH, Cheung HS, et al. Intermediate to highly suspicious calcification in breast lesions: a radio-pathologic correlation. Breast Cancer Res Treat. Jul. 2008;110(1):1-7. [pmid: 17674189].
819 Tse GM, Tan PH, Lui PC, et al. Spindle cell lesions of the breast--the pathologic differential diagnosis. Breast Cancer Res Treat. May. 2008;109(2):199-207. [pmid: 17636400].
820 Uematsu T. Screening and diagnosis of breast cancer in augmented women. Breast Cancer. 2008;15(2):159-64. [pmid: 18293060].
821 Verkooijen HM. Needle core biopsy for screen detected breast lesions: time to raise the bar?. Eur J Cancer. Nov. 2008;44(17):2540-1. [pmid: 18930652].
822 Vogel VG. Epidemiology, genetics, and risk evaluation of postmenopausal women at risk of breast cancer. Menopause. Jul–Aug. 2008;15(4 Suppl):782-9. [pmid: 18596599].
823 Warner E. Breast Surveillance of Patients with BRCA1 and BRCA2 Mutations. Current Breast Cancer Reports. 2013;5(3):255-61.
824 Perez S, Néron S, Séguin C, Holcroft C, Lisbona A, Rosberger Z. The effect of a hypnotic intervention on anxiety and psychological distress in the breast biopsy suite: A pilot study. [conference abstract].
825 Zagouri F, Sergentanis TN, Zografos GC. Vacuum-assisted breast biopsy: A role also on palpable lesions?. Med Hypotheses. 2008;70(1):198-9. [pmid: 17582694].
826 Update on current care guidelines: breast cancer diagnostics and screening. Duodecim. 2010;126(10):1183-5. [pmid: 20597348].
827 Aksoy F, Gundes E, Vatansev C, et al. Surgical treatment of phyllodes tumors of the breast: A single center experience: Memenin fillodes tumorlerinde cerrahi tedavi: Tek merkez deneyimi. J Breast Health. 2013;9(2):52-6.
828 Ding J.-H, Peng W.-J, Jiang Z.-X, Liu G.-Y, Ji Y.-J, Zheng X.-J, Hu D.-T, Wu J, Chang C, Zeng W. The first round imaging screening of breast cancer in Shanghai community: Primary results in 8234 patients. Chin J Radiol. 2013.
829 Apesteguia L, Ovelar A, Dominguez-Cunchillos F, et al. Radiofrequency ablation of breast carcinomas: preliminary results of a clinical trial. Radiologia. Nov–Dec. 2009;51(6):591-600. [pmid: 19913265].
830 Aulmann S. Ductal and lobular preneoplasia: role in breast cancer development. Pathologe. Nov. 2011;32(Suppl 2):316-20. [pmid: 21915665].
831 Bak M, Konyar E, Schneider F, et al. The “gray zone” in fine-needle aspiration cytology of the organized mammography screening. Cytohistological correlation: A “szurke zona” az emlorak mammografias szervezett szureseben. Citologiai-hisztologiai tanulmany. Orvosi Hetil. 2011;152(8):292-5.
832 Barreto AS, Mendes MF, Thuler LC. Evaluation of a strategy adopted to expand adherence to breast cancer screening in Brazilian Northeast. Rev Bras Ginecol Obstet. Feb. 2012;34(2):86-91. [pmid: 22437768].
833 Bellolio JE, Guzman GP, Orellana CJ, et al. Diagnostic value of frozen section biopsy during surgery for breast lesions or neoplasms. Rev Med Chil. Sep. 2009;137(9):1173-8. [pmid: 20011957].
834 Bettencourt H, Amendoeira I. Are core-needle biopsies representative of breast carcinomas?: Serao as microbiopsias representativas nos carcinomas da mama?. Arq Med. 2012;26(4):145-8.
835 Bilkova A, Janik V, Bendova M, et al. Computed tomography laser mamography (CTLM) - New imaging method in mammadiagnostics: Computed tomography laser mammography (CTLM) - Nova vysetrovaci metoda v mamarni diagnostice. Ceska Radiol. 2009;63(1):69-75.
836 Bokun ZV, Bokun R, Tatomirovic Z. Determination of infiltrative ductal breast carcinoma differentiation grade in biopsy imprints. Vojnosanit Pregl. Jul. 2009;66(7):527-33. [pmid: 19678576].
837 Bouchlaka A, Ben Abdallah M, Ben Aissa R, et al. Results and evaluation of 3 years of a large scale mammography program in the Ariana area of Tunisia. Tunis Med. Jul. 2009;87(7):438-42. [pmid: 20063676].
838 Bouhafa T, Masbah O, Bekkouch I, et al. Phyllodes tumors of the breast: analysis of 53 patients. Cancer Radiother. Apr. 2009;13(2):85-91. [pmid: 19119040].
839 Brouwer OR, Donker M, Woerdeman LA, et al. Local recurrence after skin-sparing mastectomy. Ned Tijdschr Geneeskd. 2012;156(31):A4692. [pmid: 22853767].
840 Chaveron C, Bachelle F, Fauquet I, et al. Clip migration after stereotactic macrobiopsy and presurgical localization: technical considerations and tricks. J Radiol. Jan. 2009;90(1 Pt 1):31-6. [pmid: 19182711].
841 Contreras-Melendez L, Piottante-Becker A, Contreras-Seitz M, et al. The Chilean experience of variability in the assessment of HER2 status using immunohistochemistry: Variabilidad en la determinacion del estado de HER2 por inmunohistoquimica en Chile. Revista Esp Patol. 2013;46(1):33-9.
842 Daubner D, Friedrich K, Spieth S. Lactating adenoma of the breast - differential diagnosis in pregnancy and during breast feeding. Rofo. Oct. 2012;184(10):934-5. [pmid: 22744327].
843 de Lara CT, Fournier M, Macgrogan G. Ganglions sentinelles et carcinome canalaire in situ. Oncologie. 2013;15(6):331-5.
844 de Souza E, de Souza LF, Batista Mda C, et al. Breast biopsy performed by the helicoid biopsy technique: an experimental study. Rev Bras Ginecol Obstet. Dec. 2010;32(12):597-601. [pmid: 21484028].
845 Ding Jianhui eaSCwwbcsrotfrotiaR-. Shanghai Community 8234 women with breast cancer screening results of the first round of the image analysis.
846 Dumay-Levesque T, Lemery S, Dauplat MM, et al. Evaluation of stereotactic core biopsies of the breast with the 10-gauge Vacora(R) biopsy device: a review of 541 procedures. J Radiol. Mar. 2011;92(3):226-35. [pmid: 21501761].
847 Engvad B, Laenkholm AV, Schwartz W, et al. Fine needle aspiration cytology of mammography screening. Ugeskr Laeger. Aug. 17. 2009;171(34):2379-82. [pmid: 19732519].
848 Fischer T, Grigoryev M, Bossenz S, et al. Sonographic detection of microcalcifications - potential of new method. Ultraschall Med. Aug. 2012;33(4):357-65. [pmid: 22322544].
849 Fischer U, Schwethelm L, Baum FT, et al. Effort, accuracy and histology of MR-guided vacuum biopsy of suspicious breast lesions--retrospective evaluation after 389 interventions. Rofo. Aug. 2009;181(8):774-81. [pmid: 19582655].
850 Fouche CJ, Tabareau F, Michenet P, et al. Specimen radiography assessment of surgical margins status in subclinical breast carcinoma: a diagnostic study. J Gynecol Obstet Biol Reprod (Paris). Jun. 2011;40(4):314-22. [pmid: 21349659].
851 Frankel PP, Esteves VF, Thuler LC, et al. Diagnostic accuracy of the fine needle aspiration cytology and core needle biopsy as a diagnostic method for breast lesions. Rev Bras Ginecol Obstet. Mar. 2011;33(3):139-43. [pmid: 21829998].
852 Frikha M, Yaiche O, Elloumi F, et al. Results of a pilot study for breast cancer screening by mammography in Sfax region, Tunisia. J Gynecol Obstet Biol Reprod (Paris). May. 2013;42(3):252-61. [pmid: 23478043].
853 Tunon de Lara C, Fournier M, Macgrogan G. Sentinel lymph nodes and ductal carcinoma in situ: Ganglions sentinelles et carcinome canalaire in situ. Oncologie.
854 Gomi N, Iwase T, Akiyama F. VAB (vacuum-assisted breast biopsy system). Nihon Rinsho. Sep. 2012;70(Suppl 7):302-5. [pmid: 23350410].
855 Gong J, Yao Y, Tang J, et al. Impact of preoperative chemotherapy on expression of hormone receptor and drug-resistant related proteins in breast cancer tissue. Chin. J. Clin Oncol. 2012;39(23):1896-8.
856 Hahn M, Fischbach E, Fehm T, et al. Are breast biopsies adequately funded? A process cost & revenue analysis. Rofo. Apr. 2011;183(4):347-57. [pmid: 21113867].
857 He YJ, Li JF, Wang TF, et al. Diagnostic value and health economic evaluation of ultrasound-combined fine-needle aspiration cytology in primary breast cancer. Zhonghua Yi Xue Za Zhi. Dec. 11. 2012;92(46):3288-90. [pmid: 23328516].
858 Heineke A, Bendel M, Tronnier M, et al. Grouped papules on the left chest wall. J Dtsch Dermatol Ges. Sep. 2010;8(9):715-7. [pmid: 20821831].
859 Horak M, Barta J, Andryskova H, et al. Breast biopsy guided by magnetic resonance - First experiences: Biopsie prsu se zamerenim cile na magneticke rezonanci - Prvni zkusenosti. Ceska Radiol. 2009;63(1):56-60.
860 Jiang H, Fu J, Zhang F, et al. Value of steel wire implantation with prone table stereotactic digital mammography in the detection of microcalcification of the breast. Chin. J. Clin Oncol. 2010;37(1):1-4.
861 Jing Z, Yu-xin J, Qing-li Z, et al. Impact of lesion size on the detection rate of non-palpable breast malignant lesions. Zhongguo Yi Xue Ke Xue Yuan Xue Bao. Apr. 2011;33(2):136-41. [pmid: 21529439].
862 Kanayev SV, Novikov SN, Semiglazov VF, et al. The role of scintimammography and ultrasound in diagnosis of early (less than 10 mm) breast cancer. Vopr Onkol. 2011;57(5):622-6. [pmid: 22238933].
863 Khlifi A, Ziadi S, Trimeche M, et al. Clinicopathological study of breast lobular carcinoma in Central Tunisia: A report of 74 cases: Etude clinicopathologique des carcinomes lobulaires du sein dans le Centre tunisien: a propos de 74 cas. J. Afr Cancer. 2011;3(3):155-62.
864 Kosa C, Garami Z, Dinya T, et al. Predictive factors of invasion with initial diagnosis of ductal carcinoma in situ based on core biopsy. Magy Seb. Aug. 2012;65(4):218-21. [pmid: 22940391].
865 Kuipers IM, Oostenbroek RJ, Storm RK, et al. Suppose a mammary carcinoma is absent from the surgical specimen. Ned Tijdschr Geneeskd. 2009;153:A3. [pmid: 19900338].
866 ZaL-YaZaR-ZaZaC-WaLaJaaWa L. Quantitative dynamic contrast enhanced MR in the prediction of response in breast cancer patients undergoing neoadjuvant chemotherapy. Chin J Radiol.
867 Langhans L, Vejborg TS, Vejborg I, et al. Marking of non-palpable changes in breast tissue. Ugeskr Laeger. Aug. 20. 2012;174(34):1891-4. [pmid: 22909568].
868 Li TY, Yu ZY, Wang LX, et al. Value of ultrasound-guided Mammotome rotation system in diagnosis and treatment of breast lesions. Chin. J. Cancer Prev Treat. 2010;17(24):2060-1.
869 Li Y, Tong XS, Mu WM, et al. Evaluation of the value of ultrasound-guided core needle biopsy in the diagnosis of breast lesions. Zhonghua Zhong Liu Za Zhi. Jun. 2010;32(6):470-1. [pmid: 20819494].
870 Liu M, Chen W, Li XR, et al. Study on diagnostic accuracy of ultrasound-guided core needle breast biopsy. Zhonghua Bing Li Xue Za Zhi. Nov. 2010;39(11):739-42. [pmid: 21215163].
871 Lobato Miguélez J, Moreno Domingo J, Martinez Urruzola J, et al. Riesgo de invasión en carcinoma in situ de mama diagnosticado por biopsia percutánea: estudio retrospectivo. Clínica e Investigación en Ginecología y Obstetricia. 2013.
872 Ma WY, Zhang P, Zhang BL, et al. Phase II clinical trial of neoadjuvant therapy with carboplatin plus paclitaxel for locally advanced triple-negative breast cancer. Zhonghua Zhong Liu Za Zhi. Oct. 2012;34(10):770-4. [pmid: 23291072].
873 Manych M. MR-detected lesions of the breast - When should a specific sonography follow?: MR-Lsionen der Brust - Wann Sollte Eine Gezielte Sonografie Folgen?. RoFo Fortschr. Geb. Rontgenstr Bildgebenden Verfahren. 2010;182(4):305.
874 MAO F, PAN B, SUN Q, et al. Diagnosis and treatment of neuroendocrine breast cancer: A retrospective analysis of ten cases and review of the literature. TUMOR. 2013;33(2):171-6.
875 Martins EC, Soares A, Guimaraes CM, et al. Ultrasound guided core biopsy for breast lesions using 16G needle. Rev Col Bras Cir. Aug. 2009;36(4):312-5. [pmid: 20076920].
876 Mercier-Vogel L, Couson F, Kohlik M, et al. Impact of breast MRI and PET-CT in breast cancer staging. Rev Med Suisse. May. 26. 2010;6(250):1076-8. 80. [pmid: 20564867].
877 Mohajeri G, Khezreh H, Kushki AM, et al. Evaluation of fine needle aspiration versus core needle biopsy for breast cancer detection. J Isfahan Med Sch. 2012;30(174).
878 Monter SEP, Gómez ACA, Chávez VG, et al. Abordaje quirúrgico de nódulos mamarios durante el embarazo•. Ginecol Obstet Mex. 2009;77(4):191-8.
879 Neira P, Aguirre B, Taub T, et al. Breast MRI--histologic correlation for ductal carcinoma in situ. Radiologia. Jul–Aug. 2009;51(4):396-402. [pmid: 19406443].
880 Nicolas F, Voltzenlogel MC, Lavoue V, et al. Pleomorphic lobular intraepithelial neoplasia: clinical, histological and prognostic study of nine cases. J Gynecol Obstet Biol Reprod (Paris). Apr. 2013;42(2):130-6. [pmid: 23265671].
881 Obermann EC, Eppenberger-Castori S, Tapia C. Assessment of proliferation: core biopsy or resection specimen? Discrepancies in breast cancer with low and high proliferation. Pathologe. May. 2012;33(3):245-50. [pmid: 22576598].
882 Ouldamer L, Body G, Arbion F, et al. Mucocele-like lesions of the breast: management after diagnosis on ultrasound guided core biopsy or stereotactic vacuum-assisted biopsy. Gynecol Obstet Fertil. Jul–Aug. 2010;38(7–8):455-9. [pmid: 20605510].
883 Peres A, Becette V, Guinebretiere JM, et al. The lesions of flat epithelial atypia diagnosed on breast biopsy. Gynecol Obstet Fertil. Oct. 2011;39(10):579-85. [pmid: 21924938].
884 Perez Monter SE, Arteaga Gomez AC, Gorbea Chavez V, et al. Surgical approach of breast nodules during pregnancy. Ginecol Obstet Mex. Apr. 2009;77(4):189-96. [pmid: 19496511].
885 Perlet C, Schneider P, Amaya B, et al. MR-Guided vacuum biopsy of 206 contrast-enhancing breast lesions. Rofo. Jan. 2002;174(1):88-95. [pmid: 11793291].
886 Plaza Loma S, Rodriguez de Diego Y, Gonzalez Blanco I, et al. Stereotactic vacuum-assisted breast biopsy. Correlation with surgical excisional biopsy: Biopsia mamaria asistida por vacio y guiada por estereotaxia. Correlacion con la biopsia quirurgica. Prog. Obstet Ginecol. 2012;55(2):66-70.
887 Prutki M, Stern-Padovan R, Jakic-Razumovic J, et al. Ultrasound guided breast biopsy--a retrospective study and literature review. Lijec Vjesn. Sep–Oct. 2012;134(9–10):270-5. [pmid: 23297511].
888 Qin NS, Wang XY, Wu CX, et al. Correlation of tumor vessel morphologic features with clinical and pathological characteristics of breast cancer on dynamic contrast enhanced MRI. Chin. J. Med Imaging Technol. 2009;25(2):244-7.
889 Ren AH, Zhang XP, Li J, et al. Dynamic contrast-enhanced breast MRI for patients with BI-RADS 3-5 microcalcifications detected by digital mammography. Chin. J. Med Imaging Technol. 2009;25(1):89-92.
890 Ricart Selma V, Camps Herrero J, Martinez Rubio C, et al. Diabetic mastopathy: clinical presentation, imaging and histologic findings, and treatment. Radiologia. Jul–Aug. 2011;53(4):349-54. [pmid: 21530989].
891 Ruvalcaba Limon E, Espejo Fonseca R, Bautista Pina V, et al. Radiological control intraoperatory of a surgical piece in non palpable breast lesions. Ginecol Obstet Mex. Sep. 2009;77(9):407-18. [pmid: 19899430].
892 Salem A, Debabria H, Mehiri S, et al. Retrospective results of ultrasonographically-guided biopsy the breast cancer screening program of the Ariana area of Tunisia. Tunis Med. Jul. 2009;87(7):463-70. [pmid: 20063681].
893 Schulz-Wendtland R, Adamietz B, Meier-Meitinger M, et al. Ultrasound-guided core cut biopsy: 15 years’ follow-up: Sonografisch gezielte Stanzbiopsie: 15 Jahre Follow-up. Geburtshilfe Frauenheilkd. 2010;70(6):478-82.
894 Semiglazov VV, Semiglazov VF, Ermchenkova AM. Minimal breast carcinomas. Vopr Onkol. 2011;57(6):702-6. [pmid: 22416384].
895 Shi SH, Deng YC, Li XJ. Ultrasound-guided mammotome biopsy in diagnosis and management of single intraductal breast papilloma. J. Pract Oncol. 2012;27(4):390-2.
896 Siegmann KC, Moron HU, Baur A, et al. Diagnostic value of a breast MRI score for the prediction of malignancy of breast lesions detected solely with MRI. Rofo. Jun. 2009;181(6):556-63. [pmid: 19452398].
897 Stoblen F, Landt S, Koninger A, et al. Detection of microcalcifications by high-resolution B-mode sonography in patients with BI-RADS 4a lesions. Gynakol Geburtshilfliche Rundsch. 2009;49(4):292-8. [pmid: 20530944].
898 Su KL, Xu HB, Hu ZJ, et al. Vacuum-assisted biopsy and wire localization for the diagnosis of non-palpable breast lesions. Zhonghua Zhong Liu Za Zhi. Jun. 2010;32(6):472-5. [pmid: 20819495].
899 Traore B, Eric Douanla D, Diallo Y, et al. Problems in the management of breast cancers diagnosed post-surgery in the unit of surgical oncology, teaching hospital Donka, Conakry (Guinea): Problematique de la prise en charge des cancers du sein de << diagnostic postoperatoire >> a l’unite de chirurgie oncologique, CHU de Donka, Conakry (Guinee). J. Afr. Cancer. 2010;2(3):140-5.
900 Uehara M. Breast surgery and biopsy in anticoagulated patients. Nihon Rinsho. Sep. 2012;70(Suppl 7):706-9. [pmid: 23350490].
901 Uhara M, Matsuda K, Shimojyo Y, et al. Comparison of two HER-2 FISH kits on formalin-fixed paraffin-embedded tissues: signal detection and simple procedure. Rinsho Byori. Jan. 2010;58(1):25-9. [pmid: 20169940].
902 Utzschneider S, Weber P, Fottner A, et al. Prognosis-adapted surgical management of bone metastases. Orthopade. Apr. 10. 2009;38(4):308-12. 14. 5. [pmid: 19296081].
903 Wang Q, Zhu CX, Zhang AQ, et al. Clinical and pathological analysis of breast cancer with false-negative mammogram. Chin. J. Cancer Prev Treat. 2009;16(2):138-40.
904 LaJ-CaFaX-LaZaW-MaaZa X-J. Analysis of 278 breast biopsy cases guided by mammography. Cancer Res Clin.
905 Xu J, Wang Q, Xia J, et al. Primary efficacy of physical examination combined with ultragraphy and complemented with mammography for breast cancer screening in 280 thousand Chinese women. European Journal of Cancer. 2013;49:S322-S3.
906 Juan Xu, et al. Complement the X-ray and ultrasonic examination mammography for breast cancer screening mode preliminary application evaluation. Chinese Journal of Cancer. 2013.
907 Yan L, Qiang S, Wei-Xuan Z. Role of fine needle aspiration cytology in surgical treatment of breast cancer. Zhongguo Yi Xue Ke Xue Yuan Xue Bao. Feb. 2011;33(1):80-2. [pmid: 21375944].
908 Ye JM, Xu L, Wang DM, et al. Prospective study on the role of MRI and B ultrasonography in evaluating the tumor response to neoadjuvant chemotherapy in breast cancer. Zhonghua Wai Ke Za Zhi. Mar. 1. 2009;47(5):349-52. [pmid: 19595011].
909 Yin CF, Zhao HJ, Gao WR. Diagnostic value of three-dimensional stereotactic localization for nonpalpable breast lesions. Chin. J. Med Imaging Technol. 2010;26(8):1492-4.
910 Yin HF, Wang YH, Qin XQ, et al. Effect of neoadjuvant chemotherapy on histologic grade and expression of biological markers in breast cancer. Zhonghua Zhong Liu Za Zhi. Nov. 2009;31(11):858-62. [pmid: 20137353].
911 Zhang Y, Tang Y, Bai L, et al. Clinical significance of ultrasound and needle biopsy in diagnosis of breast cancer with liver metastasis. Chin. J. Cancer Prev Treat. 2010;17(2):142-4.
912 Zhao HJ, Yin CF, Zhao AL. Comparison of two-dimensional and three-dimensional X-ray guided wire localization breast biopsy. Chin. J. Intervent Imaging Ther. 2011;8(4):307-9.
913 Zhao JH, Ding J, Xu SB, et al. Comparison of diagnosis value between 18F-FDG PET/CT and MRI in breast cancer. J. Jilin Univ. Med Ed. 2011;37(4):746-9.
914 Zhou YJ, Ying M, He YJ, et al. Analysis of associations between molecular subtypes and responses to neoadjuvant chemotherapy in primary breast cancer patients. Zhonghua Yi Xue Za Zhi. Jun. 11. 2013;93(22):1711-5. [pmid: 24124677].
915 Abbas H, Imran S, Waris NA, et al. Importance of physical examination in early detection of lump in breast in women of different age groups. J Ayub Med Coll Abbottabad. Apr–Jun. 2010;22(2):79-82. [pmid: 21702273].
916 Abdel-Hadi M, Abdel-Hamid GF, Abdel-Razek N, et al. Should fine-needle aspiration cytology be the first choice diagnostic modality for assessment of all nonpalpable breast lesions? The experience of a breast cancer screening center in Alexandria, Egypt. Diagn Cytopathol. Dec. 2010;38(12):880-9. [pmid: 20049973].
917 Adamietz BR, Kahmann L, Fasching PA, et al. Differentiation between phyllodes tumor and fibroadenoma using real-time elastography. Ultraschall Med. Dec. 2011;32(Suppl 2):E75-9. [pmid: 22194044].
918 Adibelli ZH, Ergenc R, Oztekin O, et al. Observer Variability of the Breast Imaging Reporting and Data System (BI-RADS) Lexicon for Mammography. Breast Care (Basel). Mar. 2010;5(1):11-6. [pmid: 22619635].
919 Adler DD, Riba MB, Eggly S. Breaking bad news in the breast imaging setting. Acad Radiol. Feb. 2009;16(2):130-5. [pmid: 19124097].
920 Aellig A, Maillard M, Phavorin A, et al. The energy metabolism of the leukocyte. VIII. The determination of the concentration of the coenzymes NAD, NADH, NADP and NADPH in polymorphonuclear leukocytes at rest and after incubation by enzymatic cycling. Enzyme. 1977;22(3):196-206. [pmid: 16746].
921 Al-Attar MA, Michell MJ, Ralleigh G, et al. The impact of image guided needle biopsy on the outcome of mammographically detected indeterminate microcalcification. Breast. Oct. 2006;15(5):635-9. [pmid: 16488148].
922 Albert US, Duda V, Hadji P, et al. Imprint cytology of core needle biopsy specimens of breast lesions. A rapid approach to detecting malignancies, with comparison of cytologic and histopathologic analyses of 173 cases. Acta Cytol. Jan–Feb. 2000;44(1):57-62. [pmid: 10667161].
923 Al-Hallaq HA, Mell LK, Bradley JA, et al. Magnetic resonance imaging identifies multifocal and multicentric disease in breast cancer patients who are eligible for partial breast irradiation. Cancer. Nov. 1. 2008;113(9):2408-14. [pmid: 18823018].
924 Al-Harethee WA, Kalles V, Papapanagiotou I, et al. Thermal damage of the specimen during breast biopsy with the use of the Breast Lesion Excision System: does it affect diagnosis?. Breast Cancer. 2013. Mar. 16. [pmid: 23504263].
925 Alimoglu E, Bayraktar SD, Bozkurt S, et al. Follow-up versus tissue diagnosis in BI-RADS category 3 solid breast lesions at US: a cost-consequence analysis. Diagn Interv Radiol. Jan–Feb. 2012;18(1):3-10. [pmid: 21997885].
926 Al-Rikabi A, Husain S. Increasing prevalence of breast cancer among Saudi patients attending a tertiary referral hospital: a retrospective epidemiologic study. Croat Med J. Jun. 2012;53(3):239-43. [pmid: 22661137].
927 Al-Sobhi SS, Helvie MA, Pass HA, et al. Extent of lumpectomy for breast cancer after diagnosis by stereotactic core versus wire localization biopsy. Ann Surg Oncol. 1999;6(4):330-5. [pmid: 10379852].
928 Anania G, Bazzocchi M, di Loreto C, et al. Percutaneous large core needle biopsy versus surgical biopsy in the diagnosis of breast lesions. Int Surg. Jan–Mar. 1997;82(1):52-5. [pmid: 9189803].
929 Andersen SB, Vejborg I, von Euler-Chelpin M. Participation behaviour following a false positive test in the Copenhagen mammography screening programme. Acta Oncol. 2008;47(4):550-5. [pmid: 18465321].
930 Andreu FJ, Sentis M, Castaner E, et al. The impact of stereotactic large-core needle biopsy in the treatment of patients with nonpalpable breast lesions: a study of diagnostic accuracy in 510 consecutive cases. Eur Radiol. 1998;8(8):1468-74. [pmid: 9853239].
931 Arentz C, Baxter K, Boneti C, et al. Ten-year experience with hematoma-directed ultrasound-guided (HUG) breast lumpectomy. Ann Surg Oncol. Oct. 2010;17(Suppl 3):378-83. [pmid: 20853061].
932 Ariyarathenam AV, Currie R, Cooper MJ, et al. Impact of age extension to include 47–49 year old women on the workload of the surgical department of a single Breast Cancer Screening Unit--The first non-randomized experience in UK. Int J Surg. 2013;11(7):535-7. [pmid: 23684821].
933 Arleo EK, Dashevsky BZ, Reichman M, et al. Screening mammography for women in their 40s: a retrospective study of the potential impact of the U.S. Preventive Service Task Force’s 2009 breast cancer screening recommendations. AJR Am J Roentgenol. Dec. 2013;201(6):1401-6. [pmid: 24261383].
934 Arora N, Martins D, Ruggerio D, et al. Effectiveness of a noninvasive digital infrared thermal imaging system in the detection of breast cancer. Am J Surg. Oct. 2008;196(4):523-6. [pmid: 18809055].
935 Arrangoiz R, Garand S, Slomski C, et al. What is the diagnostic accuracy of hypocellular fine needle aspiration of the breast in the context of an otherwise negative triple screen. Int J Oncol. 2009;6(1).
936 Ashbeck EL, Rosenberg RD, Stauber PM, et al. Benign breast biopsy diagnosis and subsequent risk of breast cancer. Cancer Epidemiol Biomarkers Prev. Mar. 2007;16(3):467-72. [pmid: 17337650].
937 Aslam HM, Saleem S, Shaikh HA, et al. Clinico- pathological profile of patients with breast diseases. Diagn Pathol. 2013;8:77. [pmid: 23659667].
938 Awad FM. Role of supersonic shear wave imaging quantitative elastography (SSI) in differentiating benign and malignant solid breast masses. The Egyptian Journal of Radiology and Nuclear Medicine. 2013;44(3):681-5.
939 Ballesio L, Maggi C, Savelli S, et al. Role of breast magnetic resonance imaging (MRI) in patients with unilateral nipple discharge: preliminary study. Radiol Med. Mar. 2008;113(2):249-64. [pmid: 18386126].
940 Ballo MS, Sneige N. Can core needle biopsy replace fine-needle aspiration cytology in the diagnosis of palpable breast carcinoma. A comparative study of 124 women. Cancer. Aug. 15. 1996;78(4):773-7. [pmid: 8756371].
941 Baltzer PA, Yang F, Dietzel M, et al. Sensitivity and specificity of unilateral edema on T2w-TSE sequences in MR-Mammography considering 974 histologically verified lesions. Breast J. May–Jun. 2010;16(3):233-9. [pmid: 20565468].
942 Barman I, Dingari NC, Saha A, et al. Application of Raman spectroscopy to identify microcalcifications and underlying breast lesions at stereotactic core needle biopsy. Cancer Res. Jun. 1. 2013;73(11):3206-15. [pmid: 23729641].
943 Barr RG. Real-time ultrasound elasticity of the breast: initial clinical results. Ultrasound Q. Jun. 2010;26(2):61-6. [pmid: 20498561].
944 Barr RG, Lackey AE. The utility of the“ bull’s-eye” artifact on breast elasticity imaging in reducing breast lesion biopsy rate. Ultrasound Q. 2011;27(3):151-5. [pmid: 21873851].
945 Barra Ade A, Gobbi H, de LRCA, et al. A comparision of aspiration cytology and core needle biopsy according to tumor size of suspicious breast lesions. Diagn Cytopathol. Jan. 2008;36(1):26-31. [pmid: 18064684].
946 Battaglia TA, Howard MB, Kavanah M, et al. The addition of internists to a breast health program. Breast J. Jan–Feb. 2012;18(1):58-64. [pmid: 22098389].
947 Beattie A. Detecting breast cancer in a general practice - Like finding needles in a haystack?. Aust Fam Physician. Dec. 2009;38(12):1003-6. [pmid: 20369155].
948 Beckmann KR, Farshid G, Roder DM, et al. Impact of hormone replacement therapy use on mammographic screening outcomes. Cancer Causes Control. Jul. 2013;24(7):1417-26. [pmid: 23649232].
949 Bent CK, Bassett LW, D’Orsi CJ, et al. The positive predictive value of BI-RADS microcalcification descriptors and final assessment categories. AJR Am J Roentgenol. May. 2010;194(5):1378-83. [pmid: 20410428].
950 Berg WA, Jaeger B, Campassi C, et al. Predictive value of specimen radiography for core needle biopsy of noncalcified breast masses. AJR Am J Roentgenol. Dec. 1998;171(6):1671-8. [pmid: 9843311].
951 Berna JD, Nieves FJ, Romero T, et al. A multimodality approach to the diagnosis of breast hamartomas with atypical mammographic appearance. Breast J. Jan–Feb. 2001;7(1):2-7. [pmid: 11348408].
952 Berna-Serna JD, Torres-Ales C, Berna-Mestre JD, et al. Role of Galactography in the Early Diagnosis of Breast Cancer. Breast Care. 2013;8(2):122-6. [pmid: 24419050].
953 Berube M, Curpen B, Ugolini P, et al. Level of suspicion of a mammographic lesion: use of features defined by BI-RADS lexicon and correlation with large-core breast biopsy. Can Assoc Radiol J. Aug. 1998;49(4):223-8. [pmid: 9709675].
954 Bianchi S, Caini S, Renne G, et al. Positive predictive value for malignancy on surgical excision of breast lesions of uncertain malignant potential (B3) diagnosed by stereotactic vacuum-assisted needle core biopsy (VANCB): a large multi-institutional study in Italy. Breast. Jun. 2011;20(3):264-70. [pmid: 21208804].
955 Bleznak AD, Magaram D. Surgical biopsy techniques for mammographically detected abnormalities. The Breast Journal. 1998;4(6):426-9.
956 Boba M, Koltun U, Bobek-Billewicz B, et al. False-negative results of breast core needle biopsies - retrospective analysis of 988 biopsies. Pol J Radiol. Jan. 2011;76(1):25-9. [pmid: 22802813].
957 Bodai BI, Boyd B, Brown L, et al. Total cost comparison of 2 biopsy methods for nonpalpable breast lesions. Am J Manag Care. May. 2001;7(5):527-38. [pmid: 11388132].
958 Bonifacino A, Petrocelli V, Pisani T, et al. Accuracy rates of US-guided vacuum-assisted breast biopsy. Anticancer Res. May–Jun. 2005;25(3c):2465-70. [pmid: 16080477].
959 Bowers GJ, Getz JB, Roettger RH, et al. Nonpalpable breast lesions: association of mammographic abnormalities with diagnosis after needle-directed biopsy. South Med J. Jul. 1993;86(7):748-52. [pmid: 8391719].
960 Brem RF, Floerke AC, Rapelyea JA, et al. Breast-specific gamma imaging as an adjunct imaging modality for the diagnosis of breast cancer. Radiology. Jun. 2008;247(3):651-7. [pmid: 18487533].
961 Brenner RJ, Sickles EA. Surveillance mammography and stereotactic core breast biopsy for probably benign lesions: a cost comparison analysis. Acad Radiol. Jun. 1997;4(6):419-25. [pmid: 9189199].
962 Breslin TM, Caughran J, Pettinga J, et al. Improving breast cancer care through a regional quality collaborative. Surgery. Oct. 2011;150(4):635-42. [pmid: 22000174].
963 Britton P, McCann J. Needle biopsy in the NHS breast screening programme 1996/97: how much and how accurate?. The Breast. 1999;8(1):5-11.
964 Brown ML, Houn F, Sickles EA, et al. Screening mammography in community practice: positive predictive value of abnormal findings and yield of follow-up diagnostic procedures. AJR Am J Roentgenol. Dec. 1995;165(6):1373-7. [pmid: 7484568].
965 Buijs-van der Woude T, Verkooijen HM, Pijnappel RM, et al. Cost comparison between stereotactic large-core-needle biopsy versus surgical excision biopsy in The Netherlands. Eur J Cancer. Sep. 2001;37(14):1736-45. [pmid: 11549426].
966 Bulte JP, Polman L, Schlooz-Vries M, et al. One-day core needle biopsy in a breast clinic: 4 years experience. Breast Cancer Res Treat. Jan. 2013;137(2):609-16. [pmid: 23239152].
967 Bundred SM, Zhou J, Whiteside S, et al. Impact of full-field digital mammography on pre-operative diagnosis and surgical treatment of mammographic microcalcification. Breast Cancer Res Treat. Jan. 2014;143(2):359-66. [pmid: 24318468].
968 Burbank F. Stereotactic breast biopsy: comparison of 14- and 11-gauge Mammotome probe performance and complication rates. Am Surg. Nov. 1997;63(11):988-95. [pmid: 9358788].
969 Burbank F, Forcier N. Tissue marking clip for stereotactic breast biopsy: initial placement accuracy, long-term stability, and usefulness as a guide for wire localization. Radiology. Nov. 1997;205(2):407-15. [pmid: 9356621].
970 Burbank F, Parker SH, Fogarty TJ. Stereotactic breast biopsy: improved tissue harvesting with the Mammotome. Am Surg. Sep. 1996;62(9):738-44. [pmid: 8751765].
971 Burnside ES, Rubin DL, Fine JP, et al. Bayesian network to predict breast cancer risk of mammographic microcalcifications and reduce number of benign biopsy results: initial experience. Radiology. Sep. 2006;240(3):666-73. [pmid: 16926323].
972 Caines JS, Schaller GH, Iles SE, et al. Ten years of breast screening in the Nova Scotia Breast Screening Program, 1991–2001. experience: use of an adaptable stereotactic device in the diagnosis of screening-detected abnormalities. Can Assoc Radiol J. Apr. 2005;56(2):82-93. [pmid: 15957275].
973 Calhoun K, Giuliano A, Brenner RJ. Intraoperative loss of core biopsy clips: clinical implications. AJR Am J Roentgenol. Mar. 2008;190(3):W196-200. [pmid: 18287412].
974 Candelaria R, Fornage BD. Second-look US examination of MR-detected breast lesions. J Clin Ultrasound. Mar–Apr. 2011;39(3):115-21. [pmid: 21387324].
975 Cangiarella J, Gross J, Symmans WF, et al. The incidence of positive margins with breast conserving therapy following mammotome biopsy for microcalcification. J Surg Oncol. Aug. 2000;74(4):263-6. [pmid: 10962457].
976 Cangiarella J, Mercado CL, Symmans WF, et al. Stereotaxic aspiration biopsy in the evaluation of mammographically detected clustered microcalcification. Cancer. Aug. 25. 1998;84(4):226-30. [pmid: 9723597].
977 Cangiarella JF, Waisman J, Weg N, et al. The Use of Stereotaxic Core Biopsy and Stereotaxic Aspiration Biopsy as Diagnostic Tools in the Evaluation of Mammary Calcification. Breast J. Nov. 2000;6(6):366-72. [pmid: 11348394].
978 Carbonaro LA, Verardi N, Di Leo G, et al. Handling a high relaxivity contrast material for dynamic breast MR imaging using higher thresholds for the initial enhancement. Invest Radiol. Mar. 2010;45(3):114-20. [pmid: 20065856].
979 Carney PA, Parikh J, Sickles EA, et al. Diagnostic mammography: identifying minimally acceptable interpretive performance criteria. Radiology. May. 2013;267(2):359-67. [pmid: 23297329].
980 Carty NJ, Ravichandran D, Carter C, et al. Randomized comparison of fine-needle aspiration cytology and Biopty-Cut needle biopsy after unsatisfactory initial cytology of discrete breast lesions. Br J Surg. Sep. 1994;81(9):1313-4. [pmid: 7953396].
981 Chan KKK, Lui CY, Chu T, et al. Stratifying risk for malignancy using microcalcification descriptors from the breast imaging reporting and data system 4th edition: Experience in a single centre in Hong Kong. J HK Coll Radiol. 2009;11(4):149-53.
982 Chang JM, Moon WK, Cho N, et al. Breast mass evaluation: factors influencing the quality of US elastography. Radiology. Apr. 2011;259(1):59-64. [pmid: 21330569].
983 Chang JM, Moon WK, Cho N, et al. Breast cancers initially detected by hand-held ultrasound: detection performance of radiologists using automated breast ultrasound data. Acta Radiol. Feb. 1. 2011;52(1):8-14. [pmid: 21498319].
984 Chang JM, Moon WK, Cho N, et al. Radiologists’ performance in the detection of benign and malignant masses with 3D automated breast ultrasound (ABUS). Eur J Radiol. Apr. 2011;78(1):99-103. [pmid: 21330080].
985 Chang JM, Moon WK, Cho N, et al. Clinical application of shear wave elastography (SWE) in the diagnosis of benign and malignant breast diseases. Breast Cancer Res Treat. Aug. 2011;129(1):89-97. [pmid: 21681447].
986 Chare MJ, Flowers CI, O’Brien CJ, et al. Image-guided core biopsy in patients with breast disease. Br J Surg. Oct. 1996;83(10):1415-6. [pmid: 8944459].
987 Chasteen ND, White LK, Campbell RF. Metal site conformational states of vanadyl(IV) human serotransferrin complexes. Biochemistry. Feb. 8. 1977;16(3):363-5. [pmid: 13814].
988 Cheng J, Qiu S, Raju U, et al. Benign breast disease heterogeneity: association with histopathology, age, and ethnicity. Breast Cancer Res Treat. Sep. 2008;111(2):289-96. [pmid: 17917807].
989 Cheng YC, Wu NY, Ko JS, et al. Breast cancers detected by breast MRI screening and ultrasound in asymptomatic Asian women: 8 years of experience in Taiwan. Oncology. 2012;82(2):98-107. [pmid: 22328009].
990 Cheung KL, Wong AW, Parker H, et al. Pathological features of primary breast cancer in the elderly based on needle core biopsies--a large series from a single centre. Crit Rev Oncol Hematol. Sep. 2008;67(3):263-7. [pmid: 18524618].
991 Cheung YC, Wan YL, Chen SC, et al. Sonographic evaluation of mammographically detected microcalcifications without a mass prior to stereotactic core needle biopsy. J Clin Ultrasound. Jul–Aug. 2002;30(6):323-31. [pmid: 12116093].
992 Chlebowski RT, Anderson G, Pettinger M, et al. Estrogen plus progestin and breast cancer detection by means of mammography and breast biopsy. Arch Intern Med. Feb. 25. 2008;168(4):370-7. quiz 45. [pmid: 18299491].
993 Cho N, Moon WK. Digital mammography-guided skin marking for sonographically guided biopsy of suspicious microcalcifications. AJR Am J Roentgenol. Mar. 2009;192(3):W132-6. [pmid: 19234241].
994 Cho N, Moon WK, Cha JH, et al. Ultrasound-guided vacuum-assisted biopsy of microcalcifications detected at screening mammography. Acta Radiol. Jul. 2009;50(6):602-9. [pmid: 19449232].
995 Cho N, Moon WK, Cha JH, et al. Sonographically guided core biopsy of the breast: comparison of 14-gauge automated gun and 11-gauge directional vacuum-assisted biopsy methods. Korean J Radiol. Apr–Jun. 2005;6(2):102-9. [pmid: 15968149].
996 Cho N, Moon WK, Chang JM, et al. Aliasing artifact depicted on ultrasound (US)-elastography for breast cystic lesions mimicking solid masses. Acta Radiol. Feb. 1. 2011;52(1):3-7. [pmid: 21498318].
997 Chu TY, Lui CY, Hung WK, et al. Localisation of occult breast lesion: a comparative analysis of hookwire and radioguided procedures. Hong Kong Med J. Oct. 2010;16(5):367-72. [pmid: 20890001].
998 Chuo CB, Corder AP. Core biopsy vs fine needle aspiration cytology in a symptomatic breast clinic. Eur J Surg Oncol. May. 2003;29(4):374-8. [pmid: 12711292].
999 Ciatto S, Del Turco MR, Marrazzo A, et al. Time trends of benign/malignant breast biopsy ratios a multicenter Italian study. Tumori. Jul–Aug. 1996;82(4):325-8. [pmid: 8890964].
1000 Clarke D, Sudhakaran N, Gateley CA. Replace fine needle aspiration cytology with automated core biopsy in the triple assessment of breast cancer. Ann R Coll Surg Engl. Mar. 2001;83(2):110-2. [pmid: 11320918].
1001 Clarke-Pearson EM, Jacobson AF, Boolbol SK, et al. Quality assurance initiative at one institution for minimally invasive breast biopsy as the initial diagnostic technique. J Am Coll Surg. Jan. 2009;208(1):75-8. [pmid: 19228506].
1002 Clifford EJ, De Vol EB, Pockaj BA, et al. Early results from a novel quality outcomes program: the American Society Of Breast Surgeons’ Mastery of Breast Surgery. Ann Surg Oncol. Oct. 2010;17(Suppl 3):233-41. [pmid: 20853039].
1003 Coldman AJ, Phillips N. False-positive screening mammograms and biopsies among women participating in a Canadian provincial breast screening program. Can J Public Health. Nov–Dec. 2012;103(6):e420-4. [pmid: 23618020].
1004 Cole EB, Toledano AY, Lundqvist M, et al. Comparison of radiologist performance with photon-counting full-field digital mammography to conventional full-field digital mammography. Acad Radiol. Aug. 2012;19(8):916-22. [pmid: 22537503].
1005 Corn CC. Review of 125 SiteSelect stereotactic large-core breast biopsy procedures. Breast J. May–Jun. 2003;9(3):147-52. [pmid: 12752621].
1006 Cornea V, Jaffer S, Bleiweiss IJ, et al. Adequate histologic sampling of breast magnetic resonance imaging-guided core needle biopsy. Arch Pathol Lab Med. Dec. 2009;133(12):1961-4. [pmid: 19961252].
1007 Corsetti V, Houssami N, Ferrari A, et al. Breast screening with ultrasound in women with mammography-negative dense breasts: evidence on incremental cancer detection and false positives, and associated cost. Eur J Cancer. Mar. 2008;44(4):539-44. [pmid: 18267357].
1008 Crotch-Harvey M, Loughran C. Combined stereotactic wide-core needle biopsy and fine-needle aspiration cytology in the assessment of impalpable mammographic abnormalities detected in a breast-screening programme. The Breast. 1996;5(1):48-9.
1009 Crowe JP Jr, Rim A, Patrick R, et al. A prospective review of the decline of excisional breast biopsy. Am J Surg. Oct. 2002;184(4):353-5. [pmid: 12383901].
1010 Crump SR, Shipp MP, McCray GG, et al. Abnormal mammogram follow-up: do community lay health advocates make a difference?. Health Promot Pract. Apr. 2008;9(2):140-8. [pmid: 18340089].
1011 Cui Y, Page DL, Lane DS, et al. Menstrual and reproductive history, postmenopausal hormone use, and risk of benign proliferative epithelial disorders of the breast: a cohort study. Breast Cancer Res Treat. Mar. 2009;114(1):113-20. [pmid: 18360772].
1012 Dahlstrom JE, Sutton S, Jain S. Histological precision of stereotactic core biopsy in diagnosis of malignant and premalignant breast lesions. Histopathology. Jun. 1996;28(6):537-41. [pmid: 8803597].
1013 Dahlstrom JE, Sutton S, Jain S. Histologic-radiologic correlation of mammographically detected microcalcification in stereotactic core biopsies. Am J Surg Pathol. Feb. 1998;22(2):256-9. [pmid: 9500229].
1014 Daly CP, Bailey JE, Klein KA, et al. Complicated breast cysts on sonography: is aspiration necessary to exclude malignancy?. Acad Radiol. May. 2008;15(5):610-7. [pmid: 18423318].
1015 Damascelli B, Frigerio LF, Lanocita R, et al. Stereotactic excisional breast biopsy performed by interventional radiologists using the advanced breast biopsy instrumentation system. Br J Radiol. Oct. 1998;71(850):1003-11. [pmid: 10211058].
1016 Damascelli B, Frigerio LF, Patelli G, et al. Stereotactic breast biopsy: en bloc excision of microcalcifications with a large-bore cannula device. AJR Am J Roentgenol. Oct. 1999;173(4):895-900. [pmid: 10511143].
1017 D’Angelo PC, Galliano DE, Rosemurgy AS. Stereotactic excisional breast biopsies utilizing the advanced breast biopsy instrumentation system. Am J Surg. Sep. 1997;174(3):297-302. [pmid: 9324141].
1018 Demir F, Donmez YC, Ozsaker E, et al. Patients’ lived experiences of excisional breast biopsy: a phenomenological study. J Clin Nurs. Mar. 2008;17(6):744-51. [pmid: 18279277].
1019 Dennison G, Anand R, Makar SH, et al. A prospective study of the use of fine-needle aspiration cytology and core biopsy in the diagnosis of breast cancer. Breast J. Nov–Dec. 2003;9(6):491-3. [pmid: 14616944].
1020 Denton ER, Ryan S, Beaconfield T, et al. Image-guided breast biopsy: analysis of pain and discomfort related to technique. Breast. Oct. 1999;8(5):257-60. [pmid: 14965740].
1021 Dershaw DD, Morris EA, Liberman L, et al. Nondiagnostic stereotaxic core breast biopsy: results of rebiopsy. Radiology. Feb. 1996;198(2):323-5. [pmid: 8596825].
1022 Destounis S, Arieno A, Morgan R, et al. Clinical experience with elasticity imaging in a community-based breast center. J Ultrasound Med. Feb. 2013;32(2):297-302. [pmid: 23341386].
1023 Destounis S, Skolny MN, Morgan R, et al. Rates of pathological underestimation for 9 and 12 gauge breast needle core biopsies at surgical excision. Breast Cancer. Jan. 2011;18(1):42-50. [pmid: 20204553].
1024 Deurloo EE, Gilhuijs KG, Kool LJS, et al. Displacement of breast tissue and needle deviations during stereotactic procedures. Invest Radiol. 2001;36(6):347-53. [pmid: 11410756].
1025 Deutscher SL, Dickerson M, Gui G, et al. Carbohydrate antigens in nipple aspirate fluid predict the presence of atypia and cancer in women requiring diagnostic breast biopsy. BMC Cancer. 2010;10:519. [pmid: 20920311].
1026 Devia A, Murray KA, Nelson EW. Stereotactic core needle biopsy and the workup of mammographic breast lesions. Arch Surg. May. 1997;132(5):512-5. discussion 5-7. [pmid: 9161394].
1027 Dietzel M, Baltzer PA, Vag T, et al. The necrosis sign in magnetic resonance-mammography: diagnostic accuracy in 1,084 histologically verified breast lesions. Breast J. Nov–Dec. 2010;16(6):603-8. [pmid: 21070437].
1028 Dillon MF, Maguire AA, McDermott EW, et al. Needle core biopsy characteristics identify patients at risk of compromised margins in breast conservation surgery. Mod Pathol. Jan. 2008;21(1):39-45. [pmid: 17948023].
1029 Dittus K, Geller B, Weaver DL, et al. Impact of mammography screening interval on breast cancer diagnosis by menopausal status and BMI. J Gen Intern Med. Nov. 2013;28(11):1454-62. [pmid: 23760741].
1030 Docktor BJ, MacGregor JH, Burrowes PW. Ultrasonographic findings 6 months after 11-gauge vacuum-assisted large-core breast biopsy. Can Assoc Radiol J. Jun. 2004;55(3):151-6. [pmid: 15237775].
1031 Donaldson LA, Cliff A, Gardiner L, et al. Surgeon-controlled ultrasound-guided core biopsies in the breast--a prospective study and a new use for surgeons in the clinic. Eur J Surg Oncol. Mar. 2003;29(2):139-42. [pmid: 12633556].
1032 Doridot V, Meunier M, El Khoury C, et al. Stereotactic radioguided surgery by siteSelect for subclinical mammographic lesions. Ann Surg Oncol. Feb. 2005;12(2):181-8. [pmid: 15827800].
1033 D’Orsi CJ, Getty DJ, Pickett RM, et al. Stereoscopic digital mammography: improved specificity and reduced rate of recall in a prospective clinical trial. Radiology. Jan. 2013;266(1):81-8. [pmid: 23150865].
1034 Dowlatshahi K, Yaremko ML, Kluskens LF, et al. Nonpalpable breast lesions: findings of stereotaxic needle-core biopsy and fine-needle aspiration cytology. Radiology. Dec. 1991;181(3):745-50. [pmid: 1947091].
1035 Doyle AJ, King AR, Miller MV, et al. Implementation of image-guided large-core needle biopsy of the breast on a limited budget. Australas Radiol. Aug. 1998;42(3):199-203. [pmid: 9727241].
1036 Doyle JM, O’Doherty A, Coffey L, et al. Can the radiologist accurately predict the adequacy of sampling when performing ultrasound-guided core biopsy of BI-RADS category 4 and 5 lesions detected on screening mammography?. Clin Radiol. Sep. 2005;60(9):999-1005. [pmid: 16124982].
1037 Duijm LE, Groenewoud JH, de Koning HJ, et al. Delayed diagnosis of breast cancer in women recalled for suspicious screening mammography. Eur J Cancer. Mar. 2009;45(5):774-81. [pmid: 19046632].
1038 Duijm LE, Groenewoud JH, Fracheboud J, et al. Utilization and cost of diagnostic imaging and biopsies following positive screening mammography in the southern breast cancer screening region of the Netherlands, 2000–2005. Eur Radiol. Nov. 2008;18(11):2390-7. [pmid: 18491102].
1039 Duijm LE, Louwman MW, Groenewoud JH, et al. Inter-observer variability in mammography screening and effect of type and number of readers on screening outcome. Br J Cancer. Mar. 24. 2009;100(6):901-7. [pmid: 19259088].
1040 Dunning K, Liedtke E, Toedter L, et al. Outpatient surgery centers draw cases away from hospitals, impact resident training volume. J Surg Educ. Nov–Dec. 2008;65(6):460-4. [pmid: 19059178].
1041 Florentine BD, Cobb CJ, Frankel K, Greaves T, Martin SE. Core needle biopsy: A useful adjunct to fine-needle aspiration in select patients with palpable breast lesions. Cancer.
1042 El Khouli RH, Macura KJ, Barker PB, et al. MRI-guided vacuum-assisted breast biopsy: a phantom and patient evaluation of targeting accuracy. J Magn Reson Imaging. Aug. 2009;30(2):424-9. [pmid: 19629977].
1043 El Khoury M, Mesurolle B, Omeroglu A, et al. Values of pathological analysis of lost tissue fragments in the vacuum canister during a vacuum-assisted stereotactic biopsy of the breast. Br J Radiol. May. 2013;86(1025):20120270. [pmid: 23520227].
1044 Elkum NB, Myles JD, Kumar P. Analyzing biological rhythms in clinical trials. Contemp Clin Trials. Sep. 2008;29(5):720-6. [pmid: 18571991].
1045 El-Sayed ME, Rakha EA, Reed J, et al. Audit of performance of needle core biopsy diagnoses of screen detected breast lesions. Eur J Cancer. Nov. 2008;44(17):2580-6. [pmid: 18632261].
1046 Elter M, Schulz-Wendtland R, Wittenberg T. The prediction of breast cancer biopsy outcomes using two CAD approaches that both emphasize an intelligible decision process. Med Phys. Nov. 2007;34(11):4164-72. [pmid: 18072480].
1047 Ertas G, Gulcur HO, Tunaci M, et al. A preliminary study on computerized lesion localization in MR mammography using 3D nMITR maps, multilayer cellular neural networks, and fuzzy c-partitioning. Med Phys. Jan. 2008;35(1):195-205. [pmid: 18293575].
1048 Eser M, Kaptanoglu L, Kement M, et al. A Challenging entity in the differential diagnosis of breast cancer: A retrospective analysis of 17 cases with granulomatous lobular mastitis: Meme kanserinin ayirici tanisinda zor bir durum: Granulomatoz lobuler mastitli 17 olgunun retrospektif analizi. J Breast Health. 2013;9(2):69-75.
1049 Evans A, Whelehan P, Thomson K, et al. Differentiating benign from malignant solid breast masses: value of shear wave elastography according to lesion stiffness combined with greyscale ultrasound according to BI-RADS classification. Br J Cancer. Jul. 10. 2012;107(2):224-9. [pmid: 22691969].
1050 Evans A, Whelehan P, Thomson K, et al. Quantitative shear wave ultrasound elastography: initial experience in solid breast masses. Breast Cancer Res. 2010;12(6):R104. [pmid: 21122101].
1051 Evans LA. Feasibility of family member presence in the OR during breast biopsy procedures. AORN J. Oct. 2008;88(4):568-86. [pmid: 18928960].
1052 Fahy BN, Bold RJ, Schneider PD, et al. Cost-benefit analysis of biopsy methods for suspicious mammographic lesions; discussion 994-5. Arch Surg. Sep. 2001;136(9):990-4. [pmid: 11529819].
1053 Fajardo LL. Cost-effectiveness of stereotaxic breast core needle biopsy. Acad Radiol. Apr. 1996;3(Suppl 1):S21-3. [pmid: 8796501].
1054 Fajardo LL, Bird RE, Herman CR, et al. Placement of endovascular embolization microcoils to localize the site of breast lesions removed at stereotactic core biopsy. Radiology. Jan. 1998;206(1):275-8. [pmid: 9423683].
1055 Farshid G, Pieterse S. Core imprint cytology of screen-detected breast lesions is predictive of the histologic results. Cancer. Jun. 25. 2006;108(3):150-6. [pmid: 16634070].
1056 Farshid G, Rush G. The use of fine-needle aspiration cytology and core biopsy in the assessment of highly suspicious mammographic microcalcifications: analysis of outcome for 182 lesions detected in the setting of a population-based breast cancer screening program. Cancer. Dec. 25. 2003;99(6):357-64. [pmid: 14681944].
1057 Faulkner K, McCormack S, Bennison K. A retrospective analysis of digital stereotaxis in breast screening. Br J Radiol. Jul. 2007;80(955):563-8. [pmid: 17621605].
1058 Feeley L, Kiernan D, Mooney T, et al. Digital mammography in a screening programme and its implications for pathology: a comparative study. J Clin Pathol. Mar. 2011;64(3):215-9. [pmid: 21177749].
1059 Fenton JJ, Xing G, Elmore JG, et al. Short-term outcomes of screening mammography using computer-aided detection: a population-based study of medicare enrollees. Ann Intern Med. Apr. 16. 2013;158(8):580-7. [pmid: 23588746].
1060 Feoli F, Paesmans M, Van Eeckhout P. Fine needle aspiration cytology of the breast: impact of experience on accuracy, using standardized cytologic criteria. Acta Cytol. Mar–Apr. 2008;52(2):145-51. [pmid: 18499986].
1061 Ferguson J, Chamberlain P, Cramer HM, et al. ER, PR, and Her2 immunocytochemistry on cell-transferred cytologic smears of primary and metastatic breast carcinomas: a comparison study with formalin-fixed cell blocks and surgical biopsies. Diagn Cytopathol. Jul. 2013;41(7):575-81. [pmid: 22807465].
1062 Ferzli GS, Hurwitz JB, Puza T, et al. Advanced breast cancer biopsy instrumentation: a critique. J Am Coll Surg. Aug. 1997;185(2):145-51. [pmid: 9249081].
1063 Ferzli GS, Puza T, Vanvorst-Bilotti S, et al. Breast Biopsies with ABBI(R): Experience with 183 Attempted Biopsies. Breast J. Jan. 1999;5(1):26-8. [pmid: 11348252].
1064 Fiaschetti V, Salimbeni C, Gaspari E, et al. The role of second-look ultrasound of BIRADS-3 mammary lesions detected by breast MR imaging. Eur J Radiol. Nov. 2012;81(11):3178-84. [pmid: 22417393].
1065 Fine RE, Boyd BA. Stereotactic breast biopsy: a practical approach. Am Surg. Feb. 1996;62(2):96-102. [pmid: 8554199].
1066 Fine RE, Boyd BA, Whitworth PW, et al. Percutaneous removal of benign breast masses using a vacuum-assisted hand-held device with ultrasound guidance. Am J Surg. Oct. 2002;184(4):332-6. [pmid: 12383895].
1067 Fine RE, Israel PZ, Walker LC, et al. A prospective study of the removal rate of imaged breast lesions by an 11-gauge vacuum-assisted biopsy probe system. Am J Surg. Oct. 2001;182(4):335-40. [pmid: 11720666].
1068 Fitzpatrick P, Fleming P, O’Neill S, et al. False-positive mammographic screening: factors influencing re-attendance over a decade of screening. J Med Screen. 2011;18(1):30-3. [pmid: 21536814].
1069 Fleury EF, Rinaldi JF, Piato S, et al. Appearance of breast masses on sonoelastography with special focus on the diagnosis of fibroadenomas. Eur Radiol. Jun. 2009;19(6):1337-46. [pmid: 19159934].
1070 Fornasa F, Pinali L, Gasparini A, et al. Diffusion-weighted magnetic resonance imaging in focal breast lesions: analysis of 78 cases with pathological correlation. Radiol Med. Mar. 2011;116(2):264-75. [pmid: 21076884].
1071 Fournier LS, Vanel D, Athanasiou A, et al. Dynamic optical breast imaging: a novel technique to detect and characterize tumor vessels. Eur J Radiol. Jan. 2009;69(1):43-9. [pmid: 18829193].
1072 Frayne J, Sterrett GF, Harvey J, et al. Stereotactic 14 gauge core-biopsy of the breast: results from 101 patients. Aust N Z J Surg. Sep. 1996;66(9):585-91. [pmid: 8859155].
1073 Freeman S. One-stop clinic can diagnose suspect lesions in a day. Oncol Rep. 2010;(SEPTEMBER–OCTOBER):14-5.
1074 Friedlander LC, Roth SO, Gavenonis SC. Results of MR imaging screening for breast cancer in high-risk patients with lobular carcinoma in situ. Radiology. Nov. 2011;261(2):421-7. [pmid: 21900618].
1075 Fu CY, Hsu HH, Yu JC, et al. Influence of age on PPV of sonographic BI-RADS categories 3, 4, and 5. Ultraschall Med. Jan. 2011;32(Suppl 1):S8-13. [pmid: 20603785].
1076 Gajdos C, Levy M, Herman Z, et al. Complete removal of nonpalpable breast malignancies with a stereotactic percutaneous vacuum-assisted biopsy instrument. J Am Coll Surg. Sep. 1999;189(3):237-40. [pmid: 10472922].
1077 Gala I, Fisher P, Hermann GA. Usefulness of Telfa pads in the histologic assessment of stereotactic-guided breast biopsy specimens. Mod Pathol. May. 1999;12(5):553-7. [pmid: 10349996].
1078 Gallagher R, Schafer G, Redick M, et al. Microcalcifications of the breast: a mammographic-histologic correlation study using a newly designed Path/Rad Tissue Tray. Ann Diagn Pathol. Jun. 2012;16(3):196-201. [pmid: 22225905].
1079 Gan FY, Wettlaufer JR, Lundell AL. Breast imaging in a military setting: a comparison with civilian breast imaging. Mil Med. May. 2004;169(5):361-7. [pmid: 15186000].
1080 Geller BM, Oppenheimer RG, Mickey RM, et al. Patient perceptions of breast biopsy procedures for screen-detected lesions. Am J Obstet Gynecol. Apr. 2004;190(4):1063-9. [pmid: 15118643].
1081 Gentry CL, Henry CA. Stereotactic Percutaneous Breast Biopsy: A Comparative Analysis Between Surgeon and Radiologist. Breast J. Mar. 1999;5(2):101-4. [pmid: 11348267].
1082 Ghosh K, Melton LJ 3rd, Suman VJ, et al. Breast biopsy utilization: a population-based study. Arch Intern Med. Jul. 25. 2005;165(14):1593-8. [pmid: 16043676].
1083 Giordano L, Giorgi D, Piccini P, et al. Time trends of process and impact indicators in Italian breast screening programmes: 1998–2007. Epidemiol Prev. May–Jun. 2009;33(3 Suppl 2):29-39. [pmid: 19776485].
1084 Giordano L, Giorgi D, Piccini P, et al. Time trends of process and impact indicators in Italian breast screening programmes--1996–2005. Epidemiol Prev. Mar–Apr. 2008;32(2 Suppl 1):23-36. [pmid: 18770993].
1085 Giordano L, Giorgi D, Ventura L, et al. Time trends of process and impact indicators in Italian breast screening programmes: 1998–2008. Epidemiol Prev. Sep–Dec. 2010;34(5–6 Suppl 4):27-34. [pmid: 21220835].
1086 Girardi V, Tonegutti M, Ciatto S, et al. Breast ultrasound in 22,131 asymptomatic women with negative mammography. Breast. Oct. 2013;22(5):806-9. [pmid: 23558244].
1087 Gittleman MA. Single-step ultrasound localization of breast lesions and lumpectomy procedure. Am J Surg. Oct. 2003;186(4):386-90. [pmid: 14553856].
1088 Goldman LE, Walker R, Hubbard R, et al. Timeliness of abnormal screening and diagnostic mammography follow-up at facilities serving vulnerable women. Med Care. Apr. 2013;51(4):307-14. [pmid: 23358386].
1089 Goldman LE, Walker R, Miglioretti DL, et al. Facility characteristics do not explain higher false-positive rates in diagnostic mammography at facilities serving vulnerable women. Med Care. Mar. 2012;50(3):210-6. [pmid: 22186768].
1090 Golub RM, Bennett CL, Stinson T, et al. Cost minimization study of image-guided core biopsy versus surgical excisional biopsy for women with abnormal mammograms. Journal of clinical oncology. 2004;22(12):2430-7. [pmid: 15197205].
1091 Goodman KA, Birdwell RL, Ikeda DM. Compliance with recommended follow-up after percutaneous breast core biopsy. AJR Am J Roentgenol. Jan. 1998;170(1):89-92. [pmid: 9423606].
1092 Gray RE, Benson GW, Lustig DD. Stereotactic breast biopsy: experience in a community setting. J Miss State Med Assoc. Jan. 1999;40(1):3-7. [pmid: 9919043].
1093 Grimes MM, Karageorge LS, Hogge JP. Does exhaustive search for microcalcifications improve diagnostic yield in stereotactic core needle breast biopsies?. Mod Pathol. Apr. 2001;14(4):350-3. [pmid: 11301352].
1094 Groenewoud JH, Pijnappel RM, van den Akker-Van Marle ME, et al. Cost-effectiveness of stereotactic large-core needle biopsy for nonpalpable breast lesions compared to open-breast biopsy. Br J Cancer. Jan. 26. 2004;90(2):383-92. [pmid: 14735181].
1095 Gruber S, Debski BK, Pinker K, et al. Three-dimensional proton MR spectroscopic imaging at 3 T for the differentiation of benign and malignant breast lesions. Radiology. Dec. 2011;261(3):752-61. [pmid: 21998046].
1096 Gufler H, Wagner S, Franke FE. The interior structure of breast microcalcifications assessed with micro computed tomography. Acta Radiol. Jul. 1. 2011;52(6):592-6. [pmid: 21498282].
1097 Gumus H, Gumus M, Devalia H, et al. Causes of failure in removing calcium in microcalcification-only lesions using 11-gauge stereotactic vacuum-assisted breast biopsy. Diagn Interv Radiol. Jul–Aug. 2012;18(4):354-9. [pmid: 22477646].
1098 Gumus H, Gumus M, Mills P, et al. Clinically palpable breast abnormalities with normal imaging: is clinically guided biopsy still required?. Clin Radiol. May. 2012;67(5):437-40. [pmid: 22119297].
1099 Gumus H, Mills P, Fish D, et al. Breast microcalcification: diagnostic value of calcified and non-calcified cores on specimen radiographs. Breast J. Mar–Apr. 2013;19(2):156-61. [pmid: 23294155].
1100 Gur D, Wallace LP, Klym AH, et al. Trends in recall, biopsy, and positive biopsy rates for screening mammography in an academic practice. Radiology. May. 2005;235(2):396-401. [pmid: 15770039].
1101 Gurel K, Karabay O, Gurel S, et al. Does prebiopsy, nonsterile ultrasonography gel affect biopsy-site asepsis?. Cardiovasc Intervent Radiol. Jan–Feb. 2008;31(1):131-4. [pmid: 17978849].
1102 Gutwein LG, Ang DN, Liu H, et al. Utilization of minimally invasive breast biopsy for the evaluation of suspicious breast lesions. Am J Surg. Aug. 2011;202(2):127-32. [pmid: 21295284].
1103 Gweon HM, Youk JH, Son EJ, et al. Visually assessed colour overlay features in shear-wave elastography for breast masses: quantification and diagnostic performance. Eur Radiol. Mar. 2013;23(3):658-63. [pmid: 22976918].
1104 Haj M, Kniaz D, Eitan A, et al. Three years of experience with advanced breast biopsy instrumentation (ABBI). Breast J. Sep–Oct. 2002;8(5):275-80. [pmid: 12199754].
1105 Hamilton LJ, Cornford EJ, Maxwell AJ. A survey of current UK practice regarding the biopsy of clinically and radiologically benign breast masses in young women. Clin Radiol. Aug. 2011;66(8):738-41. [pmid: 21513922].
1106 Hann LE, Liberman L, Dershaw DD, et al. Mammography immediately after stereotaxic breast biopsy: is it necessary?. AJR Am J Roentgenol. Jul. 1995;165(1):59-62. [pmid: 7785633].
1107 Hanna WC, Demyttenaere SV, Ferri LE, et al. The use of stereotactic excisional biopsy in the management of invasive breast cancer. World J Surg. Nov. 2005;29(11):1490-4. discussion 5-6. [pmid: 16240063].
1108 Harlow SP, Krag DN, Ames SE, et al. Intraoperative ultrasound localization to guide surgical excision of nonpalpable breast carcinoma. J Am Coll Surg. Sep. 1999;189(3):241-6. [pmid: 10472923].
1109 Harman SM, Gucciardo F, Heward CB, et al. Discrimination of breast cancer by anti-malignin antibody serum test in women undergoing biopsy. Cancer Epidemiol Biomarkers Prev. Oct. 2005;14(10):2310-5. [pmid: 16214910].
1110 Harvey JA, Nicholson BT, Lorusso AP, et al. Short-term follow-up of palpable breast lesions with benign imaging features: evaluation of 375 lesions in 320 women. AJR Am J Roentgenol. Dec. 2009;193(6):1723-30. [pmid: 19933671].
1111 Hassan HHM, Mahmoud Zahran MH, El-Prince Hassan H, et al. Diffusion magnetic resonance imaging of breast lesions: Initial experience at Alexandria University. Alexandria Journal of Medicine. 2013;49(3):265-72.
1112 Hatada T, Ishii H, Ichii S, et al. Diagnostic value of ultrasound-guided fine-needle aspiration biopsy, core-needle biopsy, and evaluation of combined use in the diagnosis of breast lesions. J Am Coll Surg. Mar. 2000;190(3):299-303. [pmid: 10703854].
1113 Hayes BD, Brodie C, O’Doherty A, et al. High-grade histologic features of DCIS are associated with R5 rather than R3 calcifications in breast screening mammography. Breast J. May–Jun. 2013;19(3):319-24. [pmid: 23600490].
1114 Hemmer JM, Kelder JC, van Heesewijk HP. Stereotactic large-core needle breast biopsy: analysis of pain and discomfort related to the biopsy procedure. Eur Radiol. Feb. 2008;18(2):351-4. [pmid: 17909818].
1115 Henderson LM, Hubbard RA, Onega TL, et al. Assessing health care use and cost consequences of a new screening modality: the case of digital mammography. Med Care. Dec. 2012;50(12):1045-52. [pmid: 22922432].
1116 Heywang-Koebrunner S, Bock K, Heindel W, et al. Mammography Screening–as of 2013. Geburtshilfe und Frauenheilkunde. 2013;73(10):1007-16. [pmid: 24771889].
1117 Hille H, Vetter M, Hackeloer BJ. The accuracy of BI-RADS classification of breast ultrasound as a first-line imaging method. Ultraschall Med. Apr. 2012;33(2):160-3. [pmid: 21877320].
1118 Hillhouse RA, Norvill KA, Buchanan SW, et al. Analysis of malignancy detected by needle-localized breast biopsy. J Am Osteopath Assoc. Jul. 1996;96(7):398-400. [pmid: 8758871].
1119 Hillner BE, Bear HD, Fajardo LL. Estimating the cost-effectiveness of stereotaxic biopsy for nonpalpable breast abnormalities: a decision analysis model. Acad Radiol. Apr. 1996;3(4):351-60. [pmid: 8796686].
1120 Hoffmann J. Analysis of surgical and diagnostic quality at a specialist breast unit. The Breast. 2006;15(4):490-7. [pmid: 16343904].
1121 Hofvind S, Ponti A, Patnick J, et al. False-positive results in mammographic screening for breast cancer in Europe: a literature review and survey of service screening programmes. J Med Screen. 2012;19(Suppl 1):57-66. [pmid: 22972811].
1122 Holloway CM, Gagliardi AR. Percutaneous needle biopsy for breast diagnosis: how do surgeons decide?. Ann Surg Oncol. Jun. 2009;16(6):1629-36. [pmid: 19357925].
1123 Holloway CM, Saskin R, Paszat L. Geographic variation and physician specialization in the use of percutaneous biopsy for breast cancer diagnosis. Can J Surg. Dec. 2008;51(6):453-63. [pmid: 19057734].
1124 Homesh NA, Issa MA, El-Sofiani HA. The diagnostic accuracy of fine needle aspiration cytology versus core needle biopsy for palpable breast lump(s). Saudi Med J. Jan. 2005;26(1):42-6. [pmid: 15756351].
1125 Hooley RJ, Greenberg KL, Stackhouse RM, et al. Screening US in patients with mammographically dense breasts: initial experience with Connecticut Public Act 09-41. Radiology. Oct. 2012;265(1):59-69. [pmid: 22723501].
1126 Hoorntje LE, Peeters PH, Mali WP, et al. Is stereotactic large-core needle biopsy beneficial prior to surgical treatment in BI-RADS 5 lesions?. Breast Cancer Res Treat. Jul. 2004;86(2):165-70. [pmid: 15319568].
1127 Hrung JM, Langlotz CP, Orel SG, et al. Cost-effectiveness of MR imaging and core-needle biopsy in the preoperative work-up of suspicious breast lesions. Radiology. Oct. 1999;213(1):39-49. [pmid: 10540638].
1128 Hsu HH, Yu JC, Lee HS, et al. Complex cystic lesions of the breast on ultrasonography: feature analysis and BI-RADS assessment. Eur J Radiol. Jul. 2011;79(1):73-9. [pmid: 20116191].
1129 Hubbard RA, Kerlikowske K, Flowers CI, et al. Cumulative Probability of False-Positive Recall or Biopsy Recommendation After 10 Years of Screening Mammography: A Cohort Study. Ann Intern Med. 2011;155(8):481-92. [pmid: 22007042].
1130 Hubbard RA, Zhu W, Horblyuk R, et al. Diagnostic imaging and biopsy pathways following abnormal screen-film and digital screening mammography. Breast Cancer Res Treat. Apr. 2013;138(3):879-87. [pmid: 23471650].
1131 Hubbard RA, Zhu W, Onega TL, et al. Effects of digital mammography uptake on downstream breast-related care among older women. Med Care. Dec. 2012;50(12):1053-9. [pmid: 23132199].
1132 Hung WK, Lam HS, Lau Y, et al. Diagnostic accuracy of vacuum-assisted biopsy device for image-detected breast lesions. ANZ J Surg. Aug. 2001;71(8):457-60. [pmid: 11504288].
1133 Hunter TB, Roberts CC, Hunt KR, et al. Occurrence of fibroadenomas in postmenopausal women referred for breast biopsy. J Am Geriatr Soc. Jan. 1996;44(1):61-4. [pmid: 8537592].
1134 Ibrahim AE, Bateman AC, Theaker JM, et al. The role and histological classification of needle core biopsy in comparison with fine needle aspiration cytology in the preoperative assessment of impalpable breast lesions. J Clin Pathol. Feb. 2001;54(2):121-5. [pmid: 11215280].
1135 Idowu MO, Hardy LB, Souers RJ, et al. Pathologic diagnostic correlation with breast imaging findings: a College of American Pathologists Q-Probes study of 48 institutions. Arch Pathol Lab Med. Jan. 2012;136(1):53-60. [pmid: 22208488].
1136 Ikeda K, Ogawa Y, Takii M, et al. A role for elastography in the diagnosis of breast lesions by measuring the maximum fat lesion ratio (max-FLR) by tissue Doppler imaging. Breast Cancer. Jan. 2012;19(1):71-6. [pmid: 21567172].
1137 Insausti LP, Alberro JA, Regueira FM, et al. An experience with the Advanced Breast Biopsy Instrumentation (ABBI) system in the management of non-palpable breast lesions. Eur Radiol. Jul. 2002;12(7):1703-10. [pmid: 12111061].
1138 Iwatani T, Matsuda A, Kawabata H, et al. Predictive factors for psychological distress related to diagnosis of breast cancer. Psychooncology. Mar. 2013;22(3):523-9. [pmid: 23577351].
1139 Jackman RJ, Marzoni FA Jr. Needle-localized breast biopsy: why do we fail?. Radiology. Sep. 1997;204(3):677-84. [pmid: 9280243].
1140 Jackman RJ, Marzoni FA Jr. Stereotactic histologic biopsy with patients prone: technical feasibility in 98% of mammographically detected lesions. AJR Am J Roentgenol. Mar. 2003;180(3):785-94. [pmid: 12591697].
1141 Jackman RJ, Rodriguez-Soto J. Breast microcalcifications: retrieval failure at prone stereotactic core and vacuum breast biopsy--frequency, causes, and outcome. Radiology. Apr. 2006;239(1):61-70. [pmid: 16567483].
1142 Jacobs IA, Chevinsky AH, Diehl W, et al. Advanced breast biopsy instrumentation (ABBI) and management of nonpalpable breast abnormalities: a community hospital experience. Breast. Oct. 2001;10(5):421-6. [pmid: 14965618].
1143 Jacobs TW, Silverman JF, Schroeder B, et al. Accuracy of touch imprint cytology of image-directed breast core needle biopsies. Acta Cytol. Mar–Apr. 1999;43(2):169-74. [pmid: 10097705].
1144 Jaffer S, Bleiweiss IJ, Nagi C. Incidental intraductal papillomas (<2 mm) of the breast diagnosed on needle core biopsy do not need to be excised. Breast J. Mar–Apr. 2013;19(2):130-3. [pmid: 23336823].
1145 Jan WA, Zada N, Samieulla, et al. Comparison of FNAC and core biopsy for evaluating breast lumps. Med Forum Mon. 2002;13(12):26-8.
1146 Jara-Lazaro AR, Tan PH. Comparing digital and optical microscopy diagnoses of breast and prostate core biopsies. Pathology. Jan. 2012;44(1):46-8. [pmid: 22157691].
1147 Jensen A, Rank F, Dyreborg U, et al. Performance of combined clinical mammography and needle biopsy: a nationwide study from Denmark. APMIS. Dec. 2006;114(12):884-92. [pmid: 17207089].
1148 Johnson KS, Baker JA, Lee SS, et al. Cancelation of MRI guided breast biopsies for suspicious breast lesions identified at 3.0 T MRI: reasons, rates, and outcomes. Acad Radiol. May. 2013;20(5):569-75. [pmid: 23473719].
1149 Jones L, Lott MF, Calder CJ, et al. Imprint cytology from ultrasound-guided core biopsies: accurate and immediate diagnosis in a one-stop breast clinic. Clin Radiol. Oct. 2004;59(10):903-8. [pmid: 15451349].
1150 Jung HJ, Hahn SY, Choi HY, et al. Breast sonographic elastography using an advanced breast tissue-specific imaging preset: initial clinical results. J Ultrasound Med. Feb. 2012;31(2):273-80. [pmid: 22298871].
1151 Kaiser CG, Reich C, Wasser K, et al. Economic aspects of MR-mammography in dense breasts. Eur J Radiol. Sep. 2012;81(Suppl 1):S69-71. [pmid: 23083609].
1152 Kaplan SS, Collado-Mesa F, Ekens J, et al. Palpable solid breast masses with probably benign sonographic features: can biopsy be avoided?. Breast J. Mar–Apr. 2013;19(2):212-4. [pmid: 23316805].
1153 Kasahara Y, Kawai M, Tsuji I, et al. Harms of screening mammography for breast cancer in Japanese women. Breast Cancer. Oct. 2013;20(4):310-5. [pmid: 22282164].
1154 Kass R, Henry-Tillman RS, Nurko J, et al. Touch preparation of breast core needle specimens is a new method for same-day diagnosis. Am J Surg. Dec. 2003;186(6):737-41. discussion 42. [pmid: 14672788].
1155 Kass R, Kumar G, Klimberg VS, et al. Clip migration in stereotactic biopsy. Am J Surg. Oct. 2002;184(4):325-31. [pmid: 12383894].
1156 Kaufman HJ, Witherspoon LE, Gwin JL Jr, et al. Stereotactic breast biopsy: a study of first core samples. Am Surg. Jun. 2001;67(6):572-5. discussion 5-6. [pmid: 11409806].
1157 Kawasaki T, Mochizuki K, Yamauchi H, et al. High prevalence of neuroendocrine carcinoma in breast lesions detected by the clinical symptom of bloody nipple discharge. Breast. Oct. 2012;21(5):652-6. [pmid: 22397895].
1158 Kaye MD, Vicinanza-Adami CA, Sullivan ML. Mammographic findings after stereotaxic biopsy of the breast performed with large-core needles. Radiology. Jul. 1994;192(1):149-51. [pmid: 8208927].
1159 Kelaher M, Cawson J, Miller J, et al. Use of breast cancer screening and treatment services by Australian women aged 25–44 years following Kylie Minogue’s breast cancer diagnosis. Int J Epidemiol. Dec. 2008;37(6):1326-32. [pmid: 18515324].
1160 Kelley WE, Bailey R, Bertelsen C, et al. Stereotactic automated surgical biopsy using the ABBI biopsy device: a multicenter study. The Breast Journal. 1998;4(5):302-6.
1161 Kennedy G, Markert M, Alexander JR, et al. Predictive value of BI-RADS classification for breast imaging in women under age 50. Breast Cancer Res Treat. Dec. 2011;130(3):819-23. [pmid: 21748292].
1162 Kessler R, Sutcliffe JB, Bell L, et al. Negative predictive value of breast-specific gamma imaging in low suspicion breast lesions: a potential means for reducing benign biopsies. Breast J. May–Jun. 2011;17(3):319-21. [pmid: 21492299].
1163 Khanna AK, Singh MR, Khanna S, et al. Fine needle aspiration cytology, imprint cytology and tru-cut needle biopsy in breast lumps: a comparative evaluation. J Indian Med Assoc. Jul. 1991;89(7):192-5. [pmid: 1940411].
1164 Kiaer HW, Laenkholm AV, Nielsen BB, et al. Classical pathological variables recorded in the Danish Breast Cancer Cooperative Group’s register 1978–2006. Acta Oncol. 2008;47(4):778-83. [pmid: 18465348].
1165 Kibil W, Hodorowicz-Zaniewska D, Popiela TJ, et al. Mammotome biopsy in diagnosing and treatment of intraductal papilloma of the breast. Polish Journal of Surgery. 2013;85(4):210-5. [pmid: 23640929].
1166 Kim BS. Usefulness of breast-specific gamma imaging as an adjunct modality in breast cancer patients with dense breast: a comparative study with MRI. Ann Nucl Med. Feb. 2012;26(2):131-7. [pmid: 22006539].
1167 Kim C, Yoon C, Park JH, et al. Evaluation of ultrasound synthetic aperture imaging using bidirectional pixel-based focusing: preliminary phantom and in vivo breast study. IEEE Trans Biomed Eng. Oct. 2013;60(10):2716-24. [pmid: 23686939].
1168 Kim MJ, Kim JY, Youn JH, et al. US-guided diffuse optical tomography for breast lesions: the reliability of clinical experience. Eur Radiol. Jul. 2011;21(7):1353-63. [pmid: 21274716].
1169 Kim SJ, Chang JM, Cho N, et al. Outcome of breast lesions detected at screening ultrasonography. Eur J Radiol. Nov. 2012;81(11):3229-33. [pmid: 22591758].
1170 Kim WH, Chang JM, Moon WK, et al. Intraductal mass on breast ultrasound: final outcomes and predictors of malignancy. AJR Am J Roentgenol. Apr. 2013;200(4):932-7. [pmid: 23521472].
1171 Kim YW, Kim SK, Youn HJ, et al. The clinical utility of automated breast volume scanner: a pilot study of 139 cases. J Breast Cancer. Sep. 2013;16(3):329-34. [pmid: 24155763].
1172 Klein RL, Mook JA, Euhus DM, et al. Evaluation of a hydrogel based breast biopsy marker (HydroMARK(R)) as an alternative to wire and radioactive seed localization for non-palpable breast lesions. J Surg Oncol. May. 2012;105(6):591-4. [pmid: 22095610].
1173 Klevesath MB, Godwin RJ, Bannon R, et al. Touch imprint cytology of core needle biopsy specimens: a useful method for immediate reporting of symptomatic breast lesions. Eur J Surg Oncol. Jun. 2005;31(5):490-4. [pmid: 15922884].
1174 Ko ES, Choi HY, Kim RB, et al. Application of sonoelastography: comparison of performance between mass and non-mass lesion. Eur J Radiol. Apr. 2012;81(4):731-6. [pmid: 21306848].
1175 Kontos M, Wilson R, Fentiman I. Digital infrared thermal imaging (DITI) of breast lesions: sensitivity and specificity of detection of primary breast cancers. Clin Radiol. Jun. 2011;66(6):536-9. [pmid: 21377664].
1176 Kooistra B, Wauters C, Strobbe L. Indeterminate breast fine-needle aspiration: repeat aspiration or core needle biopsy?. Ann Surg Oncol. Feb. 2009;16(2):281-4. [pmid: 19050965].
1177 Koskela A, Berg M, Sudah M, et al. Learning curve for add-on stereotactic core needle breast biopsy. Acta Radiol. Jun. 2006;47(5):454-60. [pmid: 16796305].
1178 Kotsianos-Hermle D, Hiltawsky KM, Wirth S, et al. Analysis of 107 breast lesions with automated 3D ultrasound and comparison with mammography and manual ultrasound. Eur J Radiol. Jul. 2009;71(1):109-15. [pmid: 18468829].
1179 Krainick-Strobel U, Flugel B, Hahn M, et al. Complete resection of benign breast lesions with an ultrasound-guided vacuum biopsy system with a median follow-up of 13 months: Komplettresektion benigner Mammabefunde mittels ultraschallgefuhrter grosslumiger Vakuumbiopsie: Medianes Follow-up von 13 Monaten. Tumor Diagn Ther. 2010;31(6):338-42.
1180 Kruger BM, Burrowes P, MacGregor JH. Accuracy of marker clip placement after mammotome breast biopsy. Can Assoc Radiol J. Jun. 2002;53(3):137-40. [pmid: 12101533].
1181 Kuhl CK, Morakkabati N, Leutner CC, et al. MR imaging--guided large-core (14-gauge) needle biopsy of small lesions visible at breast MR imaging alone. Radiology. Jul. 2001;220(1):31-9. [pmid: 11425969].
1182 Kumm TR, Szabunio MM. Elastography for the characterization of breast lesions: initial clinical experience. Cancer Control. Jul. 2010;17(3):156-61. [pmid: 20664512].
1183 Kuo YL, Chang TW. Can concurrent core biopsy and fine needle aspiration biopsy improve the false negative rate of sonographically detectable breast lesions?. BMC Cancer. 2010;10:371. [pmid: 20637074].
1184 Lacquement MA, Mitchell D, Hollingsworth AB. Positive predictive value of the Breast Imaging Reporting and Data System. J Am Coll Surg. Jul. 1999;189(1):34-40. [pmid: 10401738].
1185 Lamm RL, Jackman RJ. Mammographic abnormalities caused by percutaneous stereotactic biopsy of histologically benign lesions evident on follow-up mammograms. AJR Am J Roentgenol. Mar. 2000;174(3):753-6. [pmid: 10701620].
1186 Lang EV, Berbaum KS, Lutgendorf SK. Large-core breast biopsy: abnormal salivary cortisol profiles associated with uncertainty of diagnosis. Radiology. Mar. 2009;250(3):631-7. [pmid: 19244038].
1187 Lannin DR, Ponn T, Andrejeva L, et al. Should all breast cancers be diagnosed by needle biopsy?. Am J Surg. Oct. 2006;192(4):450-4. [pmid: 16978947].
1188 LaRaja RD, Saber AA, Sickles A. Early experience in the use of the Advanced Breast Biopsy Instrumentation: a report of one hundred twenty-seven patients. Surgery. Apr. 1999;125(4):380-4. [pmid: 10216528].
1189 Larrieux G, Cupp JA, Liao J, et al. Effect of introducing hematoma ultrasound-guided lumpectomy in a surgical practice. J Am Coll Surg. Aug. 2012;215(2):237-43. [pmid: 22632911].
1190 Larson BT, Erdman AG, Tsekos NV, et al. Design of an MRI-compatible robotic stereotactic device for minimally invasive interventions in the breast. J Biomech Eng. Aug. 2004;126(4):458-65. [pmid: 15543863].
1191 Laudico A, Redaniel MT, Mirasol-Lumague MR, et al. Epidemiology and clinicopathology of breast cancer in metro Manila and Rizal Province, Philippines. Asian Pac J Cancer Prev. Jan–Mar. 2009;10(1):167-72. [pmid: 19469648].
1192 Layfield LJ, Factor RE, Jarboe EA. Clinician compliance with laboratory regulations requiring submission of relevant clinical data: A one year retrospective analysis. Pathol Res Pract. Nov. 15. 2012;208(11):668-71. [pmid: 22999368].
1193 LeCarpentier GL, Roubidoux MA, Fowlkes JB, et al. Suspicious breast lesions: assessment of 3D Doppler US indexes for classification in a test population and fourfold cross-validation scheme. Radiology. Nov. 2008;249(2):463-70. [pmid: 18936310].
1194 Leconte I, Abraham C, Galant C, et al. Fibroadenoma: can fine needle aspiration biopsy avoid short term follow-up?. Diagn Interv Imaging. Oct. 2012;93(10):750-6. [pmid: 22999986].
1195 Lee A, Chang J, Lim W, et al. Effectiveness of breast-specific gamma imaging (BSGI) for breast cancer in Korea: a comparative study. Breast J. Sep. 2012;18(5):453-8. [pmid: 22897514].
1196 Lee AH, Villena Salinas NM, Hodi Z, et al. The value of examination of multiple levels of mammary needle core biopsy specimens taken for investigation of lesions other than calcification. J Clin Pathol. Dec. 2012;65(12):1097-9. [pmid: 22918889].
1197 Lee CI, Wells CJ, Bassett LW. Cost minimization analysis of ultrasound-guided diagnostic evaluation of probably benign breast lesions. Breast J. Jan–Feb. 2013;19(1):41-8. [pmid: 23186174].
1198 Lee EJ, Jung HK, Ko KH, et al. Diagnostic performances of shear wave elastography: which parameter to use in differential diagnosis of solid breast masses?. Eur Radiol. Jul. 2013;23(7):1803-11. [pmid: 23423637].
1199 Lee HJ, Kim EK, Kim MJ, et al. Observer variability of Breast Imaging Reporting and Data System (BI-RADS) for breast ultrasound. Eur J Radiol. Feb. 2008;65(2):293-8. [pmid: 17531417].
1200 Lee JH, Fulp W, Wells KJ, et al. Patient navigation and time to diagnostic resolution: results for a cluster randomized trial evaluating the efficacy of patient navigation among patients with breast cancer screening abnormalities, Tampa, FL. PLoS One. 2013;8(9):e74542. [pmid: 24066145].
1201 Lee SH, Chang JM, Kim WH, et al. Differentiation of benign from malignant solid breast masses: comparison of two-dimensional and three-dimensional shear-wave elastography. Eur Radiol. Apr. 2013;23(4):1015-26. [pmid: 23085867].
1202 Lefkowitz RJ. Identification of adenylate cyclase-coupled beta-adrenergic receptors with radiolabeled beta-adrenergic antagonists. Biochem Pharmacol. Sep. 15. 1975;24(18):1651-8. [pmid: 11].
1203 Lehman CD, Shook JE. Position of clip placement after vacuum-assisted breast biopsy: is a unilateral two-view postbiopsy mammogram necessary?. Breast J. Jul–Aug. 2003;9(4):272-6. [pmid: 12846859].
1204 Leifland K, Lagerstedt U, Svane G. Comparison of stereotactic fine needle aspiration cytology and core needle biopsy in 522 non-palpable breast lesions. Acta Radiol. Jul. 2003;44(4):387-91. [pmid: 12846688].
1205 Leifland K, Lundquist H, Lagerstedt U, et al. Comparison of preoperative simultaneous stereotactic fine needle aspiration biopsy and stereotactic core needle biopsy in ductal carcinoma in situ of the breast. Acta Radiol. Mar. 2003;44(2):213-7. [pmid: 12694110].
1206 Leong LC, Sim LS, Lee YS, et al. A prospective study to compare the diagnostic performance of breast elastography versus conventional breast ultrasound. Clin Radiol. Nov. 2010;65(11):887-94. [pmid: 20933643].
1207 Leucht W, Leucht D, Kiesel L. Sonographic demonstration and evaluation of microcalcifications in the breast. Breast disease. 1992;5(2):105-23.
1208 Levin DC, Parker L, Schwartz GF, et al. Percutaneous needle vs surgical breast biopsy: previous allegations of overuse of surgery are in error. J Am Coll Radiol. Feb. 2012;9(2):137-40. [pmid: 22305700].
1209 Li M, Song Y, Cho N, et al. An HR-MAS MR metabolomics study on breast tissues obtained with core needle biopsy. PLoS One. 2011;6(10):e25563. [pmid: 22028780].
1210 Liao MN, Chen PL, Chen MF, et al. Effect of supportive care on the anxiety of women with suspected breast cancer. J Adv Nurs. Jan. 2010;66(1):49-59. [pmid: 19968726].
1211 Liao MN, Chen PL, Chen MF, et al. Supportive care for Taiwanese women with suspected breast cancer during the diagnostic period: effect on healthcare and support needs. Oncol Nurs Forum. Sep. 2009;36(5):585-92. [pmid: 19726399].
1212 Liberman L, Benton CL, Dershaw DD, et al. Learning curve for stereotactic breast biopsy: how many cases are enough?. AJR Am J Roentgenol. Mar. 2001;176(3):721-7. [pmid: 11222213].
1213 Liberman L, Dershaw DD, Morris EA, et al. Clip placement after stereotactic vacuum-assisted breast biopsy. Radiology. Nov. 1997;205(2):417-22. [pmid: 9356622].
1214 Liberman L, Dershaw DD, Rosen PP, et al. Stereotaxic 14-gauge breast biopsy: how many core biopsy specimens are needed?. Radiology. Sep. 1994;192(3):793-5. [pmid: 8058949].
1215 Liberman L, Dershaw DD, Rosen PP, et al. Percutaneous removal of malignant mammographic lesions at stereotactic vacuum-assisted biopsy. Radiology. Mar. 1998;206(3):711-5. [pmid: 9494489].
1216 Liberman L, Dershaw DD, Rosen PP, et al. Core needle biopsy of synchronous ipsilateral breast lesions: impact on treatment. AJR Am J Roentgenol. Jun. 1996;166(6):1429-32. [pmid: 8633457].
1217 Liberman L, Evans WP 3rd, Dershaw DD, et al. Radiography of microcalcifications in stereotaxic mammary core biopsy specimens. Radiology. Jan. 1994;190(1):223-5. [pmid: 8259409].
1218 Liberman L, Goodstine SL, Dershaw DD, et al. One operation after percutaneous diagnosis of nonpalpable breast cancer: frequency and associated factors. AJR Am J Roentgenol. Mar. 2002;178(3):673-9. [pmid: 11856696].
1219 Liberman L, Hann LE, Dershaw DD, et al. Mammographic findings after stereotactic 14-gauge vacuum biopsy. Radiology. May. 1997;203(2):343-7. [pmid: 9114086].
1220 Liberman L, Smolkin JH, Dershaw DD, et al. Calcification retrieval at stereotactic, 11-gauge, directional, vacuum-assisted breast biopsy. Radiology. Jul. 1998;208(1):251-60. [pmid: 9646821].
1221 Lieske B, Ravichandran D, Wright D. Role of fine-needle aspiration cytology and core biopsy in the preoperative diagnosis of screen-detected breast carcinoma. Br J Cancer. Jul. 3. 2006;95(1):62-6. [pmid: 16755293].
1222 Lieu D. Cytopathologist-performed ultrasound-guided fine-needle aspiration and core-needle biopsy: a prospective study of 500 consecutive cases. Diagn Cytopathol. May. 2008;36(5):317-24. [pmid: 18418854].
1223 Lifrange E, Dondelinger RF, Foidart JM, et al. Percutaneous stereotactic en bloc excision of nonpalpable breast carcinoma: a step in the direction of supraconservative surgery. Breast. Dec. 2002;11(6):501-8. [pmid: 14965717].
1224 Lifrange E, Dondelinger RF, Fridman V, et al. En bloc excision of nonpalpable breast lesions using the advanced breast biopsy instrumentation system: an alternative to needle guided surgery?. Eur Radiol. 2001;11(5):796-801. [pmid: 11372610].
1225 Lifrange E, Kridelka F, Colin C. Stereotaxic needle-core biopsy and fine-needle aspiration biopsy in the diagnosis of nonpalpable breast lesions: controversies and future prospects. Eur J Radiol. Jan. 1997;24(1):39-47. [pmid: 9056148].
1226 Linda A, Zuiani C, Londero V, et al. Outcome of initially only magnetic resonance mammography-detected findings with and without correlate at second-look sonography: distribution according to patient history of breast cancer and lesion size. Breast. Feb. 2008;17(1):51-7. [pmid: 17709249].
1227 Lindfors KK, O’Connor J, Acredolo CR, et al. Short-interval follow-up mammography versus immediate core biopsy of benign breast lesions: assessment of patient stress. AJR Am J Roentgenol. Jul. 1998;171(1):55-8. [pmid: 9648763].
1228 Lister D, Evans AJ, Burrell HC, et al. The accuracy of breast ultrasound in the evaluation of clinically benign discrete, symptomatic breast lumps. Clin Radiol. Jul. 1998;53(7):490-2. [pmid: 9714387].
1229 Liu X, Inciardi M, Bradley JP, et al. Microcalcifications of the breast: size matters! A mammographic-histologic correlation study. Pathologica. Feb. 2007;99(1):5-10. [pmid: 17566305].
1230 Lo GG, Ai V, Chan JK, et al. Diffusion-weighted magnetic resonance imaging of breast lesions: first experiences at 3 T. J Comput Assist Tomogr. Jan–Feb. 2009;33(1):63-9. [pmid: 19188787].
1231 Logan-Young W, Dawson AE, Wilbur DC, et al. The cost-effectiveness of fine-needle aspiration cytology and 14-gauge core needle biopsy compared with open surgical biopsy in the diagnosis of breast carcinoma. Cancer. May. 15. 1998;82(10):1867-73. [pmid: 9587118].
1232 Lovrics PJ, Gordon M, Cornacchi SD, et al. Practice patterns and perceptions of margin status for breast conserving surgery for breast carcinoma: National Survey of Canadian General Surgeons. Breast. Dec. 2012;21(6):730-4. [pmid: 22901975].
1233 Lyon D, Walter J, Munro CL, et al. Challenges in interpreting cytokine biomarkers in biobehavioral research: a breast cancer exemplar. Biol Res Nurs. Jan. 2011;13(1):25-31. [pmid: 21199813].
1234 Mack LA, Dabbs K, Temple WJ. Synoptic operative record for point of care outcomes: a leap forward in knowledge translation. Eur J Surg Oncol. Sep. 2010;36(Suppl 1):S44-9. [pmid: 20609548].
1235 Madabhushi A, Agner S, Basavanhally A, et al. Computer-aided prognosis: predicting patient and disease outcome via quantitative fusion of multi-scale, multi-modal data. Comput Med Imaging Graph. Oct–Dec. 2011;35(7–8):506-14. [pmid: 21333490].
1236 Mahoney MC. Initial clinical experience with a new MRI vacuum-assisted breast biopsy device. J Magn Reson Imaging. Oct. 2008;28(4):900-5. [pmid: 18821610].
1237 Mainiero MB, Koelliker SL, Lazarus E, et al. Ultrasound-guided large-core needle biopsy of the breast. JOURNAL OF WOMENS IMAGING. 2002;4(2):52-7.
1238 Majek O, Danes J, Skovajsova M, et al. Breast cancer screening in the Czech Republic: time trends in performance indicators during the first seven years of the organised programme. BMC Public Health. 2011;11:288. [pmid: 21554747].
1239 Manfrin E, Mariotto R, Remo A, et al. Is there still a role for fine-needle aspiration cytology in breast cancer screening? Experience of the Verona Mammographic Breast Cancer Screening Program with real-time integrated radiopathologic activity (1999–2004). Cancer. Apr. 25. 2008;114(2):74-82. [pmid: 18306357].
1240 Mann RM. The effectiveness of MR imaging in the assessment of invasive lobular carcinoma of the breast. Magn Reson Imaging Clin N Am. May. 2010;18(2):259-76. ix. [pmid: 20494311].
1241 Mansour SM, Omar OS. Elastography ultrasound and questionable breast lesions: does it count?. Eur J Radiol. Nov. 2012;81(11):3234-44. [pmid: 22591761].
1242 March DE, Walker MT, Bur M, et al. Touch-preparation cytologic examination of breast core biopsy specimens: accuracy in predicting benign or malignant core histologic results. Acad Radiol. Jun. 1999;6(6):333-8. [pmid: 10376063].
1243 Margolin FR, Kaufman L, Denny SR, et al. Metallic marker placement after stereotactic core biopsy of breast calcifications: comparison of two clips and deployment techniques. AJR Am J Roentgenol. Dec. 2003;181(6):1685-90. [pmid: 14627597].
1244 Margolin FR, Kaufman L, Jacobs RP, et al. Stereotactic core breast biopsy of malignant calcifications: diagnostic yield of cores with and cores without calcifications on specimen radiographs. Radiology. Oct. 2004;233(1):251-4. [pmid: 15333764].
1245 Marti WR, Zuber M, Oertli D, et al. Advanced breast biopsy instrumentation for the evaluation of impalpable lesions: a reliable diagnostic tool with little therapeutic potential. European Journal of Surgery. 2001;167(1):15-8. [pmid: 11213814].
1246 Masood S, Antley CM, Mooney EE, et al. A Comparison of Accuracy Rates Between Open Biopsy, Cutting-Needle Biopsy, and Fine-Needle Aspiration Biopsy of the Breast: A 3-Year Experience. The Breast Journal. 1998;4(1):3-8.
1247 Masood S, Feng D, Tutuncuoglu O, et al. Diagnostic value of imprint cytology during image-guided core biopsy in improving breast health care. Ann Clin Lab Sci. Fall. 2011;41(1):8-13. [pmid: 21325248].
1248 Masroor I. Effectiveness of assigning BI-RADS category-3 to breast lesion with respect to follow-up. J Coll Physicians Surg Pak. Apr. 2008;18(4):209-12. [pmid: 18474152].
1249 Matthews BD, Williams GB. Initial experience with the advanced breast biopsy instrumentation system. Am J Surg. Feb. 1999;177(2):97-101. [pmid: 10204548].
1250 Mazouni C, Sneige N, Rouzier R, et al. A nomogram to predict for malignant diagnosis of BI-RADS Category 4 breast lesions. J Surg Oncol. Sep. 1. 2010;102(3):220-4. [pmid: 20740578].
1251 Mazzini RC, Elias S, Nazario AC, et al. Prevalence of c-myc expression in breast lesions associated with microcalcifications detected by routine mammography. Sao Paulo Med J. May. 2009;127(2):66-70. [pmid: 19597680].
1252 McKee MD, Cropp MD, Hyland A, et al. Provider case volume and outcome in the evaluation and treatment of patients with mammogram-detected breast carcinoma. Cancer. Aug. 15. 2002;95(4):704-12. [pmid: 12209712].
1253 Meloni GB, Dessole S, Becchere MP, et al. Ultrasound-guided mammotome vacuum biopsy for the diagnosis of impalpable breast lesions. Ultrasound Obstet Gynecol. Nov. 2001;18(5):520-4. [pmid: 11844176].
1254 Melotti MK, Berg WA. Core needle breast biopsy in patients undergoing anticoagulation therapy: preliminary results. AJR Am J Roentgenol. Jan. 2000;174(1):245-9. [pmid: 10628487].
1255 Mendez A, Cabanillas F, Echenique M, et al. Mammographic features and correlation with biopsy findings using 11-gauge stereotactic vacuum-assisted breast biopsy (SVABB). Ann Oncol. Mar. 2004;15(3):450-4. [pmid: 14998847].
1256 Menes TS, Kerlikowske K, Jaffer S, et al. Rates of atypical ductal hyperplasia have declined with less use of postmenopausal hormone treatment: findings from the Breast Cancer Surveillance Consortium. Cancer Epidemiol Biomarkers Prev. Nov. 2009;18(11):2822-8. [pmid: 19900937].
1257 Mercado CL, Guth AA, Toth HK, et al. Sonographically guided marker placement for confirmation of removal of mammographically occult lesions after localization. AJR Am J Roentgenol. Oct. 2008;191(4):1216-9. [pmid: 18806168].
1258 Mesurolle B, Bining HJ, El Khoury M, et al. Contribution of tissue harmonic imaging and frequency compound imaging in interventional breast sonography. J Ultrasound Med. Jul. 2006;25(7):845-55. [pmid: 16798895].
1259 Meyer JE, Smith DN, DiPiro PJ, et al. Stereotactic breast biopsy of clustered microcalcifications with a directional, vacuum-assisted device. Radiology. Aug. 1997;204(2):575-6. [pmid: 9240556].
1260 Milenkovic J, Hertl K, Kosir A, et al. Characterization of spatiotemporal changes for the classification of dynamic contrast-enhanced magnetic-resonance breast lesions. Artif Intell Med. Jun. 2013;58(2):101-14. [pmid: 23548472].
1261 Moon HJ, Kim EK, Kwak JY, et al. Interval growth of probably benign breast lesions on follow-up ultrasound: how can these be managed?. Eur Radiol. May. 2011;21(5):908-18. [pmid: 21113596].
1262 Moon HJ, Kim MJ, Kwak JY, et al. Probably benign breast lesions on ultrasonography: a retrospective review of ultrasonographic features and clinical factors affecting the BI-RADS categorization. Acta Radiol. May. 2010;51(4):375-82. [pmid: 20350247].
1263 Moon HJ, Kim MJ, Kwak JY, et al. Malignant lesions initially categorized as probably benign breast lesions: retrospective review of ultrasonographic, clinical and pathologic characteristics. Ultrasound Med Biol. Apr. 2010;36(4):551-9. [pmid: 20350681].
1264 Moon JH, Kim HH, Shin HJ, et al. Supplemental use of optical diffusion breast imaging for differentiation between benign and malignant breast lesions. AJR Am J Roentgenol. Sep. 2011;197(3):732-9. [pmid: 21862818].
1265 Moon WK, Huang CS, Shen WC, et al. Analysis of elastographic and B-mode features at sonoelastography for breast tumor classification. Ultrasound Med Biol. Nov. 2009;35(11):1794-802. [pmid: 19767139].
1266 Moore SG, Shenoy PJ, Fanucchi L, et al. Cost-effectiveness of MRI compared to mammography for breast cancer screening in a high risk population. BMC Health Serv Res. 2009;9:9. [pmid: 19144138].
1267 Moritz JD, Luftner-Nagel S, Westerhof JP, et al. A comparison of conventional mammographic magnification, ultra high magnification and industrial magnification radiography in the radiographic detection of microcalcifications within core biopsies of the breast. Br J Radiol. Nov. 1997;70(839):1099-103. [pmid: 9536898].
1268 Moritz JD, Mertens C, Westerhof JP, et al. Role of high magnification specimen radiography in surgical and core biopsies of the breast. Br J Radiol. Nov. 2000;73(875):1170-7. [pmid: 11144794].
1269 Morrogh M, Morris EA, Liberman L, et al. MRI identifies otherwise occult disease in select patients with Paget disease of the nipple. J Am Coll Surg. Feb. 2008;206(2):316-21. [pmid: 18222386].
1270 Morrogh M, Park A, Elkin EB, et al. Lessons learned from 416 cases of nipple discharge of the breast. Am J Surg. Jul. 2010;200(1):73-80. [pmid: 20079481].
1271 Morrow M, Venta L, Stinson T, et al. Prospective comparison of stereotactic core biopsy and surgical excision as diagnostic procedures for breast cancer patients. Ann Surg. Apr. 2001;233(4):537-41. [pmid: 11303136].
1272 Mouton JP, Apffelstaedt J, Baatjes K. Surgical mammography reporting in a limited resource environment. World J Surg. Nov. 2010;34(11):2530-6. [pmid: 20577769].
1273 Moy L, Elias K, Patel V, et al. Is breast MRI helpful in the evaluation of inconclusive mammographic findings?. AJR Am J Roentgenol. Oct. 2009;193(4):986-93. [pmid: 19770320].
1274 Moy L, Noz ME, Maguire GQ Jr, et al. Role of fusion of prone FDG-PET and magnetic resonance imaging of the breasts in the evaluation of breast cancer. Breast J. Jul–Aug. 2010;16(4):369-76. [pmid: 20443788].
1275 Moyle P, Sonoda L, Britton P, et al. Incidental breast lesions detected on CT: what is their significance?. Br J Radiol. Mar. 2010;83(987):233-40. [pmid: 19546179].
1276 Mullen DJ, Eisen RN, Newman RD, et al. The use of carbon marking after stereotactic large-core-needle breast biopsy. Radiology. Jan. 2001;218(1):255-60. [pmid: 11152811].
1277 Nakhleh RE, Grimm EE, Idowu MO, et al. Laboratory compliance with the American Society of Clinical Oncology/college of American Pathologists guidelines for human epidermal growth factor receptor 2 testing: a College of American Pathologists survey of 757 laboratories. Arch Pathol Lab Med. May. 2010;134(5):728-34. [pmid: 20441503].
1278 National Guideline Clearinghouse (NGC). Guideline summary: Cancer in children and young people In: Suspected cancer in primary care: guidelines for investigation, referral and reducing ethnic disparities. National Guideline Clearinghouse (NGC) [Web site]. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). [cited 2013 June 25]. Available: http://www.guideline.gov.
1279 Neary M, Lowery AJ, O’Conghaile A, et al. NCCP breast cancer referral guidelines--are breast cancer patients prioritised?. Ir Med J. Feb. 2011;104(2):39-41. [pmid: 21465872].
1280 Nederend J, Duijm LE, Louwman MW, et al. Impact of the transition from screen-film to digital screening mammography on interval cancer characteristics and treatment - a population based study from the Netherlands. Eur J Cancer. Jan. 2014;50(1):31-9. [pmid: 24275518].
1281 Nederend J, Duijm LE, Louwman MW, et al. Impact of transition from analog screening mammography to digital screening mammography on screening outcome in The Netherlands: a population-based study. Ann Oncol. Dec. 2012;23(12):3098-103. [pmid: 22745215].
1282 Ng AK, Garber JE, Diller LR, et al. Prospective study of the efficacy of breast magnetic resonance imaging and mammographic screening in survivors of Hodgkin lymphoma. J Clin Oncol. Jun. 20. 2013;31(18):2282-8. [pmid: 23610104].
1283 Ng CH, Lee KT, Taib NA, et al. Experience with hookwire localisation excision biopsy at a medical centre in Malaysia. Singapore Med J. Apr. 2010;51(4):306-10. [pmid: 20505908].
1284 Ngotho J, Githaiga J, Kaisha W. Palpable discrete breast masses in young women: two of the components of the modified triple test may be adequate. S Afr J Surg. May. 2013;51(2):58-60. [pmid: 23725894].
1285 Nguansangiam S, Jesdapatarakul S, Tangjitgamol S. Accuracy of fine needle aspiration cytology from breast masses in Thailand. Asian Pac J Cancer Prev. Oct–Dec. 2009;10(4):623-6. [pmid: 19827882].
1286 Nizri E, Schneebaum S, Klausner JM, et al. Current management practice of breast borderline lesions--need for further research and guidelines. Am J Surg. Jun. 2012;203(6):721-5. [pmid: 22153085].
1287 Noroozian M, Hadjiiski L, Rahnama-Moghadam S, et al. Digital breast tomosynthesis is comparable to mammographic spot views for mass characterization. Radiology. Jan. 2012;262(1):61-8. [pmid: 21998048].
1288 Nurko J, Mancino AT, Whitacre E, et al. Surgical benefits conveyed by biopsy site marking system using ultrasound localization. Am J Surg. Oct. 2005;190(4):618-22. [pmid: 16164935].
1289 O’Flynn EA, Currie RJ, Mohammed K, et al. Pre-operative factors indicating risk of multiple operations versus a single operation in women undergoing surgery for screen detected breast cancer. Breast. Feb. 2013;22(1):78-82. [pmid: 22789490].
1290 Ogura A, Hayakawa K, Yoshida S, et al. Use of dynamic phase subtraction (DPS) map in dynamic contrast-enhanced MRI of the breast. J Comput Assist Tomogr. Nov–Dec. 2011;35(6):749-52. [pmid: 22082548].
1291 Ohene-Yeboah M. Breast pain in Ghanaian women: clinical, ultrasonographic, mammographic and histological findings in 1612 consecutive patients. West Afr J Med. Jan. 2008;27(1):20-3. [pmid: 18689298].
1292 Oikonomou V, Fotou M, Zagouri F, et al. Imprint cytology of vacuum-assisted breast biopsy specimens: a rapid diagnostic tool in non-palpable solid lesions. Cytopathology. Oct. 2008;19(5):311-5. [pmid: 17953690].
1293 Okazaki H, Tsujimoto F, Maeda I, et al. Radiologic-pathological correlation of punctate hyperechoic foci by ultrasound in stereotactic vacuum-assisted breast biopsy samples. Jpn J Radiol. Dec. 2009;27(10):438-43. [pmid: 20035416].
1294 Okines AF, Thompson LC, Cunningham D, et al. Effect of HER2 on prognosis and benefit from peri-operative chemotherapy in early oesophago-gastric adenocarcinoma in the MAGIC trial. Ann Oncol. May. 2013;24(5):1253-61. [pmid: 23233651].
1295 Olaya W, Bae W, Wong J, et al. Are percutaneous biopsy rates a reasonable quality measure in breast cancer management?. Ann Surg Oncol. Oct. 2010;17(Suppl 3):268-72. [pmid: 20853045].
1296 O’Leary R, Hawkins K, Beazley JC, et al. Agreement between preoperative core needle biopsy and postoperative invasive breast cancer histopathology is not dependent on the amount of clinical material obtained. J Clin Pathol. Feb. 2004;57(2):193-5. [pmid: 14747449].
1297 Oliveira TM, Brasileiro Sant’Anna TK, Mauad FM, et al. Breast imaging: is the sonographic descriptor of orientation valid for magnetic resonance imaging?. J Magn Reson Imaging. Dec. 2012;36(6):1383-8. [pmid: 22911937].
1298 Olsen ML, Morton MJ, Stan DL, et al. Is there a role for magnetic resonance imaging in diagnosing palpable breast masses when mammogram and ultrasound are negative?. J Womens Health (Larchmt). Nov. 2012;21(11):1149-54. [pmid: 23046046].
1299 O’Meara ES, Zhu W, Hubbard RA, et al. Mammographic screening interval in relation to tumor characteristics and false-positive risk by race/ethnicity and age. Cancer. Nov. 15. 2013;119(22):3959-67. [pmid: 24037812].
1300 Ooi GJ, Fox J, Siu K, et al. Fourier transform infrared imaging and small angle x-ray scattering as a combined biomolecular approach to diagnosis of breast cancer. Med Phys. May. 2008;35(5):2151-61. [pmid: 18561690].
1301 Oster NV, Carney PA, Allison KH, et al. Development of a diagnostic test set to assess agreement in breast pathology: practical application of the Guidelines for Reporting Reliability and Agreement Studies (GRRAS). BMC Womens Health. 2013;13:3. [pmid: 23379630].
1302 Ozulker T, Ozulker F, Ozpacaci T, et al. The efficacy of (99m)Tc-MIBI scintimammography in the evaluation of breast lesions and axillary involvement: a comparison with X-rays mammography, ultrasonography and magnetic resonance imaging. Hell J Nucl Med. May–Aug. 2010;13(2):144-9. [pmid: 20808988].
1303 Pacheco JM, Gao F, Bumb C, et al. Racial differences in outcomes of triple-negative breast cancer. Breast Cancer Res Treat. Feb. 2013;138(1):281-9. [pmid: 23400579].
1304 Pagni F, Bosisio FM, Salvioni D, et al. Application of the British National Health Service Breast Cancer Screening Programme classification in 226 breast core needle biopsies: correlation with resected specimens. Ann Diagn Pathol. Apr. 2012;16(2):112-8. [pmid: 22056037].
1305 Park YM, Kim EK, Lee JH, et al. Palpable breast masses with probably benign morphology at sonography: can biopsy be deferred?. Acta Radiol. Dec. 2008;49(10):1104-11. [pmid: 18855166].
1306 Parker SJ, Wheaton M, Wallis MG, et al. Why should diagnostic benign breast biopsies weight less than twenty grams?. Ann R Coll Surg Engl. Mar. 2001;83(2):113-6. [pmid: 11320919].
1307 Partridge SC, DeMartini WB, Kurland BF, et al. Quantitative diffusion-weighted imaging as an adjunct to conventional breast MRI for improved positive predictive value. AJR Am J Roentgenol. Dec. 2009;193(6):1716-22. [pmid: 19933670].
1308 Pegolo E, Pandolfi M, Di Loreto C. Implementation of a microwave-assisted tissue-processing system and an automated embedding system for breast needle core biopsy samples: morphology, immunohistochemistry, and FISH evaluation. Appl Immunohistochem Mol Morphol. Jul. 2013;21(4):362-70. [pmid: 23060302].
1309 Pelletier M, Knauper B, Loiselle CG, et al. Moderators of psychological recovery from benign cancer screening results. Curr Oncol. Jun. 2012;19(3):e191-200. [pmid: 22670109].
1310 Perelman VS, Colapinto ND, Lee S, et al. Experience with the advanced breast biopsy instrumentation system. Can J Surg. Dec. 2000;43(6):437-41. [pmid: 11129832].
1311 Perez-Stable EJ, Afable-Munsuz A, Kaplan CP, et al. Factors influencing time to diagnosis after abnormal mammography in diverse women. J Womens Health (Larchmt). Feb. 2013;22(2):159-66. [pmid: 23350859].
1312 Pezner RD, Lorant JA, Terz J, et al. Wound-healing complications following biopsy of the irradiated breast. Arch Surg. Mar. 1992;127(3):321-4. [pmid: 1550480].
1313 Philpotts LE, Lee CH, Horvath LJ, et al. Canceled stereotactic core-needle biopsy of the breast: analysis of 89 cases. Radiology. Nov. 1997;205(2):423-8. [pmid: 9356623].
1314 Philpotts LE, Shaheen NA, Carter D, et al. Comparison of rebiopsy rates after stereotactic core needle biopsy of the breast with 11-gauge vacuum suction probe versus 14-gauge needle and automatic gun. AJR Am J Roentgenol. Mar. 1999;172(3):683-7. [pmid: 10063860].
1315 Pijnappel RM, van Dalen A, Borel Rinkes IH, et al. The diagnostic accuracy of core biopsy in palpable and non-palpable breast lesions. Eur J Radiol. Feb. 1997;24(2):120-3. [pmid: 9097053].
1316 Pilgrim S, Ravichandran D. Fine needle aspiration cytology as an adjunct to core biopsy in the assessment of symptomatic breast carcinoma. The Breast. 2005;14(5):411-4. [pmid: 16216746].
1317 Piron CA, Causer P, Jong R, et al. A hybrid breast biopsy system combining ultrasound and MRI. IEEE Trans Med Imaging. Sep. 2003;22(9):1100-10. [pmid: 12956265].
1318 Pocock B, Taback B, Klein L, et al. Preoperative needle biopsy as a potential quality measure in breast cancer surgery. Ann Surg Oncol. May. 2009;16(5):1108-11. [pmid: 18953610].
1319 Pogacnik A, Strojan Flezar M, Rener M. Ultrasonographically and stereotactically guided fine-needle aspiration cytology of non-palpable breast lesions: cyto-histological correlation. Cytopathology. Oct. 2008;19(5):303-10. [pmid: 17944953].
1320 Poole GH, Willsher PC, Pinder SE, et al. Diagnosis of breast cancer with core-biopsy and fine needle aspiration cytology. Aust N Z J Surg. Sep. 1996;66(9):592-4. [pmid: 8859156].
1321 Portincasa G, Lucci E, Navarra GG, et al. Initial experience with breast biopsy utilizing the Advanced Breast Biopsy Instrumentation (ABBI). J Surg Oncol. 2000;74(3):201-3. [pmid: 10951417].
1322 Povoski SP, Jimenez RE. A comprehensive evaluation of the 8-gauge vacuum-assisted Mammotome® system for ultrasound-guided diagnostic biopsy and selective excision of breast lesions. World journal of surgical oncology. 2007;5(1):83. [pmid: 17663769].
1323 Prat X, Sittek H, Grosse A, et al. European quadricentric evaluation of a breast MR biopsy and localization device: technical improvements based on phase-I evaluation. Eur Radiol. Jul. 2002;12(7):1720-7. [pmid: 12111063].
1324 Price J, Chen SW. Screening for breast cancer with MRI: recent experience from the Australian Capital Territory. J Med Imaging Radiat Oncol. Feb. 2009;53(1):69-80. [pmid: 19453531].
1325 Prieto-Granada C, Setia N, Otis CN. Lymph node extramedullary hematopoiesis in breast cancer patients receiving neoadjuvant therapy: a potential diagnostic pitfall. Int J Surg Pathol. Jun. 2013;21(3):264-6. [pmid: 23493877].
1326 Pritchard MG, Townend JN, Lester WA, et al. Management of patients taking antiplatelet or anticoagulant medication requiring invasive breast procedures: United Kingdom survey of radiologists’ and surgeons’ current practice. Clin Radiol. Mar. 2008;63(3):305-11. [pmid: 18275871].
1327 Provatopoulou X, Gounaris A, Kalogera E, et al. Circulating levels of matrix metalloproteinase-9 (MMP-9), neutrophil gelatinase-associated lipocalin (NGAL) and their complex MMP-9/NGAL in breast cancer disease. BMC Cancer. 2009;9:390. [pmid: 19889214].
1328 Pruthi S, Shmidt E, Sherman MM, et al. Promoting a breast cancer screening clinic for underserved women: a community collaboration. Ethn Dis. Autumn. 2010;20(4):463-6. [pmid: 21305838].
1329 Psooy BJ, Schreuer D, Borgaonkar J, et al. Patient navigation: improving timeliness in the diagnosis of breast abnormalities. Can Assoc Radiol J. Jun. 2004;55(3):145-50. [pmid: 15237774].
1330 Qazi DES, Mohayuddin N. Role of fine needle aspiration cytology and core biopsy in the diagnosis of breast lumps. J Postgrad med Inst. 2005;19(1):67-70.
1331 Qi J, Ye Z. CTLM as an adjunct to mammography in the diagnosis of patients with dense breast. Clin Imaging. Mar–Apr. 2013;37(2):289-94. [pmid: 23465981].
1332 Qin W, Gui G, Zhang K, et al. Proteins and carbohydrates in nipple aspirate fluid predict the presence of atypia and cancer in women requiring diagnostic breast biopsy. BMC Cancer. 2012;12:52. [pmid: 22296682].
1333 Qureshi NA, Beresford A, Sami S, et al. Imprint cytology of needle core-biopsy specimens of breast lesions: is it a useful adjunt to rapid assessment breast clinics?. Breast. Feb. 2007;16(1):81-5. [pmid: 16952454].
1334 Raj V, Sivashanmugam T, Gupta S, et al. Influence of imaging on touch imprint cytology of breast lesions. Cancer Epidemiol. Aug. 2010;34(4):457-60. [pmid: 20537609].
1335 Rebner M, Chesbrough R, Gregory N. Initial experience with the advanced breast biopsy instrumentation device. AJR Am J Roentgenol. Jul. 1999;173(1):221-6. [pmid: 10397130].
1336 Regini E, Bagnera S, Tota D, et al. Role of sonoelastography in characterising breast nodules. Preliminary experience with 120 lesions. Radiol Med. Jun. 2010;115(4):551-62. [pmid: 20177990].
1337 Renshaw AA. Minimal (< or =0.1 cm) invasive carcinoma in breast core needle biopsies. Incidence, sampling, associated findings, and follow-up. Arch Pathol Lab Med. Sep. 2004;128(9):996-9. [pmid: 15335264].
1338 Reynolds HE. Marker clip placement following directional, vacuum-assisted breast biopsy. Am Surg. Jan. 1999;65(1):59-60. [pmid: 9915534].
1339 Rhodes DJ, Hruska CB, Phillips SW, et al. Dedicated dual-head gamma imaging for breast cancer screening in women with mammographically dense breasts. Radiology. Jan. 2011;258(1):106-18. [pmid: 21045179].
1340 Riedl CC, Pfarl G, Memarsadeghi M, et al. Lesion miss rates and false-negative rates for 1115 consecutive cases of stereotactically guided needle-localized open breast biopsy with long-term follow-up. Radiology. Dec. 2005;237(3):847-53. [pmid: 16237133].
1341 Robbins J, Jeffries D, Roubidoux M, et al. Accuracy of diagnostic mammography and breast ultrasound during pregnancy and lactation. AJR Am J Roentgenol. Mar. 2011;196(3):716-22. [pmid: 21343518].
1342 Roe SM, Mathews JA, Burns RP, et al. Stereotactic and ultrasound core needle breast biopsy performed by surgeons. Am J Surg. Dec. 1997;174(6):699-703. discussion -4. [pmid: 9409600].
1343 Roman M, Hubbard RA, Sebuodegard S, et al. The cumulative risk of false-positive results in the Norwegian Breast Cancer Screening Program: Updated results. Cancer. Nov. 15. 2013;119(22):3952-8. [pmid: 23963877].
1344 Romero C, Varela C, Munoz E, et al. Impact on breast cancer diagnosis in a multidisciplinary unit after the incorporation of mammography digitalization and computer-aided detection systems. AJR Am J Roentgenol. Dec. 2011;197(6):1492-7. [pmid: 22109307].
1345 Rominger MB, Sax EV, Figiel JH, et al. Occurrence and Positive Predictive Value of Additional Nonmass Findings for Risk Stratification of Breast Microcalcifications in Mammography. Can Assoc Radiol J. 2013. Jan. 5. [pmid: 23298860].
1346 Rose A, Collins JP, Neerhut P, et al. Carbon localisation of impalpable breast lesions. Breast. Aug. 2003;12(4):264-9. [pmid: 14659311].
1347 Rosen EL, Baker JA, Soo MS. Accuracy of a collagen-plug biopsy site marking device deployed after stereotactic core needle breast biopsy. AJR Am J Roentgenol. Nov. 2003;181(5):1295-9. [pmid: 14573422].
1348 Rosen EL, Vo TT. Metallic clip deployment during stereotactic breast biopsy: retrospective analysis. Radiology. Feb. 2001;218(2):510-6. [pmid: 11161170].
1349 Rotten D, Levaillant JM, Leridon H, et al. Ultrasonographically guided fine needle aspiration cytology and core-needle biopsy in the diagnosis of breast tumors. Eur J Obstet Gynecol Reprod Biol. May. 1993;49(3):175-86. [pmid: 8405632].
1350 Ruano R, Ramos M, Garcia-Talavera JR, et al. Staging the axilla with selective sentinel node biopsy in patients with previous excision of non-palpable and palpable breast cancer. Eur J Nucl Med Mol Imaging. Jul. 2008;35(7):1299-304. [pmid: 18274744].
1351 Rubin E, Dempsey PJ, Pile NS, et al. Needle-localization biopsy of the breast: impact of a selective core needle biopsy program on yield. Radiology. Jun. 1995;195(3):627-31. [pmid: 7753985].
1352 Rulli A, Lauro A, Bisacci C, et al. Non-palpable breast lesion-biopsy by ABBI® system. A diagnostic tool. CHIRURGIA-TORINO. 2005;18(4):175.
1353 Saad Z, Vincent M, Bramwell V, et al. Timing of surgery influences survival in receptor-negative as well as receptor-positive breast cancer. Eur J Cancer. 1994;30A(9):1348-52. [pmid: 7999424].
1354 Sadler GP, McGee S, Dallimore NS, et al. Role of fine-needle aspiration cytology and needle-core biopsy in the diagnosis of lobular carcinoma of the breast. Br J Surg. Sep. 1994;81(9):1315-7. [pmid: 7953397].
1355 Saha A, Barman I, Dingari NC, et al. Precision of Raman spectroscopy measurements in detection of microcalcifications in breast needle biopsies. Anal Chem. Aug. 7. 2012;84(15):6715-22. [pmid: 22746329].
1356 Sahiner B, Chan HP, Hadjiiski LM, et al. Multi-modality CADx: ROC study of the effect on radiologists’ accuracy in characterizing breast masses on mammograms and 3D ultrasound images. Acad Radiol. Jul. 2009;16(7):810-8. [pmid: 19375953].
1357 Sakuma T, Mimura A, Tanigawa N, et al. Rapid on-site cytologic examination of 1500 breast lesions using the modified Shorr’s stain. Breast Cancer. 2013. Jun. 4. [pmid: 23733595].
1358 Sanchez Gomez S, Torres Tabanera M, Vega Bolivar A, et al. Impact of a CAD system in a screen-film mammography screening program: a prospective study. Eur J Radiol. Dec. 2011;80(3):e317-21. [pmid: 20863639].
1359 Sanders MA, Roland L, Sahoo S. Clinical implications of subcategorizing BI-RADS 4 breast lesions associated with microcalcification: a radiology-pathology correlation study. Breast J. Jan–Feb. 2010;16(1):28-31. [pmid: 19929890].
1360 Satchithananda K, Fernando RA, Ralleigh G, et al. An audit of pain/discomfort experienced during image-guided breast biopsy procedures. Breast J. Nov–Dec. 2005;11(6):398-402. [pmid: 16297083].
1361 Sauter ER, Davis W, Qin W, et al. Identification of a beta-casein-like peptide in breast nipple aspirate fluid that is associated with breast cancer. Biomark Med. Oct. 2009;3(5):577-88. [pmid: 20477526].
1362 Sauven P, Bishop H, Patnick J, et al. The National Health Service Breast Screening Programme and British Association of Surgical Oncology audit of quality assurance in breast screening 1996–2001. Br J Surg. Jan. 2003;90(1):82-7. [pmid: 12520580].
1363 Sayed S, Moloo Z, Bird P, et al. Breast cancer diagnosis in a resource poor environment through a collaborative multidisciplinary approach: the Kenyan experience. J Clin Pathol. Apr. 2013;66(4):307-11. [pmid: 23378268].
1364 Scaranelo AM, Crystal P, Bukhanov K, et al. Sensitivity of a direct computer-aided detection system in full-field digital mammography for detection of microcalcifications not associated with mass or architectural distortion. Can Assoc Radiol J. Jun. 2010;61(3):162-9. [pmid: 20137883].
1365 Schabel MC, Morrell GR, Oh KY, et al. Pharmacokinetic mapping for lesion classification in dynamic breast MRI. J Magn Reson Imaging. Jun. 2010;31(6):1371-8. [pmid: 20512889].
1366 Schaefer FK, Eden I, Schaefer PJ, et al. Factors associated with one step surgery in case of non-palpable breast cancer. Eur J Radiol. Dec. 2007;64(3):426-31. [pmid: 17386990].
1367 Schaefer FK, Heer I, Schaefer PJ, et al. Breast ultrasound elastography--results of 193 breast lesions in a prospective study with histopathologic correlation. Eur J Radiol. Mar. 2011;77(3):450-6. [pmid: 19773141].
1368 Schaub NP, Jones KJ, Nyalwidhe JO, et al. Serum proteomic biomarker discovery reflective of stage and obesity in breast cancer patients. J Am Coll Surg. May. 2009;208(5):970-8. discussion 8-80. [pmid: 19476873].
1369 Schiffhauer LM, Boger JN, Bonfiglio TA, et al. Confocal microscopy of unfixed breast needle core biopsies: a comparison to fixed and stained sections. BMC Cancer. 2009;9:265. [pmid: 19650910].
1370 Schiller DE, Le LW, Cho BC, et al. Factors associated with negative margins of lumpectomy specimen: potential use in selecting patients for intraoperative radiotherapy. Ann Surg Oncol. Mar. 2008;15(3):833-42. [pmid: 18163174].
1371 Schneider J, Lucas R, Tejerina A. Predicting complete removal of impalpable breast carcinomas using stereotactic radiologically guided surgery. Br J Surg. May. 2005;92(5):563-4. [pmid: 15739212].
1372 Schneider P, Piper S, Schmitz CH, et al. Fast 3D Near-infrared breast imaging using indocyanine green for detection and characterization of breast lesions. Rofo. Oct. 2011;183(10):956-63. [pmid: 21972043].
1373 Schnur JB, Bovbjerg DH, David D, et al. Hypnosis decreases presurgical distress in excisional breast biopsy patients. Anesth Analg. Feb. 2008;106(2):440-4. table of contents. [pmid: 18227298].
1374 Schonberg MA, Silliman RA, Marcantonio ER. Weighing the benefits and burdens of mammography screening among women age 80 years or older. J Clin Oncol. Apr. 10. 2009;27(11):1774-80. [pmid: 19255318].
1375 Schwartz JC, Rishi M, Christy CJ, et al. What do breast surgeons do?. Am J Surg. Oct. 2009;198(4):544-6. [pmid: 19800465].
1376 Schwartzberg BS, Goates JJ, Keeler SA, et al. Use of advanced breast biopsy instrumentation while performing stereotactic breast biopsies: review of 150 consecutive biopsies. J Am Coll Surg. Jul. 2000;191(1):9-15. [pmid: 10898178].
1377 Seigneurin A, Exbrayat C, Labarere J, et al. Association of diagnostic work-up with subsequent attendance in a breast cancer screening program for false-positive cases. Breast Cancer Res Treat. May. 2011;127(1):221-8. [pmid: 20809364].
1378 Seow JH, Metcalf C, Wylie E. Nipple discharge in a screening programme: imaging findings with pathological correlation. J Med Imaging Radiat Oncol. Dec. 2011;55(6):577-86. [pmid: 22141605].
1379 Setz-Pels W, Duijm LE, Coebergh JW, et al. Re-attendance after false-positive screening mammography: a population-based study in the Netherlands. Br J Cancer. Oct. 15. 2013;109(8):2044-50. [pmid: 24052045].
1380 Setz-Pels W, Duijm LE, Louwman MW, et al. Characteristics and screening outcome of women referred twice at screening mammography. Eur Radiol. Dec. 2012;22(12):2624-32. [pmid: 22696156].
1381 Shaaban MA, Aly AEAK. Real-time ultrasound elastography: Does it improve B-mode ultrasound characterization of solid breast lesions?. Egypt. J. Radiol. Nucl Med. 2012;43(2):301-9.
1382 Shabaik AS, Cox CE, Clark RA, et al. Imprint cytology of needle-localized breast lesions. Acta Cytol. Jan–Feb. 1993;37(1):10-5. [pmid: 8434486].
1383 Shafqat G, Agha A, Masror I, et al. Dynamic contrast enhanced MRI breast for lesion detection and characterization with histopathological co relation: preliminary experience at tertiary care hospital. J Pak Med Assoc. Mar. 2011;61(3):252-5. [pmid: 21465939].
1384 Shannon J, Douglas-Jones AG, Dallimore NS. Conversion to core biopsy in preoperative diagnosis of breast lesions: is it justified by results?. J Clin Pathol. Oct. 2001;54(10):762-5. [pmid: 11577122].
1385 Sharifi S, Peterson MK, Baum JK, et al. Assessment of pathologic prognostic factors in breast core needle biopsies. Mod Pathol. Oct. 1999;12(10):941-5. [pmid: 10530557].
1386 Sheth D, Wesen CA, Schroder D, et al. The advanced breast biopsy instrumentation (ABBI) experience at a community hospital. Am Surg. Aug. 1999;65(8):726-9. discussion 9-30. [pmid: 10432081].
1387 Shields MW, Smith RS, Bardwil MF, et al. Is needle-directed breast biopsy overused?. West J Med. Mar. 1994;160(3):229-31. [pmid: 8191754].
1388 Shin HJ, Sneige N, Staerkel GA. Utility of punch biopsy for lesions that are hard to aspirate by conventional fine-needle aspiration. Cancer. Jun. 25. 1999;87(3):149-54. [pmid: 10385446].
1389 Shin S, Schneider HB, Cole FJ, et al. Follow-Up Recommendations for Benign Breast Biopsies. Breast J. 2006;12(5):413-7. [pmid: 16958957].
1390 Shirley SE, Mitchell DI, Soares DP, et al. Clinicopathologic features of breast disease in Jamaica: findings of the Jamaican Breast Disease Study, 2000–2002. West Indian Med J. Mar. 2008;57(2):90-4. [pmid: 19565948].
1391 Siegal E, Angelakis E, Morris P, et al. Breast molecular imaging: a retrospective review of one institutions experience with this modality and analysis of its potential role in breast imaging decision making. Breast J. Mar–Apr. 2012;18(2):111-7. [pmid: 22300043].
1392 Simpson WL Jr, Hermann G, Rausch DR, et al. Ultrasound detection of nonpalpable mammographically occult malignancy. Can Assoc Radiol J. Apr. 2008;59(2):70-6. [pmid: 18533395].
1393 Skaane P, Gullien R, Bjorndal H, et al. Digital breast tomosynthesis (DBT): initial experience in a clinical setting. Acta Radiol. Jun. 1. 2012;53(5):524-9. [pmid: 22593120].
1394 Slanetz PJ, Giardino AA, McCarthy KA, et al. Previous breast biopsy for benign disease rarely complicates or alters interpretation on screening mammography. AJR Am J Roentgenol. Jun. 1998;170(6):1539-41. [pmid: 9609170].
1395 Smathers RL. Advanced breast biopsy instrumentation device: percentages of lesion and surrounding tissue removed. AJR Am J Roentgenol. Sep. 2000;175(3):801-3. [pmid: 10954470].
1396 Sneige N, Tulbah A. Accuracy of cytologic diagnoses made from touch imprints of image-guided needle biopsy specimens of nonpalpable breast abnormalities. Diagn Cytopathol. Jul. 2000;23(1):29-34. [pmid: 10907929].
1397 Soares JS, Barman I, Dingari NC, et al. Diagnostic power of diffuse reflectance spectroscopy for targeted detection of breast lesions with microcalcifications. Proc Natl Acad Sci U S A. Jan. 8. 2013;110(2):471-6. [pmid: 23267090].
1398 Somerville P, Seifert PJ, Destounis SV, et al. Anticoagulation and bleeding risk after core needle biopsy. AJR Am J Roentgenol. Oct. 2008;191(4):1194-7. [pmid: 18806164].
1399 Soo MS, Kliewer MA, Ghate S, et al. Stereotactic breast biopsy of noncalcified lesions: a cost-minimization analysis comparing 14-gauge multipass automated core biopsy to 14-and 11-gauge vacuum-assisted biopsy. Clin Imaging. 2005;29(1):26-33. [pmid: 15859015].
1400 Staren ED, O’Neill TP. Ultrasound-guided needle biopsy of the breast. Surgery. Oct. 1999;126(4):629-34. discussion 34-5. [pmid: 10520908].
1401 Stojadinovic A, Nissan A, Shriver CD, et al. Electrical impedance scanning as a new breast cancer risk stratification tool for young women. J Surg Oncol. 2008;97(2):112-20. [pmid: 18050282].
1402 Stolier AJ, Rupley DG. The impact of image-directed core biopsy on the practice of breast surgery: a new algorithm for a changing technology. Am Surg. Sep. 1997;63(9):827-30. [pmid: 9290531].
1403 Stomper PC, Budnick RM, Stewart CC. Breast stereotactic core biopsy washings: abundant cell samples from clinically occult lesions for flow cytometric DNA analysis. Invest Radiol. Jan. 1998;33(1):51-5. [pmid: 9438510].
1404 Stomper PC, Cholewinski SP, Penetrante RB, et al. Atypical hyperplasia: frequency and mammographic and pathologic relationships in excisional biopsies guided with mammography and clinical examination. Radiology. Dec. 1993;189(3):667-71. [pmid: 8234688].
1405 Su MYL. Early-stage invasive breast cancers: Potential role of optical tomography with US localization in assisting diagnosis: Zhu Q, Hegde PU, Ricci a Jr, et al (Univ of Connecticut, Storrs; Univ of Connecticut Health Ctr, Farmington; Hartford Hosp, CT; et al) Radiology 256:367–378, 2010. Breast Dis. 2011;22(2):151-2.
1406 Sun W, Li A, Abreo F, et al. Comparison of fine-needle aspiration cytology and core biopsy for diagnosis of breast cancer. Diagn Cytopathol. Jun. 2001;24(6):421-5. [pmid: 11391825].
1407 Suzuki K, Shiraishi A, Arakawa A. Analysis of stereotactic vacuum-assisted breast biopsy for patients with segmental calcifications. Jpn J Radiol. Dec. 2009;27(10):450-4. [pmid: 20035418].
1408 Svahn TM, Chakraborty DP, Ikeda D, et al. Breast tomosynthesis and digital mammography: a comparison of diagnostic accuracy. Br J Radiol. Nov. 2012;85(1019):e1074-82. [pmid: 22674710].
1409 Swan JS, Ying J, Stahl J, et al. Initial development of the Temporary Utilities Index: a multiattribute system for classifying the functional health impact of diagnostic testing. Qual Life Res. Apr. 2010;19(3):401-12. [pmid: 20084464].
1410 Symmans WF, Weg N, Gross J, et al. A prospective comparison of stereotaxic fine-needle aspiration versus stereotaxic core needle biopsy for the diagnosis of mammographic abnormalities. Cancer. Mar. 1. 1999;85(5):1119-32. [pmid: 10091797].
1411 Takei J, Tsunoda-Shimizu H, Kikuchi M, et al. Clinical implications of architectural distortion visualized by breast ultrasonography. Breast Cancer. 2009;16(2):132-5. [pmid: 19048193].
1412 Tan SM, Behranwala KA, Trott PA, et al. A retrospective study comparing the individual modalities of triple assessment in the pre-operative diagnosis of invasive lobular breast carcinoma. Eur J Surg Oncol. Apr. 2002;28(3):203-8. [pmid: 11944950].
1413 Taskin F, Koseoglu K, Unsal A, et al. Sclerosing adenosis of the breast: radiologic appearance and efficiency of core needle biopsy. Diagn Interv Radiol. Dec. 2011;17(4):311-6. [pmid: 21328197].
1414 Taylor K, O’Keeffe S, Britton PD, et al. Ultrasound elastography as an adjuvant to conventional ultrasound in the preoperative assessment of axillary lymph nodes in suspected breast cancer: a pilot study. Clin Radiol. Nov. 2011;66(11):1064-71. [pmid: 21835398].
1415 Thomassin-Naggara I, Jalaguier-Coudray A, Chopier J, et al. Current opinion on clip placement after breast biopsy: a survey of practising radiologists in France and Quebec. Clin Radiol. Jul. 2013;68(7):e378-83. [pmid: 23522486].
1416 Tice JA, O’Meara ES, Weaver DL, et al. Benign breast disease, mammographic breast density, and the risk of breast cancer. J Natl Cancer Inst. Jul. 17. 2013;105(14):1043-9. [pmid: 23744877].
1417 Tran DQ, Wilkerson DK, Namm J, et al. Needle-localized breast biopsy for mammographic abnormalities: a community hospital experience. Am Surg. Mar. 1999;65(3):283-8. [pmid: 10075310].
1418 Tsang FH, Lo JJ, Wong JL, et al. Application of image-guided biopsy for impalpable breast lesions in Chinese women. ANZ J Surg. Jan–Feb. 2003;73(1–2):23-5. [pmid: 12534733].
1419 Tudorica LA, Oh KY, Roy N, et al. A feasible high spatiotemporal resolution breast DCE-MRI protocol for clinical settings. Magn Reson Imaging. Nov. 2012;30(9):1257-67. [pmid: 22770687].
1420 Turner AJ, Hick PE. Inhibition of aldehyde reductase by acidic metabolites of the biogenic amines. Biochem Pharmacol. Sep. 15. 1975;24(18):1731-3. [pmid: 16].
1421 Uematsu T, Kasami M. Core wash cytology of breast lesions by ultrasonographically guided core needle biopsy. Breast Cancer Res Treat. May. 2008;109(2):251-3. [pmid: 17616804].
1422 Uematsu T, Kasami M, Takahashi K, et al. Clip placement after an 11-gauge vacuum-assisted stereotactic breast biopsy: correlation between breast thickness and clip movement. Breast Cancer. Jan. 2012;19(1):30-6. [pmid: 21274668].
1423 Ukwenya AY, Yusufu LM, Nmadu PT, et al. Delayed treatment of symptomatic breast cancer: the experience from Kaduna, Nigeria. S Afr J Surg. Nov. 2008;46(4):106-10. [pmid: 19051953].
1424 Utzon-Frank N, Vejborg I, von Euler-Chelpin M, et al. Balancing sensitivity and specificity: sixteen year’s of experience from the mammography screening programme in Copenhagen, Denmark. Cancer Epidemiol. Oct. 2011;35(5):393-8. [pmid: 21239242].
1425 Vargas HI, Vargas MP, Gonzalez K, et al. Percutaneous excisional biopsy of palpable breast masses under ultrasound visualization. Breast J. Sep–Oct. 2006;12(5 Suppl 2):S218-22. [pmid: 16959005].
1426 Verardi N, Di Leo G, Carbonaro LA, et al. Contrast-enhanced MR imaging of the breast: association between asymmetric increased breast vascularity and ipsilateral cancer in a consecutive series of 197 patients. Radiol Med. Mar. 2013;118(2):239-50. [pmid: 22872456].
1427 Verenhitach BD, Elias S, Patrocinio AC, et al. Evaluation of the clinical efficacy of minimally invasive procedures for breast cancer screening at a teaching hospital. J Clin Pathol. Oct. 2011;64(10):858-61. [pmid: 21666140].
1428 Verkooijen HM, Buskens E, Peeters PH, et al. Diagnosing non-palpable breast disease: short-term impact on quality of life of large-core needle biopsy versus open breast biopsy. Surg Oncol. May. 2002;10(4):177-81. [pmid: 12020672].
1429 Verkooijen HM, Peeters PH, Borel Rinkes IH, et al. Risk factors for cancellation of stereotactic large core needle biopsy on a prone biopsy table. Br J Radiol. Nov. 2001;74(887):1007-12. [pmid: 11709465].
1430 Verkooijen HM, Peterse JL, Schipper ME, et al. Interobserver variability between general and expert pathologists during the histopathological assessment of large-core needle and open biopsies of non-palpable breast lesions. Eur J Cancer. Oct. 2003;39(15):2187-91. [pmid: 14522377].
1431 Verschuur-Maes AH, van Gils CH, van den Bosch MA, et al. Digital mammography: more microcalcifications, more columnar cell lesions without atypia. Mod Pathol. Sep. 2011;24(9):1191-7. [pmid: 21572405].
1432 Vimpeli SM, Saarenmaa I, Huhtala H, et al. Large-core needle biopsy versus fine-needle aspiration biopsy in solid breast lesions: comparison of costs and diagnostic value. Acta Radiol. Oct. 2008;49(8):863-9. [pmid: 18618302].
1433 Wai CJ, Al-Mubarak G, Homer MJ, et al. A modified triple test for palpable breast masses: the value of ultrasound and core needle biopsy. Ann Surg Oncol. Mar. 2013;20(3):850-5. [pmid: 23104707].
1434 Waldherr C, Cerny P, Altermatt HJ, et al. Value of one-view breast tomosynthesis versus two-view mammography in diagnostic workup of women with clinical signs and symptoms and in women recalled from screening. AJR Am J Roentgenol. Jan. 2013;200(1):226-31. [pmid: 23255766].
1435 Wang S, Delproposto Z, Wang H, et al. Differentiation of breast cancer from fibroadenoma with dual-echo dynamic contrast-enhanced MRI. PLoS One. 2013;8(7):e67731. [pmid: 23844077].
1436 Watanabe S. Mammographic detection of early breast cancer. Gan No Rinsho. Aug. 1988;34(10):1378-87. [pmid: 3172495].
1437 Watermann DO, Einert A, Ehritt-Braun C, et al. Experience with the Advanced Breast Biopsy Instrumentation (ABBI) system. Anticancer Res. Sep–Oct. 2002;22(5):3067-70. [pmid: 12530044].
1438 Wauters CA, Sanders-Eras CT, Kooistra BW, et al. Modified core wash cytology procedure for the immediate diagnosis of core needle biopsies of breast lesions. Cancer. Oct. 25. 2009;117(5):333-7. [pmid: 19739241].
1439 Wauters CA, Sanders-Eras MC, de Kievit-van der Heijden IM, et al. Modified core wash cytology (CWC), an asset in the diagnostic work-up of breast lesions. Eur J Surg Oncol. Oct. 2010;36(10):957-62. [pmid: 20708371].
1440 Weigel S, Biesheuvel C, Berkemeyer S, et al. Digital mammography screening: how many breast cancers are additionally detected by bilateral ultrasound examination during assessment?. Eur Radiol. Mar. 2013;23(3):684-91. [pmid: 23052645].
1441 Weigert J, Steenbergen S. The connecticut experiment: the role of ultrasound in the screening of women with dense breasts. Breast J. Nov–Dec. 2012;18(6):517-22. [pmid: 23009208].
1442 Weismann CF, Forstner R, Prokop E, et al. Three-dimensional targeting: a new three-dimensional ultrasound technique to evaluate needle position during breast biopsy. Ultrasound Obstet Gynecol. Sep. 2000;16(4):359-64. [pmid: 11169313].
1443 Westenend PJ, Sever AR, Beekman-De Volder HJ, et al. A comparison of aspiration cytology and core needle biopsy in the evaluation of breast lesions. Cancer. Apr. 25. 2001;93(2):146-50. [pmid: 11309781].
1444 Whang IY. Power Doppler needle-induced fremitus for breast localization. Arch Gynecol Obstet. Oct. 2008;278(4):337-40. [pmid: 18283477].
1445 Williams MB, Judy PG, Gunn S, et al. Dual-modality breast tomosynthesis. Radiology. Apr. 2010;255(1):191-8. [pmid: 20308457].
1446 Wishart GC, Campisi M, Boswell M, et al. The accuracy of digital infrared imaging for breast cancer detection in women undergoing breast biopsy. Eur J Surg Oncol. Jun. 2010;36(6):535-40. [pmid: 20452740].
1447 Wishart GC, Campisi MS, Chapman D, et al. O-83 Digital infrared imaging for breast cancer detection in younger women undergoing breast biopsy. EJC Supplements. 2010;8(6):31-2. Language: English. Entry Date: 20110304. Revision Date: 20120817. Publication Type: journal article.
1448 Witek-Janusek L, Gabram S, Mathews HL. Psychologic stress, reduced NK cell activity, and cytokine dysregulation in women experiencing diagnostic breast biopsy. Psychoneuroendocrinology. Jan. 2007;32(1):22-35. [pmid: 17092654].
1449 Witt A, Yavuz D, Walchetseder C, et al. Preoperative core needle biopsy as an independent risk factor for wound infection after breast surgery. Obstet Gynecol. Apr. 2003;101(4):745-50. [pmid: 12681880].
1450 Wong SL, Edwards MJ, Chao C, et al. The effect of prior breast biopsy method and concurrent definitive breast procedure on success and accuracy of sentinel lymph node biopsy. Ann Surg Oncol. Apr. 2002;9(3):272-7. [pmid: 11923134].
1451 Woods RW, Oliphant L, Shinki K, et al. Validation of results from knowledge discovery: mass density as a predictor of breast cancer. J Digit Imaging. Oct. 2010;23(5):554-61. [pmid: 19760292].
1452 Woods RW, Sisney GS, Salkowski LR, et al. The mammographic density of a mass is a significant predictor of breast cancer. Radiology. Feb. 2011;258(2):417-25. [pmid: 21177388].
1453 Woon DT, Serpell JW. Preoperative core biopsy of soft tissue tumours facilitates their surgical management: a 10-year update. ANZ J Surg. Nov. 2008;78(11):977-81. [pmid: 18959696].
1454 Wu X, Chen G, Lu J, et al. Label-free detection of breast masses using multiphoton microscopy. PLoS One. 2013;8(6):e65933. [pmid: 23755295].
1455 Xie HB, Salhadar A, Haara A, et al. How stereotactic core-needle biopsy affected breast fine-needle aspiration utilization: an 11-year institutional review. Diagn Cytopathol. Aug. 2004;31(2):106-10. [pmid: 15282722].
1456 Yang JH, Lee SD, Nam SJ. Diagnostic utility of ABBI®(Advanced Breast Biopsy Instrumentation) for nonpalpable breast lesions in Korea. The breast journal. 2000;6(4):257-62. [pmid: 11348375].
1457 Yau EJ, Gutierrez RL, DeMartini WB, et al. The utility of breast MRI as a problem-solving tool. Breast J. May–Jun. 2011;17(3):273-80. [pmid: 21477168].
1458 Yazici B, Sever AR, Mills P, et al. Scar formation after stereotactic vacuum-assisted core biopsy of benign breast lesions. Clin Radiol. Jul. 2006;61(7):619-24. [pmid: 16784949].
1459 Yener NA, Midi A, Cubuk R, et al. Palpable lesions as a diagnostic tool in patients with thoracic pathology. Diagn Cytopathol. Jan. 2013;41(1):28-34. [pmid: 21681977].
1460 Ying X, Lin Y, Xia X, et al. A comparison of mammography and ultrasound in women with breast disease: a receiver operating characteristic analysis. Breast J. Mar–Apr. 2012;18(2):130-8. [pmid: 22356352].
1461 Yong WS, Chia KH, Poh WT, et al. A comparison of trucut biopsy with fine needle aspiration cytology in the diagnosis of breast cancer. Singapore Med J. Sep. 1999;40(9):587-9. [pmid: 10628249].
1462 Yoon JH, Kim MH, Kim EK, et al. Interobserver variability of ultrasound elastography: how it affects the diagnosis of breast lesions. AJR Am J Roentgenol. Mar. 2011;196(3):730-6. [pmid: 21343520].
1463 Youk JH, Gweon HM, Son EJ, et al. Diagnostic value of commercially available shear-wave elastography for breast cancers: integration into BI-RADS classification with subcategories of category 4. Eur Radiol. Oct. 2013;23(10):2695-704. [pmid: 23652850].
1464 Zagouri F, Sergentanis TN, Gounaris A, et al. Pain in different methods of breast biopsy: emphasis on vacuum-assisted breast biopsy. Breast. Feb. 2008;17(1):71-5. [pmid: 17869106].
1465 Zagouri F, Sergentanis TN, Zografos GC. Lesions too close to the chest wall: a relative contraindication for vacuum-assisted breast biopsy. AJR Am J Roentgenol. Apr. 2008;190(4):W270. [pmid: 18356420].
1466 Zahid Z, Ibrahim Z, Bilal S, et al. Comparison of diagnostic accuracy of film-Screen mammography and ultrasound in breast masses. Pak. J. Med Health Sci. 2011;5(3):433-5.
1467 Zanca F, Chakraborty DP, Van Ongeval C, et al. An improved method for simulating microcalcifications in digital mammograms. Med Phys. Sep. 2008;35(9):4012-8. [pmid: 18841852].
1468 Zheng B, Lederman D, Sumkin JH, et al. A preliminary evaluation of multi-probe resonance-frequency electrical impedance based measurements of the breast. Acad Radiol. Feb. 2011;18(2):220-9. [pmid: 21126888].
1469 Zheng B, Zuley ML, Sumkin JH, et al. Detection of breast abnormalities using a prototype resonance electrical impedance spectroscopy system: a preliminary study. Med Phys. Jul. 2008;35(7):3041-8. [pmid: 18697526].
1470 Zhou J, Zhan W, Chang C, et al. Role of acoustic shear wave velocity measurement in characterization of breast lesions. J Ultrasound Med. Feb. 2013;32(2):285-94. [pmid: 23341385].
1471 Zhu C, Burnside ES, Sisney GA, et al. Fluorescence spectroscopy: an adjunct diagnostic tool to image-guided core needle biopsy of the breast. IEEE Trans Biomed Eng. Oct. 2009;56(10):2518-28. [pmid: 19272976].
1472 Zhu J, Kurihara Y, Kanemaki Y, et al. Diagnostic accuracy of high-resolution MRI using a microscopy coil for patients with presumed DCIS following mammography screening. J Magn Reson Imaging. Jan. 2007;25(1):96-103. [pmid: 17154376].
1473 Zhu Q, Hegde PU, Ricci A Jr, et al. Early-stage invasive breast cancers: potential role of optical tomography with US localization in assisting diagnosis. Radiology. Aug. 2010;256(2):367-78. [pmid: 20571122].
1474 Zimmermann CJ, Sheffield KM, Duncan CB, et al. Time trends and geographic variation in use of minimally invasive breast biopsy. J Am Coll Surg. Apr. 2013;216(4):814-24. discussion 24-7. [pmid: 23376029].
1475 Zimmermann N, Ohlinger R. Diagnostic value of palpation, mammography, and ultrasonography in the diagnosis of fibroadenoma: impact of breast density, patient age, ultrasonographic size, and palpability. Ultraschall Med. Dec. 2012;33(7):E151-7. [pmid: 21667430].
1476 Zografos G, Koulocheri D, Liakou P, et al. Novel technology of multimodal ultrasound tomography detects breast lesions. Eur Radiol. Mar. 2013;23(3):673-83. [pmid: 22983317].
1477 Zografos GC, Zagouri F, Sergentanis TN, et al. Cytokine dysregulation during vacuum-assisted breast biopsy: early phase of a complex phenomenon. Isr Med Assoc J. Mar. 2008;10(3):246. [pmid: 18494247].
1478 Zonderland H, Hermans J, Van De Vijver M, et al. Triple diagnostic approach versus ultrasound-guided 18 gauge core biopsy in suspicious breast masses. The Breast. 1998;7(3):168-72.
1479 Zonderland HM, van de Vijver MJ, Visser M. Breast lesion diagnosis: integrating pathology and radiology. Ned Tijdschr Geneeskd. 2011;155(18):A2967. [pmid: 21466724].
1480 Abbate F, Bacigalupo L, Latronico A, et al. Ultrasound-guided vacuum assisted breast biopsy in the assessment of C3 breast lesions by ultrasound-guided fine needle aspiration cytology: results and costs in comparison with surgery. Breast. Apr. 2009;18(2):73-7. [pmid: 19342236].
1481 Abbate F, Cassano E, Menna S, et al. Ultrasound-guided vacuum-assisted breast biopsy: Use at the European Institute of Oncology in 2010. J Ultrasound. Dec. 2011;14(4):177-81. [pmid: 23397003].
1482 Abbott AM, Portschy PR, Lee C, et al. Prospective multicenter trial evaluating balloon-catheter partial-breast irradiation for ductal carcinoma in situ. Int J Radiat Oncol Biol Phys. Nov. 1. 2013;87(3):494-8. [pmid: 24074922].
1483 Abdsaleh S, Warnberg F, Azavedo E, et al. Comparison of core needle biopsy and surgical specimens in malignant breast lesions regarding histological features and hormone receptor expression. Histopathology. May. 2008;52(6):773-5. [pmid: 18393972].
1484 Acs G, Paragh G, Chuang ST, et al. The presence of micropapillary features and retraction artifact in core needle biopsy material predicts lymph node metastasis in breast carcinoma. Am J Surg Pathol. Feb. 2009;33(2):202-10. [pmid: 18987549].
1485 Adkisson CD, Vallow LA, Kowalchik K, et al. Patient age and preoperative breast MRI in women with breast cancer: biopsy and surgical implications. Ann Surg Oncol. Jun. 2011;18(6):1678-83. [pmid: 21207171].
1486 Adler DD, Light RJ, Granstrom P, et al. Follow-up of benign results of stereotactic core breast biopsy. Acad Radiol. Apr. 2000;7(4):248-53. [pmid: 10766097].
1487 Aftab K, Idrees R. Nipple adenoma of breast: a masquerader of malignancy. J Coll Physicians Surg Pak. Jul. 2010;20(7):472-4. [pmid: 20642949].
1488 Aftab ML, Rashid A, Aslam M, et al. Clinical value of sure cut biopsy in breast masses. Pak. J. Med Health Sci. 2010;4(1):46-8.
1489 Agarwal T, Patel B, Rajan P, et al. Core biopsy versus FNAC for palpable breast cancers. Is image guidance necessary?. Eur J Cancer. Jan. 2003;39(1):52-6. [pmid: 12504658].
1490 Ahmad A, Bano U, Gondal M, et al. Her-2/neu gene overexpression in breast carcinoma and its association with clinicopathological characteristics of the disease. J Coll Physicians Surg Pak. May. 2009;19(5):297-9. [pmid: 19409162].
1491 Ahmadiyeh N, Stoleru MA, Raza S, et al. Management of intraductal papillomas of the breast: an analysis of 129 cases and their outcome. Ann Surg Oncol. Aug. 2009;16(8):2264-9. [pmid: 19484312].
1492 Akagi T, Kinoshita T, Shien T, et al. Clinical and pathological features of intracystic papillary carcinoma of the breast. Surg Today. 2009;39(1):5-8. [pmid: 19132460].
1493 Akbulut M, Zekioglu O, Kapkac M, et al. Fine needle aspiration cytology of glycogen-rich clear cell carcinoma of the breast: review of 37 cases with histologic correlation. Acta Cytol. Jan–Feb. 2008;52(1):65-71. [pmid: 18323277].
1494 Al Hassan T, Delli Fraine P, El-Khoury M, et al. Accuracy of percutaneous core needle biopsy in diagnosing papillary breast lesions and potential impact of sonographic features on their management. J Clin Ultrasound. Jan. 2013;41(1):1-9. [pmid: 22987609].
1495 Al Sarakbi W, Salhab M, Thomas V, et al. Is preoperative core biopsy accurate in determining the hormone receptor status in women with invasive breast cancer?. Int Semin Surg Oncol. Aug. 22. 2005;2:15. [pmid: 16115314].
1496 Al-Janabi S, Huisman A, Willems SM, et al. Digital slide images for primary diagnostics in breast pathology: a feasibility study. Hum Pathol. Dec. 2012;43(12):2318-25. [pmid: 22901465].
1497 Al-Khawari HA, Al-Manfouhi HA, Madda JP, et al. Radiologic features of granulomatous mastitis. Breast J. Nov–Dec. 2011;17(6):645-50. [pmid: 21929558].
1498 Allen LR, Lago-Toro CE, Hughes JH, et al. Is there a role for MRI in the preoperative assessment of patients with DCIS?. Ann Surg Oncol. Sep. 2010;17(9):2395-400. [pmid: 20217259].
1499 Allison KH, Eby PR, Kohr J, et al. Atypical ductal hyperplasia on vacuum-assisted breast biopsy: suspicion for ductal carcinoma in situ can stratify patients at high risk for upgrade. Hum Pathol. Jan. 2011;42(1):41-50. [pmid: 20970167].
1500 Amir E, Miller N, Geddie W, et al. Prospective study evaluating the impact of tissue confirmation of metastatic disease in patients with breast cancer. J Clin Oncol. Feb. 20. 2012;30(6):587-92. [pmid: 22124102].
1501 Ancona A, Capodieci M, Galiano A, et al. Vacuum-assisted biopsy diagnosis of atypical ductal hyperplasia and patient management. Radiol Med. Mar. 2011;116(2):276-91. [pmid: 21225358].
1502 Andacoglu O, Kanbour-Shakir A, Teh YC, et al. Rationale of excisional biopsy after the diagnosis of benign radial scar on core biopsy: a single institutional outcome analysis. Am J Clin Oncol. Feb. 2013;36(1):7-11. [pmid: 22134516].
1503 Andrade VP, Gobbi H. Accuracy of typing and grading invasive mammary carcinomas on core needle biopsy compared with the excisional specimen. Virchows Arch. Dec. 2004;445(6):597-602. [pmid: 15480766].
1504 Andrews-Tang D, Diamond AB, Rogers L, et al. Diabetic Mastopathy: Adjunctive Use of Ultrasound and Utility of Core Biopsy in Diagnosis. Breast J. May. 2000;6(3):183-8. [pmid: 11348362].
1505 Andrykowski MA, Carpenter JS, Studts JL, et al. Psychological impact of benign breast biopsy: a longitudinal, comparative study. Health Psychol. Sep. 2002;21(5):485-94. [pmid: 12211516].
1506 Ansari B, Boughey JC, Adamczyk DL, et al. Should axillary ultrasound be used in patients with a preoperative diagnosis of ductal carcinoma in situ?. Am J Surg. Sep. 2012;204(3):290-3. [pmid: 22749764].
1507 Apple SK. Variability in gross and microscopic pathology reporting in excisional biopsies of breast cancer tissue. Breast J. Mar–Apr. 2006;12(2):145-9. [pmid: 16509839].
1508 Apple SK, Lowe AC, Rao PN, et al. Comparison of fluorescent in situ hybridization HER-2/neu results on core needle biopsy and excisional biopsy in primary breast cancer. Mod Pathol. Sep. 2009;22(9):1151-9. [pmid: 19483670].
1509 Arazi-Kleinman T, Causer PA, Nofech-Mozes S, et al. Is ductal carcinoma in situ with “possible invasion” more predictive of invasive carcinoma than pure ductal carcinoma in situ?. Can Assoc Radiol J. May. 2012;63(2):146-52. [pmid: 21561735].
1510 Arnedos M, Nerurkar A, Osin P, et al. Discordance between core needle biopsy (CNB) and excisional biopsy (EB) for estrogen receptor (ER), progesterone receptor (PgR) and HER2 status in early breast cancer (EBC). Ann Oncol. Dec. 2009;20(12):1948-52. [pmid: 19570962].
1511 Arnould L, Roger P, Macgrogan G, et al. Accuracy of HER2 status determination on breast core-needle biopsies (immunohistochemistry, FISH, CISH and SISH vs FISH). Mod Pathol. May. 2012;25(5):675-82. [pmid: 22222637].
1512 Aroner SA, Collins LC, Schnitt SJ, et al. Columnar cell lesions and subsequent breast cancer risk: a nested case-control study. Breast Cancer Res. 2010;12(4):R61. [pmid: 20691043].
1513 Arora S, Menes TS, Moung C, et al. Atypical ductal hyperplasia at margin of breast biopsy--is re-excision indicated?. Ann Surg Oncol. Mar. 2008;15(3):843-7. [pmid: 17987337].
1514 Arora S, Moezzi M, Kim U, et al. Is surgical excision necessary for atypical ductal hyperplasia diagnosed with 8 gauge stereotactic biopsy?. Breast J. Nov–Dec. 2009;15(6):673-4. [pmid: 19686226].
1515 Aruga T, Suzuki E, Saji S, et al. A low number of tumor-infiltrating FOXP3-positive cells during primary systemic chemotherapy correlates with favorable anti-tumor response in patients with breast cancer. Oncol Rep. Aug. 2009;22(2):273-8. [pmid: 19578766].
1516 Athanassiou E, Sioutopoulou D, Vamvakopoulos N, et al. The fat content of small primary breast cancer interferes with radiofrequency-induced thermal ablation. Eur Surg Res. 2009;42(1):54-8. [pmid: 18987475].
1517 Badoual C, Maruani A, Ghorra C, et al. Pathological prognostic factors of invasive breast carcinoma in ultrasound-guided large core biopsies-correlation with subsequent surgical excisions. Breast. Feb. 2005;14(1):22-7. [pmid: 15695077].
1518 Bae MS, Moon WK, Cho N, et al. Patient age and tumor size determine the cancer yield of preoperative bilateral breast MRI in women with ductal carcinoma in situ. AJR Am J Roentgenol. Sep. 2013;201(3):684-91. [pmid: 23971464].
1519 Baek SE, Kim MJ, Kim EK, et al. Effect of clinical information on diagnostic performance in breast sonography. J Ultrasound Med. Oct. 2009;28(10):1349-56. [pmid: 19778881].
1520 Baez E, Huber A, Vetter M, et al. Minimal invasive complete excision of benign breast tumors using a three-dimensional ultrasound-guided mammotome vacuum device. Ultrasound Obstet Gynecol. Mar. 2003;21(3):267-72. [pmid: 12666222].
1521 Bagaria SP, Shamonki J, Kinnaird M, et al. The florid subtype of lobular carcinoma in situ: marker or precursor for invasive lobular carcinoma?. Ann Surg Oncol. Jul. 2011;18(7):1845-51. [pmid: 21287281].
1522 Bagnall MJ, Evans AJ, Wilson AR, et al. When have mammographic calcifications been adequately sampled at needle core biopsy?. Clin Radiol. Jul. 2000;55(7):548-53. [pmid: 10924380].
1523 Bagnall MJ, Evans AJ, Wilson AR, et al. Predicting invasion in mammographically detected microcalcification. Clin Radiol. Oct. 2001;56(10):828-32. [pmid: 11895299].
1524 Bai HX, Motwani SB, Higgins SA, et al. Breast conservation therapy for ductal carcinoma in situ (DCIS): does presentation of disease affect long-term outcomes?. Int J Clin Oncol. 2013. Jun. 19. [pmid: 23780727].
1525 Bani MR, Lux MP, Heusinger K, et al. Factors correlating with reexcision after breast-conserving therapy. Eur J Surg Oncol. Jan. 2009;35(1):32-7. [pmid: 18539425].
1526 Barr FE, Degnim AC, Hartmann LC, et al. Estrogen receptor expression in atypical hyperplasia: lack of association with breast cancer. Cancer Prev Res (Phila). Mar. 2011;4(3):435-44. [pmid: 21209395].
1527 Barry WT, Kernagis DN, Dressman HK, et al. Intratumor heterogeneity and precision of microarray-based predictors of breast cancer biology and clinical outcome. J Clin Oncol. May. 1. 2010;28(13):2198-206. [pmid: 20368555].
1528 Bathen TF, Geurts B, Sitter B, et al. Feasibility of MR metabolomics for immediate analysis of resection margins during breast cancer surgery. PLoS One. 2013;8(4):e61578. [pmid: 23613877].
1529 Bauer TL, Pandelidis SM, Rhoads JE Jr. Five-year survival of 100 women with carcinoma of the breast diagnosed by screening mammography and needle-localization biopsy. J Am Coll Surg. May. 1994;178(5):427-30. [pmid: 8167877].
1530 Becker AK, Gordon PB, Harrison DA, et al. Flat ductal intraepithelial neoplasia 1A diagnosed at stereotactic core needle biopsy: is excisional biopsy indicated?. AJR Am J Roentgenol. Mar. 2013;200(3):682-8. [pmid: 23436863].
1531 Begum SM, Jara-Lazaro AR, Thike AA, et al. Mucin extravasation in breast core biopsies--clinical significance and outcome correlation. Histopathology. Nov. 2009;55(5):609-17. [pmid: 19912367].
1532 Bendifallah S, Chabbert-Buffet N, Maurin N, et al. Predictive factors for breast cancer in patients diagnosed with ductal intraepithelial neoplasia, grade 1B. Anticancer Res. Aug. 2012;32(8):3571-9. [pmid: 22843948].
1533 Bendifallah S, Defert S, Chabbert-Buffet N, et al. Scoring to predict the possibility of upgrades to malignancy in atypical ductal hyperplasia diagnosed by an 11-gauge vacuum-assisted biopsy device: an external validation study. Eur J Cancer. Jan. 2012;48(1):30-6. [pmid: 22100905].
1534 Bennett LE, Ghate SV, Bentley R, et al. Is surgical excision of core biopsy proven benign papillomas of the breast necessary?. Acad Radiol. May. 2010;17(5):553-7. [pmid: 20223685].
1535 Berg JC, Visscher DW, Vierkant RA, et al. Breast cancer risk in women with radial scars in benign breast biopsies. Breast Cancer Res Treat. Mar. 2008;108(2):167-74. [pmid: 18297395].
1536 Berg WA, Madsen KS, Schilling K, et al. Breast cancer: comparative effectiveness of positron emission mammography and MR imaging in presurgical planning for the ipsilateral breast. Radiology. Jan. 2011;258(1):59-72. [pmid: 21076089].
1537 Bernard JR Jr, Vallow LA, DePeri ER, et al. In newly diagnosed breast cancer, screening MRI of the contralateral breast detects mammographically occult cancer, even in elderly women: the mayo clinic in Florida experience. Breast J. Mar–Apr. 2010;16(2):118-26. [pmid: 20136645].
1538 Bianchi S, Bendinelli B, Castellano I, et al. Morphological parameters of lobular in situ neoplasia in stereotactic 11-gauge vacuum-assisted needle core biopsy do not predict the presence of malignancy on subsequent surgical excision. Histopathology. Jul. 2013;63(1):83-95. [pmid: 23692123].
1539 Bianchi S, Caini S, Cattani MG, et al. Diagnostic concordance in reporting breast needle core biopsies using the B classification-A panel in Italy. Pathol Oncol Res. Dec. 2009;15(4):725-32. [pmid: 19449173].
1540 Bianchi S, Giannotti E, Vanzi E, et al. Radial scar without associated atypical epithelial proliferation on image-guided 14-gauge needle core biopsy: analysis of 49 cases from a single-centre and review of the literature. Breast. Apr. 2012;21(2):159-64. [pmid: 21944431].
1541 Biggar MA, Kerr KM, Erzetich LM, et al. Columnar cell change with atypia (flat epithelial atypia) on breast core biopsy-outcomes following open excision. Breast J. Nov–Dec. 2012;18(6):578-81. [pmid: 23078374].
1542 Bode MK, Rissanen T. Imaging findings and accuracy of core needle biopsy in mucinous carcinoma of the breast. Acta Radiol. Mar. 1. 2011;52(2):128-33. [pmid: 21498339].
1543 Bode MK, Rissanen T, Apaja-Sarkkinen M. Ultrasonography-guided core needle biopsy in differential diagnosis of papillary breast tumors. Acta Radiol. Sep. 2009;50(7):722-9. [pmid: 19488890].
1544 Bodian CA, lattes R, Perzin KH. The epidemiology of gross cystic disease of the breast confirmed by biopsy or by aspiration of cyst fluid. Cancer Detect Prev. 1992;16(1):7-15. [pmid: 1551140].
1545 Bohling SD, Allison KH. Immunosuppressive regulatory T cells are associated with aggressive breast cancer phenotypes: a potential therapeutic target. Mod Pathol. Dec. 2008;21(12):1527-32. [pmid: 18820666].
1546 Bonanni B, Puntoni M, Cazzaniga M, et al. Dual effect of metformin on breast cancer proliferation in a randomized presurgical trial. J Clin Oncol. Jul. 20. 2012;30(21):2593-600. [pmid: 22564993].
1547 Bonnas C, Specht K, Spleiss O, et al. Effects of cold ischemia and inflammatory tumor microenvironment on detection of PI3K/AKT and MAPK pathway activation patterns in clinical cancer samples. Int J Cancer. Oct. 1. 2012;131(7):1621-32. [pmid: 22213219].
1548 Bonnefoi H, Piccart M, Bogaerts J, et al. TP53 status for prediction of sensitivity to taxane versus non-taxane neoadjuvant chemotherapy in breast cancer (EORTC 10994/BIG 1-00): a randomised phase 3 trial. Lancet Oncol. Jun. 2011;12(6):527-39. [pmid: 21570352].
1549 Borecky N, Rickard M. Preoperative diagnosis of carcinoma within fibroadenoma on screening mammograms. J Med Imaging Radiat Oncol. Feb. 2008;52(1):64-7. [pmid: 18373829].
1550 Boughey JC, Hartmann LC, Anderson SS, et al. Evaluation of the Tyrer-Cuzick (International Breast Cancer Intervention Study) model for breast cancer risk prediction in women with atypical hyperplasia. J Clin Oncol. Aug. 1. 2010;28(22):3591-6. [pmid: 20606088].
1551 Boulos FI, Dupont WD, Simpson JF, et al. Histologic associations and long-term cancer risk in columnar cell lesions of the breast: a retrospective cohort and a nested case-control study. Cancer. Nov. 1. 2008;113(9):2415-21. [pmid: 18816618].
1552 Bowman E, Oprea G, Okoli J, et al. Pseudoangiomatous stromal hyperplasia (PASH) of the breast: a series of 24 patients. Breast J. May–Jun. 2012;18(3):242-7. [pmid: 22583194].
1553 Braun M, Fountoulakis M, Papadopoulou A, et al. Down-regulation of microfilamental network-associated proteins in leukocytes of breast cancer patients: potential application to predictive diagnosis. Cancer Genomics Proteomics. Jan–Feb. 2009;6(1):31-40. [pmid: 19451088].
1554 Brem RF, Ioffe M, Rapelyea JA, et al. Invasive lobular carcinoma: detection with mammography, sonography, MRI, and breast-specific gamma imaging. AJR Am J Roentgenol. Feb. 2009;192(2):379-83. [pmid: 19155397].
1555 Brem RF, Shahan C, Rapleyea JA, et al. Detection of occult foci of breast cancer using breast-specific gamma imaging in women with one mammographic or clinically suspicious breast lesion. Acad Radiol. Jun. 2010;17(6):735-43. [pmid: 20457416].
1556 Brennan SB, Corben A, Liberman L, et al. Papilloma diagnosed at MRI-guided vacuum-assisted breast biopsy: is surgical excision still warranted?. AJR Am J Roentgenol. Oct. 2012;199(4):W512-9. [pmid: 22997402].
1557 Brkljacic B, Cikara I, Ivanac G, et al. Ultrasound-guided bipolar radiofrequency ablation of breast cancer in inoperable patients: a pilot study. Ultraschall Med. Apr. 2010;31(2):156-62. [pmid: 19941254].
1558 Browne EP, Punska EC, Lenington S, et al. Increased promoter methylation in exfoliated breast epithelial cells in women with a previous breast biopsy. Epigenetics. Dec. 2011;6(12):1425-35. [pmid: 22139572].
1559 Bukhari MH, Akhtar ZM. Comparison of accuracy of diagnostic modalities for evaluation of breast cancer with review of literature. Diagn Cytopathol. Jun. 2009;37(6):416-24. [pmid: 19217034].
1560 Bundred NJ, Cramer A, Morris J, et al. Cyclooxygenase-2 inhibition does not improve the reduction in ductal carcinoma in situ proliferation with aromatase inhibitor therapy: results of the ERISAC randomized placebo-controlled trial. Clin Cancer Res. Mar. 1. 2010;16(5):1605-12. [pmid: 20179229].
1561 Bunting DM, Steel JR, Holgate CS, et al. Long term follow-up and risk of breast cancer after a radial scar or complex sclerosing lesion has been identified in a benign open breast biopsy. Eur J Surg Oncol. Aug. 2011;37(8):709-13. [pmid: 21684716].
1562 Burbank F. Mammographic findings after 14-gauge automated needle and 14-gauge directional, vacuum-assisted stereotactic breast biopsies. Radiology. Jul. 1997;204(1):153-6. [pmid: 9205238].
1563 Burge CN, Chang HR, Apple SK. Do the histologic features and results of breast cancer biomarker studies differ between core biopsy and surgical excision specimens?. Breast. Apr. 2006;15(2):167-72. [pmid: 16095904].
1564 Cahill RA, Walsh D, Landers RJ, et al. Preoperative profiling of symptomatic breast cancer by diagnostic core biopsy. Ann Surg Oncol. Jan. 2006;13(1):45-51. [pmid: 16378157].
1565 Calvo-Plaza I, Ugidos L, Miro C, et al. Retrospective study assessing the role of MRI in the diagnostic procedures for early breast carcinoma: a correlation of new foci in the MRI with tumor pathological features. Clin Transl Oncol. Mar. 2013;15(3):205-10. [pmid: 22872518].
1566 Campbell I, Royle G, Coddington R, et al. Management of screen-detected breast cancer: audit of the first 100 cases in the Southampton and Salisbury breast screening programme. Ann R Coll Surg Engl. Jan. 1993;75(1):13-7. [pmid: 8422137].
1567 Cangiarella J, Guth A, Axelrod D, et al. Is surgical excision necessary for the management of atypical lobular hyperplasia and lobular carcinoma in situ diagnosed on core needle biopsy?: a report of 38 cases and review of the literature. Arch Pathol Lab Med. Jun. 2008;132(6):979-83. [pmid: 18517282].
1568 Carder PJ, Liston JC. Will the spectrum of lesions prompting a “B3” breast core biopsy increase the benign biopsy rate?. J Clin Pathol. Feb. 2003;56(2):133-8. [pmid: 12560393].
1569 Carder PJ, Shaaban A, Alizadeh Y, et al. Screen-detected pleomorphic lobular carcinoma in situ (PLCIS): risk of concurrent invasive malignancy following a core biopsy diagnosis. Histopathology. Sep. 2010;57(3):472-8. [pmid: 20727019].
1570 Carkaci S, Lane DL, Gilcrease MZ, et al. Do all mucocele-like lesions of the breast require surgery?. Clin Imaging. Mar–Apr. 2011;35(2):94-101. [pmid: 21377046].
1571 Carson W, Sanchez-Forgach E, Stomper P, et al. Lobular carcinoma in situ: observation without surgery as an appropriate therapy. Ann Surg Oncol. Mar. 1994;1(2):141-6. [pmid: 7834439].
1572 Cassano E, Urban LA, Pizzamiglio M, et al. Ultrasound-guided vacuum-assisted core breast biopsy: experience with 406 cases. Breast Cancer Res Treat. Mar. 2007;102(1):103-10. [pmid: 16838109].
1573 Catteau X, Simon P, Noel JC. Predictors of invasive breast cancer in mammographically detected microcalcification in patients with a core biopsy diagnosis of flat epithelial atypia, atypical ductal hyperplasia or ductal carcinoma in situ and recommendations for a selective approach to sentinel lymph node biopsy. Pathol Res Pract. Apr. 15. 2012;208(4):217-20. [pmid: 22445178].
1574 Caughran JL, Vicini FA, Kestin LL, et al. Optimal use of re-excision in patients diagnosed with early-stage breast cancer by excisional biopsy treated with breast-conserving therapy. Ann Surg Oncol. Nov. 2009;16(11):3020-7. [pmid: 19636632].
1575 Cavaliere A, Sidoni A, Scheibel M, et al. Biopathologic profile of breast cancer core biopsy: is it always a valid method?. Cancer Lett. Jan. 31. 2005;218(1):117-21. [pmid: 15639347].
1576 Cermik TF, Mavi A, Basu S, et al. Impact of FDG PET on the preoperative staging of newly diagnosed breast cancer. Eur J Nucl Med Mol Imaging. Mar. 2008;35(3):475-83. [pmid: 17957366].
1577 Chae BJ, Lee A, Song BJ, et al. Predictive factors for breast cancer in patients diagnosed atypical ductal hyperplasia at core needle biopsy. World J Surg Oncol. 2009;7:77. [pmid: 19852801].
1578 Chagpar AB, Martin RC 2nd, Hagendoorn LJ, et al. Lumpectomy margins are affected by tumor size and histologic subtype but not by biopsy technique. Am J Surg. Oct. 2004;188(4):399-402. [pmid: 15474434].
1579 Chagpar AB, Scoggins CR, Sahoo S, et al. Biopsy type does not influence sentinel lymph node status. Am J Surg. Oct. 2005;190(4):551-6. [pmid: 16164918].
1580 Chambon M, Orsetti B, Berthe ML, et al. Prognostic significance of TRIM24/TIF-1alpha gene expression in breast cancer. Am J Pathol. Apr. 2011;178(4):1461-9. [pmid: 21435435].
1581 Chan MY, Lim S. Predictors of invasive breast cancer in ductal carcinoma in situ initially diagnosed by core biopsy. Asian J Surg. Apr. 2010;33(2):76-82. [pmid: 21029943].
1582 Chang JM, Han W, Moon WK, et al. Papillary lesions initially diagnosed at ultrasound-guided vacuum-assisted breast biopsy: rate of malignancy based on subsequent surgical excision. Ann Surg Oncol. Sep. 2011;18(9):2506-14. [pmid: 21369740].
1583 Chang JM, Moon WK, Cho N, et al. Risk of carcinoma after subsequent excision of benign papilloma initially diagnosed with an ultrasound (US)-guided 14-gauge core needle biopsy: a prospective observational study. Eur Radiol. May. 2010;20(5):1093-100. [pmid: 19890638].
1584 Charles M, Edge SB, Winston JS, et al. Effect of stereotactic core needle biopsy on pathologic measurement of tumor size of T1 invasive breast carcinomas presenting as mammographic masses. Cancer. May. 1. 2003;97(9):2137-41. [pmid: 12712464].
1585 Charlot M, Seldin DC, O’Hara C, et al. Localized amyloidosis of the breast: a case series. Amyloid. Jun. 2011;18(2):72-5. [pmid: 21501022].
1586 Chen J, Yao Q, Li D, et al. Neoadjuvant rh-endostatin, docetaxel and epirubicin for breast cancer: efficacy and safety in a prospective, randomized, phase II study. BMC Cancer. May. 21. 2013;13(1):248. [pmid: 23693018].
1587 Chen X, Sun L, Mao Y, et al. Preoperative core needle biopsy is accurate in determining molecular subtypes in invasive breast cancer. BMC Cancer. 2013;13:390. [pmid: 23957561].
1588 Cheng TY, Chen CM, Lee MY, et al. Risk factors associated with conversion from nonmalignant to malignant diagnosis after surgical excision of breast papillary lesions. Ann Surg Oncol. Dec. 2009;16(12):3375-9. [pmid: 19641969].
1589 Cherrington BD, Mohanan S, Diep AN, et al. Comparative analysis of peptidylarginine deiminase-2 expression in canine, feline and human mammary tumours. J Comp Pathol. Aug–Oct. 2012;147(2–3):139-46. [pmid: 22520816].
1590 Cheung YC, Wan YL, Lo YF, et al. Preoperative magnetic resonance imaging evaluation for breast cancers after sonographically guided core-needle biopsy: a comparison study. Ann Surg Oncol. Aug. 2004;11(8):756-61. [pmid: 15289239].
1591 Chiesa J, Ferrer C, Arnould C, et al. Autocrine proliferative effects of hGH are maintained in primary cultures of human mammary carcinoma cells. J Clin Endocrinol Metab. Sep. 2011;96(9):E1418-26. [pmid: 21733992].
1592 Chin-Lenn L, Mack LA, Temple W, et al. Predictors of treatment with mastectomy, use of sentinel lymph node biopsy and upstaging to invasive cancer in patients diagnosed with breast ductal carcinoma in situ (DCIS) on core biopsy. Ann Surg Oncol. Jan. 2014;21(1):66-73. [pmid: 24046105].
1593 Chintamani, Tandon M, Mishra A, et al. Sentinel lymph node biopsy using dye alone method is reliable and accurate even after neo-adjuvant chemotherapy in locally advanced breast cancer--a prospective study. World J Surg Oncol. 2011;9:19. [pmid: 21396137].
1594 Chivukula M, Bhargava R, Brufsky A, et al. Clinical importance of HER2 immunohistologic heterogeneous expression in core-needle biopsies vs resection specimens for equivocal (immunohistochemical score 2+) cases. Mod Pathol. Apr. 2008;21(4):363-8. [pmid: 18246053].
1595 Chivukula M, Bhargava R, Tseng G, et al. Clinicopathologic implications of “flat epithelial atypia” in core needle biopsy specimens of the breast. Am J Clin Pathol. Jun. 2009;131(6):802-8. [pmid: 19461086].
1596 Chivukula M, Haynik DM, Brufsky A, et al. Pleomorphic lobular carcinoma in situ (PLCIS) on breast core needle biopsies: clinical significance and immunoprofile. Am J Surg Pathol. Nov. 2008;32(11):1721-6. [pmid: 18769331].
1597 Chivukula M, Striebel JM, Ersahin C, et al. Evaluation of morphologic features to identify “basal-like phenotype” on core needle biopsies of breast. Appl Immunohistochem Mol Morphol. Oct. 2008;16(5):411-6. [pmid: 18542031].
1598 Cho N, Moon WK, Chang JM, et al. Ultrasonography-guided vacuum-assisted biopsy of microcalcifications: Comparison of the diagnostic yield of calcified cores and non-calcified cores on specimen radiographs. Acta Radiol. Mar. 2010;51(2):123-7. [pmid: 19912076].
1599 Cho N, Moon WK, Chang JM, et al. Sonoelastographic lesion stiffness: preoperative predictor of the presence of an invasive focus in nonpalpable DCIS diagnosed at US-guided needle biopsy. Eur Radiol. Aug. 2011;21(8):1618-27. [pmid: 21400103].
1600 Choi J, Koo JS. Comparative study of histological features between core needle biopsy and surgical excision in phyllodes tumor. Pathol Int. Feb. 2012;62(2):120-6. [pmid: 22243782].
1601 Choi JS, Baek HM, Kim S, et al. HR-MAS MR spectroscopy of breast cancer tissue obtained with core needle biopsy: correlation with prognostic factors. PLoS One. 2012;7(12):e51712. [pmid: 23272149].
1602 Choi YJ, Ko EY, Kook S. Diagnosis of pseudoangiomatous stromal hyperplasia of the breast: ultrasonography findings and different biopsy methods. Yonsei Med J. Oct. 31. 2008;49(5):757-64. [pmid: 18972596].
1603 Choi YJ, Shin YD, Kang YH, et al. The Effects of Preoperative (18)F-FDG PET/CT in Breast Cancer Patients in Comparison to the Conventional Imaging Study. J Breast Cancer. Dec. 2012;15(4):441-8. [pmid: 23346174].
1604 Chung J, Son EJ, Kim JA, et al. Giant phyllodes tumors of the breast: imaging findings with clinicopathological correlation in 14 cases. Clin Imaging. Mar–Apr. 2011;35(2):102-7. [pmid: 21377047].
1605 Chuthapisith S, Bean BE, Cowley G, et al. Annexins in human breast cancer: Possible predictors of pathological response to neoadjuvant chemotherapy. Eur J Cancer. May. 2009;45(7):1274-81. [pmid: 19171478].
1606 Ciatto S, Houssami N. Breast imaging and needle biopsy in women with clinically evident breast cancer: does combined imaging change overall diagnostic sensitivity?. Breast. Aug. 2007;16(4):382-6. [pmid: 17350262].
1607 Ciocchetti JM, Joy N, Staller S, et al. The effect of magnetic resonance imaging in the workup of breast cancer. Am J Surg. Dec. 2009;198(6):824-8. [pmid: 19969136].
1608 Clark CJ, Wechter D. Morphea of the breast--an uncommon cause of breast erythema. Am J Surg. Jul. 2010;200(1):173-6. [pmid: 20637350].
1609 Coffey JP, Hill JC. Breast sentinel node imaging with low-dose SPECT/CT. Nucl Med Commun. Feb. 2010;31(2):107-11. [pmid: 19966597].
1610 Colleoni M, Viale G, Zahrieh D, et al. Expression of ER, PgR, HER1, HER2, and response: a study of preoperative chemotherapy. Ann Oncol. Mar. 2008;19(3):465-72. [pmid: 17986623].
1611 Collins LC, Wang Y, Connolly JL, et al. Potential role of tissue microarrays for the study of biomarker expression in benign breast disease and normal breast tissue. Appl Immunohistochem Mol Morphol. Oct. 2009;17(5):438-41. [pmid: 19363445].
1612 Connor CS, Tawfik OW, Joyce AJ, et al. A comparison of prognostic tumor markers obtained on image-guided breast biopsies and final surgical specimens. Am J Surg. Oct. 2002;184(4):322-4. [pmid: 12383893].
1613 Corben AD, Abi-Raad R, Popa I, et al. Pathologic response and long-term follow-up in breast cancer patients treated with neoadjuvant chemotherapy: a comparison between classifications and their practical application. Arch Pathol Lab Med. Aug. 2013;137(8):1074-82. [pmid: 23899063].
1614 Cote ML, Ruterbusch JJ, Alosh B, et al. Benign breast disease and the risk of subsequent breast cancer in African American women. Cancer Prev Res (Phila). Dec. 2012;5(12):1375-80. [pmid: 23087047].
1615 Crowe JP, Patrick RJ, Rim A. The importance of preoperative breast MRI for patients newly diagnosed with breast cancer. Breast J. Jan–Feb. 2009;15(1):52-60. [pmid: 19141134].
1616 Cyr AE, Novack D, Trinkaus K, et al. Are we overtreating papillomas diagnosed on core needle biopsy?. Ann Surg Oncol. Apr. 2011;18(4):946-51. [pmid: 21046266].
1617 da Silva BB, dos Santos AR, Pires CG, et al. Effect of raloxifene on vascular endothelial growth factor expression in breast carcinomas of postmenopausal women. Cell Prolif. Aug. 2009;42(4):506-10. [pmid: 19489979].
1618 Daidone MG, Orefice S, Mastore M, et al. Comparing core needle to surgical biopsies in breast cancer for cell kinetic and ploidy studies. Breast Cancer Res Treat. Sep. 1991;19(1):33-7. [pmid: 1756265].
1619 D’Alfonso T, Liu YF, Monni S, et al. Accurately assessing her-2/neu status in needle core biopsies of breast cancer patients in the era of neoadjuvant therapy: emerging questions and considerations addressed. Am J Surg Pathol. Apr. 2010;34(4):575-81. [pmid: 20216378].
1620 D’Alfonso TM, Wang K, Chiu YL, et al. Pathologic upgrade rates on subsequent excision when lobular carcinoma in situ is the primary diagnosis in the needle core biopsy with special attention to the radiographic target. Arch Pathol Lab Med. Jul. 2013;137(7):927-35. [pmid: 23808465].
1621 Darvishian F, Singh B, Simsir A, et al. Atypia on breast core needle biopsies: reproducibility and significance. Ann Clin Lab Sci. Summer. 2009;39(3):270-6. [pmid: 19667411].
1622 Dayton A, Soot L, Wolf R, et al. Light-guided lumpectomy: first clinical experience. J Biophotonics. Oct. 2011;4(10):752-8. [pmid: 21956998].
1623 de Beca FF, Rasteiro C, Correia A, et al. Improved malignancy prediction by B3 breast lesions subclassification. Ann Diagn Pathol. Oct. 2013;17(5):434-6. [pmid: 23773891].
1624 de Cremoux P, Martin EC, Vincent-Salomon A, et al. Quantitative PCR analysis of c-erb B-2 (HER2/neu) gene amplification and comparison with p185(HER2/neu) protein expression in breast cancer drill biopsies. Int J Cancer. Oct. 8. 1999;83(2):157-61. [pmid: 10471520].
1625 De Felice C, Cipolla V, Stagnitti A, et al. The impact of presurgical magnetic resonance in early breast cancer: an observational study. Eur J Gynaecol Oncol. 2012;33(2):193-9. [pmid: 22611962].
1626 Dede DS, Gumuskaya B, Guler G, et al. Evaluation of changes of biologic markers ER, PR, HER 2 and Ki-67 in breast cancer with administration of neoadjuvant dose-dense doxorubicin, cyclophosphamide followed by paclitaxel. J BUO N. Jan–Mar. 2013;18(1):57-63. [pmid: 23613389].
1627 DeMartini WB, Hanna L, Gatsonis C, et al. Evaluation of tissue sampling methods used for MRI-detected contralateral breast lesions in the American College of Radiology Imaging Network 6667 trial. AJR Am J Roentgenol. Sep. 2012;199(3):W386-91. [pmid: 22915431].
1628 Dennis MA, Parker S, Kaske TI, et al. Incidental treatment of nipple discharge caused by benign intraductal papilloma through diagnostic Mammotome biopsy. AJR Am J Roentgenol. May. 2000;174(5):1263-8. [pmid: 10789774].
1629 Deshaies I, Provencher L, Jacob S, et al. Factors associated with upgrading to malignancy at surgery of atypical ductal hyperplasia diagnosed on core biopsy. Breast. Feb. 2011;20(1):50-5. [pmid: 20619647].
1630 Destounis SV, Murphy PF, Seifert PJ, et al. Management of patients diagnosed with lobular carcinoma in situ at needle core biopsy at a community-based outpatient facility. AJR Am J Roentgenol. Feb. 2012;198(2):281-7. [pmid: 22268169].
1631 Dey P, Logasundaram R, Joshi K. Artificial neural network in diagnosis of lobular carcinoma of breast in fine-needle aspiration cytology. Diagn Cytopathol. Feb. 2013;41(2):102-6. [pmid: 21987420].
1632 Di Loreto C, Puglisi F, Rimondi G, et al. Large core biopsy for diagnostic and prognostic evaluation of invasive breast carcinomas. Eur J Cancer. Sep. 1996;32A(10):1693-700. [pmid: 8983276].
1633 Di Saverio S, Catena F, Santini D, et al. 259 Patients with DCIS of the breast applying USC/Van Nuys prognostic index: a retrospective review with long term follow up. Breast Cancer Res Treat. Jun. 2008;109(3):405-16. [pmid: 17687650].
1634 Diepstraten SC, van de Ven SM, Pijnappel RM, et al. Development and evaluation of a prediction model for underestimated invasive breast cancer in women with ductal carcinoma in situ at stereotactic large core needle biopsy. PLoS One. 2013;8(10):e77826. [pmid: 24147085].
1635 Dogan L, Gulcelik MA, Yuksel M, et al. Wire-guided localization biopsy to determine surgical margin status in patients with non-palpable suspicious breast lesions. Asian Pac J Cancer Prev. 2012;13(10):4989-92. [pmid: 23244096].
1636 Domeyer PJ, Sergentanis TN, Zagouri F, et al. Health-related quality of life in vacuum-assisted breast biopsy: short-term effects, long-term effects and predictors. Health Qual Life Outcomes. 2010;8:11. [pmid: 20102642].
1637 Domingo L, Romero A, Blanch J, et al. Clinical and radiological features of breast tumors according to history of false-positive results in mammography screening. Cancer Epidemiol. Oct. 2013;37(5):660-5. [pmid: 23962702].
1638 Dominici L, Liao GS, Brock J, et al. Large needle core biopsy of atypical ductal hyperplasia: results of surgical excision. Breast J. Sep. 2012;18(5):506-8. [pmid: 22897750].
1639 dos Santos LG, da Silva BB. The effect of raloxifene on telomerase expression in breast carcinoma samples from postmenopausal women. Eur J Obstet Gynecol Reprod Biol. Nov. 2011;159(1):165-7. [pmid: 21741149].
1640 Douglas-Jones AG, Collett N, Morgan JM, et al. Comparison of core oestrogen receptor (ER) assay with excised tumour: intratumoral distribution of ER in breast carcinoma. J Clin Pathol. Dec. 2001;54(12):951-5. [pmid: 11729216].
1641 Doyle B, Al-Mudhaffer M, Kennedy MM, et al. Sentinel lymph node biopsy in patients with a needle core biopsy diagnosis of ductal carcinoma in situ: is it justified?. J Clin Pathol. Jun. 2009;62(6):534-8. [pmid: 19190009].
1642 Dragun AE, Jenrette JM, Ackerman SJ, et al. Mammographic surveillance after MammoSite breast brachytherapy: analysis of architectural patterns and additional interventions. Am J Clin Oncol. Dec. 2007;30(6):574-9. [pmid: 18091050].
1643 Drev P, Grazio SF, Bracko M. Tissue microarrays for routine diagnostic assessment of HER2 status in breast carcinoma. Appl Immunohistochem Mol Morphol. Mar. 2008;16(2):179-84. [pmid: 18227723].
1644 Dudley DJ, Drake J, Quinlan J, et al. Beneficial effects of a combined navigator/promotora approach for Hispanic women diagnosed with breast abnormalities. Cancer Epidemiol Biomarkers Prev. Oct. 2012;21(10):1639-44. [pmid: 23045538].
1645 Dunbier AK, Anderson H, Ghazoui Z, et al. Relationship between plasma estradiol levels and estrogen-responsive gene expression in estrogen receptor-positive breast cancer in postmenopausal women. J Clin Oncol. Mar. 1. 2010;28(7):1161-7. [pmid: 20124184].
1646 Dundar MM, Badve S, Bilgin G, et al. Computerized classification of intraductal breast lesions using histopathological images. IEEE Trans Biomed Eng. Jul. 2011;58(7):1977-84. [pmid: 21296703].
1647 Dutra I, Nassif H, Page D, et al. Integrating machine learning and physician knowledge to improve the accuracy of breast biopsy. AMIA Annu Symp Proc. 2011;2011:349-55. [pmid: 22195087].
1648 Eby PR, Calhoun KE, Kurland BF, et al. Preoperative and intraoperative sonographic visibility of collagen-based breast biopsy marker clips. Acad Radiol. Mar. 2010;17(3):340-7. [pmid: 20042350].
1649 Eby PR, Ochsner JE, DeMartini WB, et al. Frequency and upgrade rates of atypical ductal hyperplasia diagnosed at stereotactic vacuum-assisted breast biopsy: 9-versus 11-gauge. AJR Am J Roentgenol. Jan. 2009;192(1):229-34. [pmid: 19098204].
1650 Edeiken-Monroe BS, Monroe DP, Monroe BJ, et al. Metastases to intramammary lymph nodes in patients with breast cancer: sonographic findings. J Clin Ultrasound. Jun. 2008;36(5):279-85. [pmid: 18366093].
1651 Edelweiss M, Corben AD, Liberman L, et al. Focal extravasated mucin in breast core needle biopsies: is surgical excision always necessary?. Breast J. May–Jun. 2013;19(3):302-9. [pmid: 23534893].
1652 Edwards HD, Oakley F, Koyama T, et al. The impact of tumor size in breast needle biopsy material on final pathologic size and tumor stage: a detailed analysis of 222 consecutive cases. Am J Surg Pathol. May. 2013;37(5):739-44. [pmid: 23552386].
1653 Ekmekcioglu O, Aliyev A, Yilmaz S, et al. Correlation of 18F-fluorodeoxyglucose uptake with histopathological prognostic factors in breast carcinoma. Nucl Med Commun. Nov. 2013;34(11):1055-67. [pmid: 24025919].
1654 El-Sayed ME, Rakha EA, Reed J, et al. Predictive value of needle core biopsy diagnoses of lesions of uncertain malignant potential (B3) in abnormalities detected by mammographic screening. Histopathology. Dec. 2008;53(6):650-7. [pmid: 19076681].
1655 El-Shinawi M, Abdelwahab SF, Sobhy M, et al. Capturing and characterizing immune cells from breast tumor microenvironment: an innovative surgical approach. Ann Surg Oncol. Oct. 2010;17(10):2677-84. [pmid: 20333554].
1656 El-Sibai MF, Cohen C, Nassar A, et al. Predictive markers in primary breast cancer compared with lymph node and bloodspread metastases. Int J Physiol Pathophysiol Pharmacol. 2009;1(1):57-63. [pmid: 21383878].
1657 El-Tamer M, Axiotis C, Kim E, et al. Accurate prediction of the amount of in situ tumor in palpable breast cancers by core needle biopsy: implications for neoadjuvant therapy. Ann Surg Oncol. Jul–Aug. 1999;6(5):461-6. [pmid: 10458684].
1658 Erggelet J, Grosse R, Holzhausen H, et al. Correlation of human epidermal growth factor receptor 2 (HER2), estrogen receptor (ER), and progesterone receptor (PR) expression as predicted by core biopsy with the immunohistochemical results of surgical breast cancer specimens. Breast Care. 2007;2(2):94-8.
1659 Erozgen F, Ersoy YE, Akaydin M, et al. Corticosteroid treatment and timing of surgery in idiopathic granulomatous mastitis confusing with breast carcinoma. Breast Cancer Res Treat. Sep. 2010;123(2):447-52. [pmid: 20625813].
1660 Fan XC, Nemoto T, Blatto K, et al. Impact of presurgical breast magnetic resonance imaging (MRI) on surgical planning - a retrospective analysis from a private radiology group. Breast J. Mar–Apr. 2013;19(2):134-41. [pmid: 23294216].
1661 Fancellu A, Soro D, Castiglia P, et al. Usefulness of magnetic resonance in patients with invasive cancer eligible for breast conservation: a comparative study. Clin Breast Cancer. Apr. 2014;14(2):114-21. [pmid: 24321101].
1662 Farshid G, Downey P, Gill P, et al. Assessment of 1183 screen-detected, category 3B, circumscribed masses by cytology and core biopsy with long-term follow up data. Br J Cancer. Apr. 8. 2008;98(7):1182-90. [pmid: 18382460].
1663 Farshid G, Walker A, Battersby G, et al. Predictors of malignancy in screen-detected breast masses with indeterminate/equivocal (grade 3) imaging features. Breast. Feb. 2011;20(1):56-61. [pmid: 20691591].
1664 Fatakdawala H, Xu J, Basavanhally A, et al. Expectation-maximization-driven geodesic active contour with overlap resolution (EMaGACOR): application to lymphocyte segmentation on breast cancer histopathology. IEEE Trans Biomed Eng. Jul. 2010;57(7):1676-89. [pmid: 20172780].
1665 Fedewa SA, Edge SB, Stewart AK, et al. Race and ethnicity are associated with delays in breast cancer treatment (2003–2006). J Health Care Poor Underserved. Feb. 2011;22(1):128-41. [pmid: 21317511].
1666 Feldman SM, Krag DN, McNally RK, et al. Limitation in gamma probe localization of the sentinel node in breast cancer patients with large excisional biopsy. J Am Coll Surg. Mar. 1999;188(3):248-54. [pmid: 10065813].
1667 Ferreira M, Albarracin CT, Resetkova E. Pseudoangiomatous stromal hyperplasia tumor: a clinical, radiologic and pathologic study of 26 cases. Mod Pathol. Feb. 2008;21(2):201-7. [pmid: 18084246].
1668 Fillion MM, Black EA, Hudson KB, et al. The effect of multiple wire localization in breast conservation. Am Surg. May. 2012;78(5):519-22. [pmid: 22546121].
1669 Fine RE, Staren ED. Percutaneous radiofrequency-assisted excision of fibroadenomas. Am J Surg. Oct. 2006;192(4):545-7. [pmid: 16978972].
1670 Flegg KM, Flaherty JJ, Bicknell AM, et al. Surgical outcomes of borderline breast lesions detected by needle biopsy in a breast screening program. World J Surg Oncol. 2010;8:78. [pmid: 20822548].
1671 Forghani MN, Memar B, Jangjoo A, et al. The effect of excisional biopsy on the accuracy of sentinel lymph node mapping in early stage breast cancer: comparison with core needle biopsy. Am Surg. Nov. 2010;76(11):1232-5. [pmid: 21140690].
1672 Friedman PD, Sanders LM, Menendez C, et al. Retrieval of lost microcalcifications during stereotactic vacuum-assisted core biopsy. AJR Am J Roentgenol. Jan. 2003;180(1):275-80. [pmid: 12490519].
1673 Fu CY, Chen TW, Hong ZJ, et al. Papillary breast lesions diagnosed by core biopsy require complete excision. Eur J Surg Oncol. Nov. 2012;38(11):1029-35. [pmid: 22959140].
1674 Fuehrer N, Hartmann L, Degnim A, et al. Atypical apocrine adenosis of the breast: long-term follow-up in 37 patients. Arch Pathol Lab Med. Feb. 2012;136(2):179-82. [pmid: 22288965].
1675 Gadre SA, Perkins GH, Sahin AA, et al. Neovascularization in mucinous ductal carcinoma in situ suggests an alternative pathway for invasion. Histopathology. Nov. 2008;53(5):545-53. [pmid: 18983463].
1676 Gao F, Carter G, Tseng G, et al. Clinical importance of histologic grading of lobular carcinoma in situ in breast core needle biopsy specimens: current issues and controversies. Am J Clin Pathol. May. 2010;133(5):767-71. [pmid: 20395524].
1677 Garcia-Manero M, Olartecoechea B, Royo P. Different injection sites of radionuclide for sentinel lymph node detection in breast cancer: single institution experience. Eur J Obstet Gynecol Reprod Biol. Dec. 2010;153(2):185-7. [pmid: 20702018].
1678 Garg S, Mohan H, Bal A, et al. A comparative analysis of core needle biopsy and fine-needle aspiration cytology in the evaluation of palpable and mammographically detected suspicious breast lesions. Diagn Cytopathol. Nov. 2007;35(11):681-9. [pmid: 17924407].
1679 Garwood ER, Kumar AS, Baehner FL, et al. Fluvastatin reduces proliferation and increases apoptosis in women with high grade breast cancer. Breast Cancer Res Treat. Jan. 2010;119(1):137-44. [pmid: 19728082].
1680 Gautier N, Lalonde L, Tran-Thanh D, et al. Chronic granulomatous mastitis: Imaging, pathology and management. Eur J Radiol. Apr. 2013;82(4):e165-75. [pmid: 23200627].
1681 Gazic B, Pizem J, Bracko M, et al. S-phase fraction determined on fine needle aspirates is an independent prognostic factor in breast cancer - a multivariate study of 770 patients. Cytopathology. Oct. 2008;19(5):294-302. [pmid: 18070112].
1682 Gemignani ML, Patil S, Seshan VE, et al. Feasibility and predictability of perioperative PET and estrogen receptor ligand in patients with invasive breast cancer. J Nucl Med. Oct. 2013;54(10):1697-702. [pmid: 23970364].
1683 Gerloff A, Dittmer A, Oerlecke I, et al. Protein expression of the Ets transcription factor Elf-1 in breast cancer cells is negatively correlated with histological grading, but not with clinical outcome. Oncol Rep. Nov. 2011;26(5):1121-5. [pmid: 21811762].
1684 Germano S, Kennedy S, Rani S, et al. MAGE-D4B is a novel marker of poor prognosis and potential therapeutic target involved in breast cancer tumorigenesis. Int J Cancer. May. 1. 2012;130(9):1991-2002. [pmid: 21618523].
1685 Gill HK, Ioffe OB, Berg WA. When is a diagnosis of sclerosing adenosis acceptable at core biopsy?. Radiology. Jul. 2003;228(1):50-7. [pmid: 12738875].
1686 Giskeodegard GF, Lundgren S, Sitter B, et al. Lactate and glycine-potential MR biomarkers of prognosis in estrogen receptor-positive breast cancers. NMR Biomed. Nov. 2012;25(11):1271-9. [pmid: 22407957].
1687 Glazebrook KN, Reynolds C, Smith RL, et al. Adenoid cystic carcinoma of the breast. AJR Am J Roentgenol. May. 2010;194(5):1391-6. [pmid: 20410430].
1688 Go EM, Chan SK, Vong JS, et al. Predictors of invasion in needle core biopsies of the breast with ductal carcinoma in situ. Mod Pathol. May. 2010;23(5):737-42. [pmid: 20081814].
1689 Gobbi H, Tse G, Page DL, et al. Reactive spindle cell nodules of the breast after core biopsy or fine-needle aspiration. Am J Clin Pathol. Feb. 2000;113(2):288-94. [pmid: 10664632].
1690 Godinez J, Gombos EC, Chikarmane SA, et al. Breast MRI in the evaluation of eligibility for accelerated partial breast irradiation. AJR Am J Roentgenol. Jul. 2008;191(1):272-7. [pmid: 18562758].
1691 Golshan M, Fung BB, Wiley E, et al. Prediction of breast cancer size by ultrasound, mammography and core biopsy. Breast. Aug. 2004;13(4):265-71. [pmid: 15325659].
1692 Goto M, Yuen S, Akazawa K, et al. The role of breast MR imaging in pre-operative determination of invasive disease for ductal carcinoma in situ diagnosed by needle biopsy. Eur Radiol. Jun. 2012;22(6):1255-64. [pmid: 22205445].
1693 Gould DJ, Salmans JA, Lassinger BK, et al. Factors associated with phyllodes tumor of the breast after core needle biopsy identifies fibroepithelial neoplasm. J Surg Res. Nov. 2012;178(1):299-303. [pmid: 22524977].
1694 Govindarajulu S, Narreddy S, Shere MH, et al. Preoperative mammotome biopsy of ducts beneath the nipple areola complex. Eur J Surg Oncol. May. 2006;32(4):410-2. [pmid: 16516432].
1695 Grady I, Gorsuch-Rafferty H, Hadley P. Preoperative staging with magnetic resonance imaging, with confirmatory biopsy, improves surgical outcomes in women with breast cancer without increasing rates of mastectomy. Breast J. May–Jun. 2012;18(3):214-8. [pmid: 22487017].
1696 Graesslin O, Antoine M, Chopier J, et al. Histology after lumpectomy in women with epithelial atypia on stereotactic vacuum-assisted breast biopsy. Eur J Surg Oncol. Feb. 2010;36(2):170-5. [pmid: 19811884].
1697 Greco FA, Spigel DR, Yardley DA, et al. Molecular profiling in unknown primary cancer: accuracy of tissue of origin prediction. Oncologist. 2010;15(5):500-6. [pmid: 20427384].
1698 Green S, Khalkhali I, Azizollahi E, et al. Excisional biopsy of borderline lesions after large bore vacuum-assisted core needle biopsy- is it necessary?. Am Surg. Oct. 2011;77(10):1358-60. [pmid: 22127088].
1699 Greer LT, Rosman M, Mylander WC, et al. Does breast tumor heterogeneity necessitate further immunohistochemical staining on surgical specimens?. J Am Coll Surg. Feb. 2013;216(2):239-51. [pmid: 23141136].
1700 Greif F, Sharon E, Shechtman I, et al. Carcinoma within solitary ductal papilloma of the breast. Eur J Surg Oncol. Apr. 2010;36(4):384-6. [pmid: 19646841].
1701 Gresik CM, Godellas C, Aranha GV, et al. Pseudoangiomatous stromal hyperplasia of the breast: a contemporary approach to its clinical and radiologic features and ideal management. Surgery. Oct. 2010;148(4):752-7. discussion 7-8. [pmid: 20708765].
1702 Grin A, O’Malley FP, Mulligan AM. Cytokeratin 5 and estrogen receptor immunohistochemistry as a useful adjunct in identifying atypical papillary lesions on breast needle core biopsy. Am J Surg Pathol. Nov. 2009;33(11):1615-23. [pmid: 19675450].
1703 Groheux D, Giacchetti S, Moretti JL, et al. Correlation of high 18F-FDG uptake to clinical, pathological and biological prognostic factors in breast cancer. Eur J Nucl Med Mol Imaging. Mar. 2011;38(3):426-35. [pmid: 21057787].
1704 Gunalp B, Ince S, Karacalioglu AO, et al. Clinical impact of (18)F-FDG PET/CT on initial staging and therapy planning for breast cancer. Exp Ther Med. Oct. 2012;4(4):693-8. [pmid: 23170128].
1705 Gutierrez RL, DeMartini WB, Silbergeld JJ, et al. High cancer yield and positive predictive value: outcomes at a center routinely using preoperative breast MRI for staging. AJR Am J Roentgenol. Jan. 2011;196(1):W93-9. [pmid: 21178040].
1706 Hahn M, Okamgba S, Scheler P, et al. Vacuum-assisted breast biopsy: a comparison of 11-gauge and 8-gauge needles in benign breast disease. World J Surg Oncol. 2008;6:51. [pmid: 18489771].
1707 Haigh PI, Hansen NM, Qi K, et al. Biopsy method and excision volume do not affect success rate of subsequent sentinel lymph node dissection in breast cancer. Ann Surg Oncol. Jan–Feb. 2000;7(1):21-7. [pmid: 10674444].
1708 Haj M, Loberant N, Salamon V, et al. Membranous fat necrosis of the breast: diagnosis by minimally invasive technique. Breast J. Nov–Dec. 2004;10(6):504-8. [pmid: 15569206].
1709 Han JS, Molberg KH, Sarode V. Predictors of invasion and axillary lymph node metastasis in patients with a core biopsy diagnosis of ductal carcinoma in situ: an analysis of 255 cases. Breast J. May–Jun. 2011;17(3):223-9. [pmid: 21545433].
1710 Hanley C, Kessaram R. Quality of diagnosis and surgical management of breast lesions in a community hospital: room for improvement?. Can J Surg. Jun. 2006;49(3):185-92. [pmid: 16749979].
1711 Hanley KZ, Birdsong GG, Cohen C, et al. Immunohistochemical detection of estrogen receptor, progesterone receptor, and human epidermal growth factor receptor 2 expression in breast carcinomas: comparison on cell block, needle-core, and tissue block preparations. Cancer. Aug. 25. 2009;117(4):279-88. [pmid: 19551847].
1712 Harada S, Mick R, Roses RE, et al. The significance of HER-2/neu receptor positivity and immunophenotype in ductal carcinoma in situ with early invasive disease. J Surg Oncol. Oct. 2011;104(5):458-65. [pmid: 21557226].
1713 Haraldsdottir KH, Ivarsson K, Gotberg S, et al. Interstitial laser thermotherapy (ILT) of breast cancer. Eur J Surg Oncol. Jul. 2008;34(7):739-45. [pmid: 18291614].
1714 Hargaden GC, Yeh ED, Georgian-Smith D, et al. Analysis of the mammographic and sonographic features of pseudoangiomatous stromal hyperplasia. AJR Am J Roentgenol. Aug. 2008;191(2):359-63. [pmid: 18647902].
1715 Harris GC, Denley HE, Pinder SE, et al. Correlation of histologic prognostic factors in core biopsies and therapeutic excisions of invasive breast carcinoma. Am J Surg Pathol. Jan. 2003;27(1):11-5. [pmid: 12502923].
1716 Harrison RL, Britton P, Warren R, et al. Can we be sure about a radiological diagnosis of fat necrosis of the breast?. Clin Radiol. Feb. 2000;55(2):119-23. [pmid: 10657157].
1717 Hasebe T, Tamura N, Iwasaki M, et al. Grading system for lymph vessel tumor emboli: significant outcome predictor for patients with invasive ductal carcinoma of the breast who received neoadjuvant therapy. Mod Pathol. Apr. 2010;23(4):581-92. [pmid: 20118911].
1718 Hayes BD, O’Doherty A, Quinn CM. Correlation of needle core biopsy with excision histology in screen-detected B3 lesions: the Merrion Breast Screening Unit experience. J Clin Pathol. Dec. 2009;62(12):1136-40. [pmid: 19946101].
1719 Hedayati E, Schedin A, Nyman H, et al. The effects of breast cancer diagnosis and surgery on cognitive functions. Acta Oncol. Oct. 2011;50(7):1027-36. [pmid: 21554027].
1720 Heudel P, Cimarelli S, Montella A, et al. Value of PET-FDG in primary breast cancer based on histopathological and immunohistochemical prognostic factors. Int J Clin Oncol. Dec. 2010;15(6):588-93. [pmid: 20809217].
1721 Hiraike H, Wada-Hiraike O, Nakagawa S, et al. Expression of DBC1 is associated with nuclear grade and HER2 expression in breast cancer. Exp Ther Med. Nov. 2011;2(6):1105-9. [pmid: 22977628].
1722 Hoang JK, Hill P, Cawson JN. Can mammographic findings help discriminate between atypical ductal hyperplasia and ductal carcinoma in situ after needle core biopsy?. Breast. Jun. 2008;17(3):282-8. [pmid: 18063369].
1723 Holley SO, Appleton CM, Farria DM, et al. Pathologic outcomes of nonmalignant papillary breast lesions diagnosed at imaging-guided core needle biopsy. Radiology. Nov. 2012;265(2):379-84. [pmid: 22952379].
1724 Hollingsworth AB, Stough RG. Multicentric and contralateral invasive tumors identified with pre-op MRI in patients newly diagnosed with ductal carcinoma in situ of the breast. Breast J. Sep. 2012;18(5):420-7. [pmid: 22804792].
1725 Holmes DR, Silverstein MJ. A minimally invasive breast biopsy clinic: an innovative way to teach breast fellows how to perform breast ultrasound and ultrasound-guided breast procedures. Am J Surg. Oct. 2006;192(4):439-43. [pmid: 16978945].
1726 Hong ZJ, Chu CH, Fan HL, et al. Factors predictive of breast cancer in open biopsy in cases with atypical ductal hyperplasia diagnosed by ultrasound-guided core needle biopsy. Eur J Surg Oncol. Sep. 2011;37(9):758-64. [pmid: 21764539].
1727 Horiguchi K, Toi M, Horiguchi S, et al. Predictive value of CD24 and CD44 for neoadjuvant chemotherapy response and prognosis in primary breast cancer patients. J Med Dent Sci. Jun. 2010;57(2):165-75. [pmid: 21073135].
1728 Horimoto Y, Tokuda E, Arakawa A, et al. Significance of HER2 protein examination in ductal carcinoma in situ. J Surg Res. May. 15. 2011;167(2):e205-10. [pmid: 20018297].
1729 Houssami N, Ambrogetti D, Marinovich ML, et al. Accuracy of a preoperative model for predicting invasive breast cancer in women with ductal carcinoma-in-situ on vacuum-assisted core needle biopsy. Ann Surg Oncol. May. 2011;18(5):1364-71. [pmid: 21107741].
1730 Houssami N, Ciatto S, Ellis I, et al. Underestimation of malignancy of breast core-needle biopsy: concepts and precise overall and category-specific estimates. Cancer. Feb. 1. 2007;109(3):487-95. [pmid: 17186530].
1731 Hovanessian Larsen LJ, Peyvandi B, Klipfel N, et al. Granulomatous lobular mastitis: imaging, diagnosis, and treatment. AJR Am J Roentgenol. Aug. 2009;193(2):574-81. [pmid: 19620458].
1732 Hsu HH, Yu JC, Hsu GC, et al. Atypical ductal hyperplasia of the breast diagnosed by ultrasonographically guided core needle biopsy. Ultraschall Med. Oct. 2012;33(5):447-54. [pmid: 22161618].
1733 Huang CH, Veillard A, Roux L, et al. Time-efficient sparse analysis of histopathological whole slide images. Comput Med Imaging Graph. Oct–Dec. 2011;35(7–8):579-91. [pmid: 21145705].
1734 Huang O, Chen C, Wu J, et al. Retrospective analysis of 119 Chinese noninflammatory locally advanced breast cancer cases treated with intravenous combination of vinorelbine and epirubicin as a neoadjuvant chemotherapy: a median follow-up of 63.4 months. BMC Cancer. 2009;9:375. [pmid: 19845944].
1735 Huang YT, Cheung YC, Lo YF, et al. MRI findings of cancers preoperatively diagnosed as pure DCIS at core needle biopsy. Acta Radiol. Dec. 1. 2011;52(10):1064-8. [pmid: 21969708].
1736 Hukkinen K, Kivisaari L, Heikkila PS, et al. Unsuccessful preoperative biopsies, fine needle aspiration cytology or core needle biopsy, lead to increased costs in the diagnostic workup in breast cancer. Acta Oncol. 2008;47(6):1037-45. [pmid: 18607862].
1737 Hung WK, Ying M, Chan M, et al. The impact of sentinel lymph node biopsy in patients with a core biopsy diagnosis of ductal carcinoma in situ. Breast Cancer. Oct. 2010;17(4):276-80. [pmid: 19756924].
1738 Hunt RJ, Steel JR, Porter GJ, et al. Lesions of uncertain malignant potential (B3) on core biopsy in the NHS Breast Screening Programme: is the screening round relevant?. Ann R Coll Surg Engl. Mar. 2012;94(2):108-11. [pmid: 22391380].
1739 Ibrahim N, Bessissow A, Lalonde L, et al. Surgical outcome of biopsy-proven lobular neoplasia: is there any difference between lobular carcinoma in situ and atypical lobular hyperplasia?. AJR Am J Roentgenol. Feb. 2012;198(2):288-91. [pmid: 22268170].
1740 Ilic I, Randelovic P, Ilic R, et al. An approach to malignant mammary phyllodes tumors detection. Vojnosanit Pregl. Apr. 2009;66(4):277-82. [pmid: 19441158].
1741 Ingegnoli A, d’Aloia C, Frattaruolo A, et al. Flat epithelial atypia and atypical ductal hyperplasia: carcinoma underestimation rate. Breast J. Jan–Feb. 2010;16(1):55-9. [pmid: 19825003].
1742 Inoue S, Inoue M, Kawasaki T, et al. Six cases showing radial scar/complex sclerosing lesions of the breast detected by breast cancer screening. Breast Cancer. 2008;15(3):247-51. [pmid: 18311480].
1743 Inui H, Watatani M, Hashimoto Y, et al. Hematoma-directed and ultrasound-guided breast-conserving surgery for nonpalpable breast cancer after Mammotome biopsy. Surg Today. 2008;38(3):279-82. [pmid: 18307007].
1744 Irfan K, Brem RF. Surgical and mammographic follow-up of papillary lesions and atypical lobular hyperplasia diagnosed with stereotactic vacuum-assisted biopsy. Breast J. Jul–Aug. 2002;8(4):230-3. [pmid: 12100116].
1745 Itakura K, Lessing J, Sakata T, et al. The impact of preoperative magnetic resonance imaging on surgical treatment and outcomes for ductal carcinoma in situ. Clin Breast Cancer. Mar. 2011;11(1):33-8. [pmid: 21421520].
1746 Jackman RJ, Burbank F, Parker SH, et al. Atypical ductal hyperplasia diagnosed at stereotactic breast biopsy: improved reliability with 14-gauge, directional, vacuum-assisted biopsy. Radiology. Aug. 1997;204(2):485-8. [pmid: 9240540].
1747 Jackman RJ, Marzoni FA Jr, Nowels KW. Percutaneous removal of benign mammographic lesions: comparison of automated large-core and directional vacuum-assisted stereotactic biopsy techniques. AJR Am J Roentgenol. Nov. 1998;171(5):1325-30. [pmid: 9798873].
1748 Jaffer S, Bleiweiss IJ, Nagi CS. Benign mucocele-like lesions of the breast: revisited. Mod Pathol. May. 2011;24(5):683-7. [pmid: 21240257].
1749 Jaffer S, Nagi C, Bleiweiss IJ. Excision is indicated for intraductal papilloma of the breast diagnosed on core needle biopsy. Cancer. Jul. 1. 2009;115(13):2837-43. [pmid: 19402174].
1750 Jaka RC, Zaveri SS, Somashekhar SP, et al. Value of frozen section and primary tumor factors in determining sentinel lymph node spread in early breast carcinoma. Indian J Surg Oncol. Jan. 2010;1(1):27-36. [pmid: 22930615].
1751 Jakate K, De Brot M, Goldberg F, et al. Papillary lesions of the breast: impact of breast pathology subspecialization on core biopsy and excision diagnoses. Am J Surg Pathol. Apr. 2012;36(4):544-51. [pmid: 22314186].
1752 James TA, Mace JL, Virnig BA, et al. Preoperative needle biopsy improves the quality of breast cancer surgery. J Am Coll Surg. Oct. 2012;215(4):562-8. [pmid: 22726895].
1753 Jimenez RE, Bongers S, Bouwman D, et al. Clinicopathologic significance of ductal carcinoma in situ in breast core needle biopsies with invasive cancer. Am J Surg Pathol. Jan. 2000;24(1):123-8. [pmid: 10632496].
1754 Jones RJ, Young O, Renshaw L, et al. Src inhibitors in early breast cancer: a methodology, feasibility and variability study. Breast Cancer Res Treat. Mar. 2009;114(2):211-21. [pmid: 18409068].
1755 Jorgensen TJ, Helzlsouer KJ, Clipp SC, et al. DNA repair gene variants associated with benign breast disease in high cancer risk women. Cancer Epidemiol Biomarkers Prev. Jan. 2009;18(1):346-50. [pmid: 19124519].
1756 Jung SY, Kang HS, Kwon Y, et al. Risk factors for malignancy in benign papillomas of the breast on core needle biopsy. World J Surg. Feb. 2010;34(2):261-5. [pmid: 19997916].
1757 Kadivar M, Monabati A, Joulaee A, et al. Epstein-Barr virus and breast cancer: lack of evidence for an association in Iranian women. Pathol Oncol Res. Sep. 2011;17(3):489-92. [pmid: 21207256].
1758 Kalles V, Zografos GC, Provatopoulou X, et al. Circulating levels of endothelin-1 (ET-1) and its precursor (Big ET-1) in breast cancer early diagnosis. Tumour Biol. Aug. 2012;33(4):1231-6. [pmid: 22415226].
1759 Kaneko S, Gerasimova T, Butler WM, et al. The use of FISH on breast core needle samples for the presurgical assessment of HER-2 oncogene status. Exp Mol Pathol. Aug. 2002;73(1):61-6. [pmid: 12127055].
1760 Kaya H, Ragazzini T, Aribal E, et al. Her-2/neu gene amplification compared with HER-2/neu protein overexpression on ultrasound guided core-needle biopsy specimens of breast carcinoma. Pathol Oncol Res. 2001;7(4):279-83. [pmid: 11882907].
1761 Keto JL, Kirstein L, Sanchez DP, et al. MRI versus breast-specific gamma imaging (BSGI) in newly diagnosed ductal cell carcinoma-in-situ: a prospective head-to-head trial. Ann Surg Oncol. Jan. 2012;19(1):249-52. [pmid: 21739318].
1762 Khoumais NA, Scaranelo AM, Moshonov H, et al. Incidence of breast cancer in patients with pure flat epithelial atypia diagnosed at core-needle biopsy of the breast. Ann Surg Oncol. Jan. 2013;20(1):133-8. [pmid: 23064777].
1763 Khoury T, Zakharia Y, Tan W, et al. Breast hormonal receptors test should be repeated on excisional biopsy after negative core needle biopsy. Breast J. Mar–Apr. 2011;17(2):180-6. [pmid: 21306471].
1764 Khout H, Mohiuddin MK, Veeratterapillay R, et al. Breast cancer mimicking fibroadenomas in postmenopausal women. Int J Surg. 2011;9(1):2-4. [pmid: 20804869].
1765 Kibil W, Hodorowicz-Zaniewska D, Popiela TJ, et al. Vacuum-assisted core biopsy in diagnosis and treatment of intraductal papillomas. Clin Breast Cancer. Apr. 2013;13(2):129-32. [pmid: 23127339].
1766 Killelea BK, Gillego A, Kirstein LJ, et al. George Peters Award: How does breast-specific gamma imaging affect the management of patients with newly diagnosed breast cancer?. Am J Surg. Oct. 2009;198(4):470-4. [pmid: 19800450].
1767 Killelea BK, Grube BJ, Rishi M, et al. Is the use of preoperative breast MRI predictive of mastectomy?. World J Surg Oncol. 2013;11:154. [pmid: 23849218].
1768 Kim BS, Moon BI, Cha ES. A comparative study of breast-specific gamma imaging with the conventional imaging modality in breast cancer patients with dense breasts. Ann Nucl Med. Dec. 2012;26(10):823-9. [pmid: 22922890].
1769 Kim HS, Seok JH, Cha ES, et al. Significance of nipple enhancement of Paget’s disease in contrast enhanced breast MRI. Arch Gynecol Obstet. Aug. 2010;282(2):157-62. [pmid: 19838723].
1770 Kim J, Han W, Go EY, et al. Validation of a scoring system for predicting malignancy in patients diagnosed with atypical ductal hyperplasia using an ultrasound-guided core needle biopsy. J Breast Cancer. Dec. 2012;15(4):407-11. [pmid: 23346169].
1771 Kim J, Han W, Lee JW, et al. Factors associated with upstaging from ductal carcinoma in situ following core needle biopsy to invasive cancer in subsequent surgical excision. Breast. Oct. 2012;21(5):641-5. [pmid: 22749854].
1772 Kim MJ, Kim EK, Kwak JY, et al. Sonographic surveillance for the detection of contralateral metachronous breast cancer in an Asian population. AJR Am J Roentgenol. Jan. 2009;192(1):221-8. [pmid: 19098203].
1773 Kim MJ, Kim SI, Youk JH, et al. The diagnosis of non-malignant papillary lesions of the breast: comparison of ultrasound-guided automated gun biopsy and vacuum-assisted removal. Clin Radiol. Jun. 2011;66(6):530-5. [pmid: 21353213].
1774 Kim SM, Kim HH, Kang DK, et al. Mucocele-like tumors of the breast as cystic lesions: sonographic-pathologic correlation. AJR Am J Roentgenol. Jun. 2011;196(6):1424-30. [pmid: 21606308].
1775 Kim T, Jung EA, Song JY, et al. Prevalence of the CTNNB1 mutation genotype in surgically resected fibromatosis of the breast. Histopathology. Jan. 2012;60(2):347-56. [pmid: 22211293].
1776 Kimmick GG, Cirrincione C, Duggan DB, et al. Fifteen-year median follow-up results after neoadjuvant doxorubicin, followed by mastectomy, followed by adjuvant cyclophosphamide, methotrexate, and fluorouracil (CMF) followed by radiation for stage III breast cancer: a phase II trial (CALGB 8944). Breast Cancer Res Treat. Feb. 2009;113(3):479-90. [pmid: 18306034].
1777 Kinoshita T, Iwamoto E, Tsuda H, et al. Radiofrequency ablation as local therapy for early breast carcinomas. Breast Cancer. Jan. 2011;18(1):10-7. [pmid: 20072824].
1778 Klimberg VS, Boneti C, Adkins LL, et al. Feasibility of percutaneous excision followed by ablation for local control in breast cancer. Ann Surg Oncol. Oct. 2011;18(11):3079-87. [pmid: 21904959].
1779 Ko E, Han W, Lee JW, et al. Scoring system for predicting malignancy in patients diagnosed with atypical ductal hyperplasia at ultrasound-guided core needle biopsy. Breast Cancer Res Treat. Nov. 2008;112(1):189-95. [pmid: 18060577].
1780 Ko EY, Bae YA, Kim MJ, et al. Factors affecting the efficacy of ultrasound-guided vacuum-assisted percutaneous excision for removal of benign breast lesions. J Ultrasound Med. Jan. 2008;27(1):65-73. [pmid: 18096732].
1781 Koh C, Nelson JM, Cook PF. Evaluation of a patient navigation program. Clin J Oncol Nurs. Feb. 2011;15(1):41-8. [pmid: 21278040].
1782 Kohr JR, Eby PR, Allison KH, et al. Risk of upgrade of atypical ductal hyperplasia after stereotactic breast biopsy: effects of number of foci and complete removal of calcifications. Radiology. Jun. 2010;255(3):723-30. [pmid: 20173103].
1783 Kok KY, Telisinghe PU. Granulomatous mastitis: presentation, treatment and outcome in 43 patients. Surgeon. Aug. 2010;8(4):197-201. [pmid: 20569938].
1784 Koo JS, Han K, Kim MJ, et al. Can additional immunohistochemistry staining replace the surgical excision for the diagnosis of papillary breast lesions classified as benign on 14-gage core needle biopsy?. Breast Cancer Res Treat. Feb. 2013;137(3):797-806. [pmid: 23292118].
1785 Koo JS, Jung W. Xanthogranulomatous mastitis: clinicopathology and pathological implications. Pathol Int. Apr. 2009;59(4):234-40. [pmid: 19351366].
1786 Koo JS, Kim MJ, Kim EK, et al. Factors in the breast core needle biopsies of atypical ductal hyperplasia that can predict carcinoma in the subsequent surgical excision specimens. J Breast Cancer. 2010;13(2):132-7.
1787 Koo JS, Kim MJ, Kim EK, et al. Comparison of immunohistochemical staining in breast papillary neoplasms of cytokeratin 5/6 and p63 in core needle biopsies and surgical excisions. Appl Immunohistochem Mol Morphol. Mar. 2012;20(2):108-15. [pmid: 22553810].
1788 Kostopoulos S, Glotsos D, Cavouras D, et al. Computer-based association of the texture of expressed estrogen receptor nuclei with histologic grade using immunohistochemically-stained breast carcinomas. Anal Quant Cytol Histol. Aug. 2009;31(4):187-96. [pmid: 19736866].
1789 Krainick-Strobel U, Huber B, Majer I, et al. Complete extirpation of benign breast lesions with an ultrasound-guided vacuum biopsy system. Ultrasound in obstetrics & gynecology. 2007;29(3):342-6. [pmid: 17167817].
1790 Kremer ME, Downs-Holmes C, Novak RD, et al. Neglecting to screen women between the ages of 40 and 49 years with mammography: what is the impact on breast cancer diagnosis?. AJR Am J Roentgenol. May. 2012;198(5):1218-22. [pmid: 22528917].
1791 Kryvenko ON, Chitale DA, VanEgmond EM, et al. Angiolipoma of the female breast: clinicomorphological correlation of 52 cases. Int J Surg Pathol. Feb. 2011;19(1):35-43. [pmid: 21087987].
1792 Kundu UR, Guo M, Landon G, et al. Fine-needle aspiration cytology of sclerosing adenosis of the breast: a retrospective review of cytologic features in conjunction with corresponding histologic features and radiologic findings. Am J Clin Pathol. Jul. 2012;138(1):96-102. [pmid: 22706864].
1793 Kunju LP, Cookingham C, Toy KA, et al. EZH2 and ALDH-1 mark breast epithelium at risk for breast cancer development. Mod Pathol. Jun. 2011;24(6):786-93. [pmid: 21399615].
1794 Kurita T, Tsuchiya S, Watarai Y, et al. Roles of fine-needle aspiration and core needle biopsy in the diagnosis of breast cancer. Breast Cancer. Jan. 2012;19(1):23-9. [pmid: 21298376].
1795 Kurniawan ED, Rose A, Mou A, et al. Risk factors for invasive breast cancer when core needle biopsy shows ductal carcinoma in situ. Arch Surg. Nov. 2010;145(11):1098-104. [pmid: 21079099].
1796 Kurniawan ED, Wong MH, Windle I, et al. Predictors of surgical margin status in breast-conserving surgery within a breast screening program. Ann Surg Oncol. Sep. 2008;15(9):2542-9. [pmid: 18618180].
1797 Kurz KD, Roy S, Saleh A, et al. MRI features of intraductal papilloma of the breast: sheep in wolf’s clothing?. Acta Radiol. Apr. 1. 2011;52(3):264-72. [pmid: 21498361].
1798 Kushwaha AC, O’Toole M, Sneige N, et al. Mammographic-pathologic correlation of apocrine metaplasia diagnosed using vacuum-assisted stereotactic core-needle biopsy: our 4-year experience. AJR Am J Roentgenol. Mar. 2003;180(3):795-8. [pmid: 12591698].
1799 Kvasnovsky CL, Kesmodel SB, Gragasin JL, et al. Expansion of screening mammography in the Veterans Health Administration: implications for breast cancer treatment. JAMA Surg. Nov. 2013;148(11):999-1004. [pmid: 24048217].
1800 Kwok KMK, Lui CY, Fung PYE, et al. Incidence, causes, and implications of unsuccessful calcification retrieval at stereotactic breast biopsy - 5 years’ experience. J. HK Coll Radiol. 2009;11(4):154-60.
1801 Kwok TC, Rakha EA, Lee AH, et al. Histological grading of breast cancer on needle core biopsy: the role of immunohistochemical assessment of proliferation. Histopathology. Aug. 2010;57(2):212-9. [pmid: 20716163].
1802 Lacambra MD, Lam CC, Mendoza P, et al. Biopsy sampling of breast lesions: comparison of core needle- and vacuum-assisted breast biopsies. Breast Cancer Res Treat. Apr. 2012;132(3):917-23. [pmid: 21698409].
1803 Lau B, Romero LM. Does preoperative magnetic resonance imaging beneficially alter surgical management of invasive lobular carcinoma?. Am Surg. Oct. 2011;77(10):1368-71. [pmid: 22127091].
1804 Lau K, Lui C, Tee L, et al. Role of Breast Magnetic Resonance Imaging in the Preoperative Assessment and Its Impact on Surgical Management of Patients with Newly Diagnosed Breast Cancer.
1805 Lavoue V, Roger CM, Poilblanc M, et al. Pure flat epithelial atypia (DIN 1a) on core needle biopsy: study of 60 biopsies with follow-up surgical excision. Breast Cancer Res Treat. Jan. 2011;125(1):121-6. [pmid: 20945087].
1806 Law Y, Cheung PS, Lau S, et al. Impact of magnetic resonance imaging on preoperative planning for breast cancer surgery. Hong Kong Med J. Aug. 2013;19(4):294-9. [pmid: 23832947].
1807 Lebeau A, Turzynski A, Braun S, et al. Reliability of human epidermal growth factor receptor 2 immunohistochemistry in breast core needle biopsies. J Clin Oncol. Jul. 10. 2010;28(20):3264-70. [pmid: 20498397].
1808 Lee AH, Denley HE, Pinder SE, et al. Excision biopsy findings of patients with breast needle core biopsies reported as suspicious of malignancy (B4) or lesion of uncertain malignant potential (B3). Histopathology. Apr. 2003;42(4):331-6. [pmid: 12653944].
1809 Lee AH, Key HP, Bell JA, et al. Concordance of HER2 status assessed on needle core biopsy and surgical specimens of invasive carcinoma of the breast. Histopathology. May. 2012;60(6):880-4. [pmid: 22320892].
1810 Lee AH, Rakha EA, Hodi Z, et al. Re-audit of revised method for assessing the mitotic component of histological grade in needle core biopsies of invasive carcinoma of the breast. Histopathology. Jun. 2012;60(7):1166-7. [pmid: 22385388].
1811 Lee CH, Philpotts LE, Horvath LJ, et al. Follow-up of breast lesions diagnosed as benign with stereotactic core-needle biopsy: frequency of mammographic change and false-negative rate. Radiology. Jul. 1999;212(1):189-94. [pmid: 10405741].
1812 Lee E, Wylie E, Metcalf C. Ultrasound imaging features of radial scars of the breast. Australas Radiol. Jun. 2007;51(3):240-5. [pmid: 17504315].
1813 Lee JW, Han W, Ko E, et al. Sonographic lesion size of ductal carcinoma in situ as a preoperative predictor for the presence of an invasive focus. J Surg Oncol. Jul. 1. 2008;98(1):15-20. [pmid: 18459155].
1814 Lee KA, Zuley ML, Chivukula M, et al. Risk of malignancy when microscopic radial scars and microscopic papillomas are found at percutaneous biopsy. AJR Am J Roentgenol. Feb. 2012;198(2):W141-5. [pmid: 22268203].
1815 Lee TY, Macintosh RF, Rayson D, et al. Flat epithelial atypia on breast needle core biopsy: a retrospective study with clinical-pathological correlation. Breast J. Jul–Aug. 2010;16(4):377-83. [pmid: 20459431].
1816 Leidenius MH, Vironen JH, von Smitten KA, et al. The outcome of sentinel node biopsy in breast cancer patients with preoperative surgical biopsy. J Surg Oncol. Jun. 1. 2009;99(7):420-3. [pmid: 19350567].
1817 Lewis JL, Lee DY, Tartter PI. The significance of lobular carcinoma in situ and atypical lobular hyperplasia of the breast. Ann Surg Oncol. Dec. 2012;19(13):4124-8. [pmid: 22847126].
1818 Li J, Dershaw DD, Lee CH, et al. MRI follow-up after concordant, histologically benign diagnosis of breast lesions sampled by MRI-guided biopsy. AJR Am J Roentgenol. Sep. 2009;193(3):850-5. [pmid: 19696301].
1819 Li JL, Wang ZL, Su L, et al. Breast lesions with ultrasound imaging-histologic discordance at 16-gauge core needle biopsy: can re-biopsy with 10-gauge vacuum-assisted system get definitive diagnosis?. Breast. Dec. 2010;19(6):446-9. [pmid: 20869243].
1820 Li S, Wu J, Chen K, et al. Clinical outcomes of 1,578 Chinese patients with breast benign diseases after ultrasound-guided vacuum-assisted excision: recurrence and the risk factors. Am J Surg. Jan. 2013;205(1):39-44. [pmid: 23040695].
1821 Li SP, Padhani AR, Taylor NJ, et al. Vascular characterisation of triple negative breast carcinomas using dynamic MRI. Eur Radiol. Jul. 2011;21(7):1364-73. [pmid: 21258931].
1822 Li X, Deavers MT, Guo M, et al. The effect of prolonged cold ischemia time on estrogen receptor immunohistochemistry in breast cancer. Mod Pathol. Jan. 2013;26(1):71-8. [pmid: 22899286].
1823 Li X, Weaver O, Desouki MM, et al. Microcalcification is an important factor in the management of breast intraductal papillomas diagnosed on core biopsy. Am J Clin Pathol. Dec. 2012;138(6):789-95. [pmid: 23161711].
1824 Liberman L, Cody HS 3rd. Percutaneous biopsy and sentinel lymphadenectomy: minimally invasive diagnosis and treatment of nonpalpable breast cancer. AJR Am J Roentgenol. Oct. 2001;177(4):887-91. [pmid: 11566696].
1825 Liberman L, Cody HS 3rd, Hill AD, et al. Sentinel lymph node biopsy after percutaneous diagnosis of nonpalpable breast cancer. Radiology. Jun. 1999;211(3):835-44. [pmid: 10352613].
1826 Liberman L, Dershaw DD, Rosen PP, et al. Stereotaxic core biopsy of breast carcinoma: accuracy at predicting invasion. Radiology. Feb. 1995;194(2):379-81. [pmid: 7824713].
1827 Liberman L, Morris EA, Dershaw DD, et al. MR imaging of the ipsilateral breast in women with percutaneously proven breast cancer. AJR Am J Roentgenol. Apr. 2003;180(4):901-10. [pmid: 12646427].
1828 Liberman L, Zakowski MF, Avery S, et al. Complete percutaneous excision of infiltrating carcinoma at stereotactic breast biopsy: how can tumor size be assessed?. AJR Am J Roentgenol. Nov. 1999;173(5):1315-22. [pmid: 10541111].
1829 Lieberman S, Sella T, Maly B, et al. Breast magnetic resonance imaging characteristics in women with occult primary breast carcinoma. Isr Med Assoc J. Jun. 2008;10(6):448-52. [pmid: 18669145].
1830 Lieske B, Ravichandran D, Alvi A, et al. Screen-detected breast lesions with an indeterminate (B3) core needle biopsy should be excised. Eur J Surg Oncol. Dec. 2008;34(12):1293-8. [pmid: 18162359].
1831 Lieu D. Value of cytopathologist-performed ultrasound-guided fine-needle aspiration as a screening test for ultrasound-guided core-needle biopsy in nonpalpable breast masses. Diagn Cytopathol. Apr. 2009;37(4):262-9. [pmid: 19217029].
1832 Lin SJ, Cawson J, Hill P, et al. Image-guided sampling reveals increased stroma and lower glandular complexity in mammographically dense breast tissue. Breast Cancer Res Treat. Jul. 2011;128(2):505-16. [pmid: 21258862].
1833 Lind DS, Minter R, Steinbach B, et al. Stereotactic core biopsy reduces the reexcision rate and the cost of mammographically detected cancer. Journal of Surgical Research. 1998;78(1):23-6. [pmid: 9733612].
1834 Linda A, Zuiani C, Bazzocchi M, et al. Borderline breast lesions diagnosed at core needle biopsy: can magnetic resonance mammography rule out associated malignancy? Preliminary results based on 79 surgically excised lesions. Breast. Apr. 2008;17(2):125-31. [pmid: 18083514].
1835 Linda A, Zuiani C, Furlan A, et al. Radial scars without atypia diagnosed at imaging-guided needle biopsy: how often is associated malignancy found at subsequent surgical excision, and do mammography and sonography predict which lesions are malignant?. AJR Am J Roentgenol. Apr. 2010;194(4):1146-51. [pmid: 20308524].
1836 Linda A, Zuiani C, Furlan A, et al. Nonsurgical management of high-risk lesions diagnosed at core needle biopsy: can malignancy be ruled out safely with breast MRI?. AJR Am J Roentgenol. Feb. 2012;198(2):272-80. [pmid: 22268168].
1837 Linda A, Zuiani C, Londero V, et al. What to do with B3 lesions at needle biopsy. Eur J Radiol. Sep. 2012;81(Suppl 1):S90-2. [pmid: 23083618].
1838 Ling CM, Coffey CM, Rapelyea JA, et al. Breast-specific gamma imaging in the detection of atypical ductal hyperplasia and lobular neoplasia. Acad Radiol. Jun. 2012;19(6):661-6. [pmid: 22578225].
1839 Lips EH, Mukhtar RA, Yau C, et al. Lobular histology and response to neoadjuvant chemotherapy in invasive breast cancer. Breast Cancer Res Treat. Nov. 2012;136(1):35-43. [pmid: 22961065].
1840 Londero V, Zuiani C, Linda A, et al. Borderline breast lesions: comparison of malignancy underestimation rates with 14-gauge core needle biopsy versus 11-gauge vacuum-assisted device. Eur Radiol. Jun. 2011;21(6):1200-6. [pmid: 21225267].
1841 Londero V, Zuiani C, Linda A, et al. High-risk breast lesions at imaging-guided needle biopsy: usefulness of MRI for treatment decision. AJR Am J Roentgenol. Aug. 2012;199(2):W240-50. [pmid: 22826427].
1842 Lopes-Costa PV, dos Santos AR, dos Santos LG, et al. Evaluation of Ki-67 and Bcl-2 antigen expression in breast carcinomas of women treated with raloxifene. Cell Prolif. Apr. 2010;43(2):124-9. [pmid: 20447057].
1843 Lorenzetti MA, De Matteo E, Gass H, et al. Characterization of Epstein Barr virus latency pattern in Argentine breast carcinoma. PLoS One. 2010;5(10):e13603. [pmid: 21042577].
1844 Lorgis V, Algros MP, Villanueva C, et al. Discordance in early breast cancer for tumour grade, estrogen receptor, progesteron receptors and human epidermal receptor-2 status between core needle biopsy and surgical excisional primary tumour. Breast. Jun. 2011;20(3):284-7. [pmid: 21288720].
1845 Lu Q, Tan EY, Ho B, et al. Surgical excision of intraductal breast papilloma diagnosed on core biopsy. ANZ J Surg. Mar. 2012;82(3):168-72. [pmid: 22510128].
1846 Lyon DE, McCain NL, Walter J, et al. Cytokine comparisons between women with breast cancer and women with a negative breast biopsy. Nurs Res. Jan–Feb. 2008;57(1):51-8. [pmid: 18091292].
1847 Macaskill EJ, Bartlett JM, Sabine VS, et al. The mammalian target of rapamycin inhibitor everolimus (RAD001) in early breast cancer: results of a pre-operative study. Breast Cancer Res Treat. Aug. 2011;128(3):725-34. [pmid: 20941539].
1848 Macaskill EJ, Purdie CA, Jordan LB, et al. Axillary lymph node core biopsy for breast cancer metastases -- how many needle passes are enough?. Clin Radiol. May. 2012;67(5):417-9. [pmid: 22119100].
1849 Majewski SA, Zuley ML, Pinnamaneni N, et al. Frequency of carcinoma at secondary imaging-guided percutaneous breast biopsy performed after a high-risk pathologic result at primary biopsy. AJR Am J Roentgenol. Aug. 2013;201(2):439-47. [pmid: 23883227].
1850 Manenti G, Bolacchi F, Perretta T, et al. Small breast cancers: in vivo percutaneous US-guided radiofrequency ablation with dedicated cool-tip radiofrequency system. Radiology. May. 2009;251(2):339-46. [pmid: 19304918].
1851 Manfrin E, Mariotto R, Remo A, et al. Benign breast lesions at risk of developing cancer--a challenging problem in breast cancer screening programs: five years’ experience of the Breast Cancer Screening Program in Verona (1999–2004). Cancer. Feb. 1. 2009;115(3):499-507. [pmid: 19117040].
1852 Mansoor S, Ip C, Stomper PC. Yield of Terminal Duct Lobule Units in Normal Breast Stereotactic Core Biopsy Specimens: Implications for Biomarker Studies. Breast J. Jul. 2000;6(4):220-4. [pmid: 11348369].
1853 Marcotte-Bloch C, Balu-Maestro C, Chamorey E, et al. MRI for the size assessment of pure ductal carcinoma in situ (DCIS): a prospective study of 33 patients. Eur J Radiol. Mar. 2011;77(3):462-7. [pmid: 19896789].
1854 Margenthaler JA, Duke D, Monsees BS, et al. Correlation between core biopsy and excisional biopsy in breast high-risk lesions. Am J Surg. Oct. 2006;192(4):534-7. [pmid: 16978969].
1855 Marsden CG, Wright MJ, Pochampally R, et al. Breast tumor-initiating cells isolated from patient core biopsies for study of hormone action. Methods Mol Biol. 2009;590:363-75. [pmid: 19763516].
1856 Mathew J, Crawford DJ, Lwin M, et al. Ultrasound-guided, vacuum-assisted excision in the diagnosis and treatment of clinically benign breast lesions. Ann R Coll Surg Engl. Jul. 2007;89(5):494-6. [pmid: 17688722].
1857 Matos AV, de Canella EO, Koch HA, et al. Fat necrosis in the breast after reconstruction with transverse rectus abdominis myocutaneous flap: MRI features. Eur J Radiol. Sep. 2012;81(Suppl 1):S97-8. [pmid: 23083621].
1858 Maxwell AJ, Mataka G, Pearson JM. Benign papilloma diagnosed on image-guided 14 G core biopsy of the breast: effect of lesion type on likelihood of malignancy at excision. Clin Radiol. Apr. 2013;68(4):383-7. [pmid: 23206431].
1859 Maxwell AJ, Pearson JM. Criteria for the safe avoidance of needle sampling in young women with solid breast masses. Clin Radiol. Mar. 2010;65(3):218-22. [pmid: 20152278].
1860 McCann B, Miaskowski C, Koetters T, et al. Associations between pro- and anti-inflammatory cytokine genes and breast pain in women prior to breast cancer surgery. J Pain. May. 2012;13(5):425-37. [pmid: 22515947].
1861 McCormack VA, Joffe M, van den Berg E, et al. Breast cancer receptor status and stage at diagnosis in over 1,200 consecutive public hospital patients in Soweto, South Africa: a case series. Breast Cancer Res. 2013;15(5):R84. [pmid: 24041225].
1862 McGhan LJ, Pockaj BA, Wasif N, et al. Atypical ductal hyperplasia on core biopsy: an automatic trigger for excisional biopsy?. Ann Surg Oncol. Oct. 2012;19(10):3264-9. [pmid: 22878619].
1863 McLaughlin JM, Anderson RT, Ferketich AK, et al. Effect on survival of longer intervals between confirmed diagnosis and treatment initiation among low-income women with breast cancer. J Clin Oncol. Dec. 20. 2012;30(36):4493-500. [pmid: 23169521].
1864 Mehrotra R, Pandya S, Singhla M, et al. Spectrum of malignancies in Allahabad, North India: a hospital-based study. Asian Pac J Cancer Prev. Jul–Sep. 2008;9(3):525-8. [pmid: 18990032].
1865 Meloni GB, Dessole S, Becchere MP, et al. Effectiveness of “core biopsy” by the mammotome device for diagnosis of inflammatory carcinoma. Clin Exp Obstet Gynecol. 1999;26(3–4):181-2. [pmid: 10668149].
1866 Menes TS, Zissman S, Golan O, et al. Yield of selective magnetic resonance imaging in preoperative workup of newly diagnosed breast cancer patients planned for breast conserving surgery. Am Surg. Apr. 2012;78(4):451-5. [pmid: 22472404].
1867 Merdad AA, Bahadur YA, Fawzy EE, et al. Phase II study on the use of intraoperative radiotherapy in early breast cancer. Saudi Med J. Nov. 2013;34(11):1133-8. [pmid: 24252890].
1868 Mesurolle B, Sygal V, Lalonde L, et al. Sonographic and mammographic appearances of breast hemangioma. AJR Am J Roentgenol. Jul. 2008;191(1):W17-22. [pmid: 18562711].
1869 Meyer JE, Smith DN, Lester SC, et al. Large-needle core biopsy: nonmalignant breast abnormalities evaluated with surgical excision or repeat core biopsy. Radiology. Mar. 1998;206(3):717-20. [pmid: 9494490].
1870 Middleton LP, Price KM, Puig P, et al. Implementation of American Society of Clinical Oncology/College of American Pathologists HER2 Guideline Recommendations in a tertiary care facility increases HER2 immunohistochemistry and fluorescence in situ hybridization concordance and decreases the number of inconclusive cases. Arch Pathol Lab Med. May. 2009;133(5):775-80. [pmid: 19415952].
1871 Mihalik JE, Krupka L, Davenport R, et al. The rate of imaging-histologic discordance of benign breast disease: a multidisciplinary approach to the management of discordance at a large university-based hospital. Am J Surg. Mar. 2010;199(3):319-23. discussion 23. [pmid: 20226903].
1872 Miller NA, Chapman JA, Qian J, et al. Heterogeneity Between Ducts of the Same Nuclear Grade Involved by Duct Carcinoma In Situ (DCIS) of the Breast. Cancer Inform. 2010;9:209-16. [pmid: 20981137].
1873 Mimmi MC, Picotti P, Corazza A, et al. High-performance metabolic marker assessment in breast cancer tissue by mass spectrometry. Clin Chem Lab Med. Feb. 2011;49(2):317-24. [pmid: 21143022].
1874 Minot DM, Kipp BR, Root RM, et al. Automated cellular imaging system III for assessing HER2 status in breast cancer specimens: development of a standardized scoring method that correlates with FISH. Am J Clin Pathol. Jul. 2009;132(1):133-8. [pmid: 19864244].
1875 Mittendorf EA, Arciero CA, Gutchell V, et al. Core biopsy diagnosis of ductal carcinoma in situ: an indication for sentinel lymph node biopsy. Curr Surg. Mar–Apr. 2005;62(2):253-7. [pmid: 15796952].
1876 Miyake T, Shimazu K, Ohashi H, et al. Indication for sentinel lymph node biopsy for breast cancer when core biopsy shows ductal carcinoma in situ. Am J Surg. Jul. 2011;202(1):59-65. [pmid: 21741518].
1877 Miyashita M, Amano G, Ishida T, et al. The clinical significance of breast MRI in the management of ductal carcinoma in situ diagnosed on needle biopsy. Jpn J Clin Oncol. Jun. 2013;43(6):654-63. [pmid: 23592884].
1878 Mohammed S, Statz A, Lacross JS, et al. Granulomatous mastitis: a 10 year experience from a large inner city county hospital. J Surg Res. Sep. 2013;184(1):299-303. [pmid: 23890401].
1879 Mondal HP, Roy H, Mondal P, et al. Usefulness of serum CA-15.3 in the management of benign breast lesion. J Indian Med Assoc. Apr. 2012;110(4):242-4. [pmid: 23025224].
1880 Monticciolo DL. Histologic grading at breast core needle biopsy: comparison with results from the excised breast specimen. Breast J. Jan–Feb. 2005;11(1):9-14. [pmid: 15647072].
1881 Moon HG, Han W, Lee JW, et al. Limitations of conventional contrast-enhanced MRI in selecting sentinel node biopsy candidates among DCIS patients. J Breast Cancer. 2010;13(2):154-9.
1882 Morgan EA, Kozono DE, Wang Q, et al. Cutaneous radiation-associated angiosarcoma of the breast: poor prognosis in a rare secondary malignancy. Ann Surg Oncol. Nov. 2012;19(12):3801-8. [pmid: 22890593].
1883 Morgan JM, Douglas-Jones AG, Gupta SK. Analysis of histological features in needle core biopsy of breast useful in preoperative distinction between fibroadenoma and phyllodes tumour. Histopathology. Mar. 2010;56(4):489-500. [pmid: 20459556].
1884 Mori M, Tsunoda H, Takamoto Y, et al. MRI and ultrasound evaluation of invasive lobular carcinoma of the breast after primary systemic therapy. Breast Cancer. 2013. Aug. 9. [pmid: 23929123].
1885 Mori N, Ota H, Mugikura S, et al. Detection of invasive components in cases of breast ductal carcinoma in situ on biopsy by using apparent diffusion coefficient MR parameters. Eur Radiol. Oct. 2013;23(10):2705-12. [pmid: 23732688].
1886 Mosier AD, Keylock J, Smith DV. Benign papillomas diagnosed on large-gauge vacuum-assisted core needle biopsy which span <1.5 cm do not need surgical excision. Breast J. Nov–Dec. 2013;19(6):611-7. [pmid: 24102818].
1887 Mudduwa L, Liyanage T. Immunohistochemical assessment of hormone receptor status of breast carcinoma: interobserver variation of the quick score. Indian J Med Sci. Jan. 2009;63(1):21-7. [pmid: 19346635].
1888 Mulheron B, Gray RJ, Pockaj BA, et al. Is excisional biopsy indicated for patients with lobular neoplasia diagnosed on percutaneous core needle biopsy of the breast?. Am J Surg. Dec. 2009;198(6):792-7. [pmid: 19969131].
1889 Muller BM, Brase JC, Haufe F, et al. Comparison of the RNA-based EndoPredict multigene test between core biopsies and corresponding surgical breast cancer sections. J Clin Pathol. Jul. 2012;65(7):660-2. [pmid: 22447922].
1890 Murata Y, Hamada N, Kubota K, et al. Choline by magnetic spectroscopy and dynamic contrast enhancement curve by magnetic resonance imaging in neoadjuvant chemotherapy for invasive breast cancer. Mol Med Rep. Jan–Feb. 2009;2(1):39-43. [pmid: 21475788].
1891 Murray MP, Luedtke C, Liberman L, et al. Classic lobular carcinoma in situ and atypical lobular hyperplasia at percutaneous breast core biopsy: outcomes of prospective excision. Cancer. Mar. 1. 2013;119(5):1073-9. [pmid: 23132235].
1892 Murthy SS, Sandhya DG, Ahmed F, et al. Assessment of HER2/Neu status by fluorescence in situ hybridization in immunohistochemistry-equivocal cases of invasive ductal carcinoma and aberrant signal patterns: a study at a tertiary cancer center. Indian J Pathol Microbiol. Jul–Sep. 2011;54(3):532-8. [pmid: 21934215].
1893 Muttarak M, Sangchan S, Kongmebhol P, et al. Mammographic and ultrasonographic features of invasive lobular carcinoma: A review of 16 patients. Biomed Imaging Intervent J. 2010;6(3).
1894 Nagi CS, O’Donnell JE, Tismenetsky M, et al. Lobular neoplasia on core needle biopsy does not require excision. Cancer. May. 15. 2008;112(10):2152-8. [pmid: 18348299].
1895 Nakai K, Mitomi H, Alkam Y, et al. Predictive value of MGMT, hMLH1, hMSH2 and BRCA1 protein expression for pathological complete response to neoadjuvant chemotherapy in basal-like breast cancer patients. Cancer Chemother Pharmacol. Apr. 2012;69(4):923-30. [pmid: 22083523].
1896 Nakano S, Sakamoto H, Ohtsuka M, et al. Evaluation and indications of ultrasound-guided vacuum-assisted core needle breast biopsy. Breast Cancer. 2007;14(3):292-6. [pmid: 17690507].
1897 Naoi Y, Kishi K, Tanei T, et al. High genomic grade index associated with poor prognosis for lymph node-negative and estrogen receptor-positive breast cancers and with good response to chemotherapy. Cancer. Feb. 1. 2011;117(3):472-9. [pmid: 20878674].
1898 Nayak A, Carkaci S, Gilcrease MZ, et al. Benign papillomas without atypia diagnosed on core needle biopsy: experience from a single institution and proposed criteria for excision. Clin Breast Cancer. Dec. 2013;13(6):439-49. [pmid: 24119786].
1899 Neuman HB, Brogi E, Ebrahim A, et al. Desmoid tumors (fibromatoses) of the breast: a 25-year experience. Ann Surg Oncol. Jan. 2008;15(1):274-80. [pmid: 17896146].
1900 Ngai JH, Zelles GW, Rumore GJ, et al. Breast biopsy techniques and adequacy of margins. Arch Surg. Nov. 1991;126(11):1343-6. discussion 6-7. [pmid: 1747047].
1901 Nguyen CV, Albarracin CT, Whitman GJ, et al. Atypical ductal hyperplasia in directional vacuum-assisted biopsy of breast microcalcifications: considerations for surgical excision. Ann Surg Oncol. Mar. 2011;18(3):752-61. [pmid: 20972636].
1902 Niell B, Specht M, Gerade B, et al. Is excisional biopsy required after a breast core biopsy yields lobular neoplasia?. AJR Am J Roentgenol. Oct. 2012;199(4):929-35. [pmid: 22997389].
1903 Niraula S, Dowling RJ, Ennis M, et al. Metformin in early breast cancer: a prospective window of opportunity neoadjuvant study. Breast Cancer Res Treat. Oct. 2012;135(3):821-30. [pmid: 22933030].
1904 Nishimura R, Osako T, Okumura Y, et al. Clinical significance of Ki-67 in neoadjuvant chemotherapy for primary breast cancer as a predictor for chemosensitivity and for prognosis. Breast Cancer. Oct. 2010;17(4):269-75. [pmid: 19730975].
1905 Noel JC, Buxant F, Engohan-Aloghe C. Immediate surgical resection of residual microcalcifications after a diagnosis of pure flat epithelial atypia on core biopsy: a word of caution. Surg Oncol. Dec. 2010;19(4):243-6. [pmid: 19783426].
1906 Nofech-Mozes S, Holloway C, Hanna W. The role of cytokeratin 5/6 as an adjunct diagnostic tool in breast core needle biopsies. Int J Surg Pathol. Oct. 2008;16(4):399-406. [pmid: 18499686].
1907 Nori J, Bazzocchi M, Boeri C, et al. Role of axillary lymph node ultrasound and large core biopsy in the preoperative assessment of patients selected for sentinel node biopsy. Radiol Med. Apr. 2005;109(4):330-44. [pmid: 15883518].
1908 Noske A, Pahl S, Fallenberg E, et al. Flat epithelial atypia is a common subtype of B3 breast lesions and is associated with noninvasive cancer but not with invasive cancer in final excision histology. Hum Pathol. Apr. 2010;41(4):522-7. [pmid: 20004938].
1909 O’Flynn EA, Morel JC, Gonzalez J, et al. Prediction of the presence of invasive disease from the measurement of extent of malignant microcalcification on mammography and ductal carcinoma in situ grade at core biopsy. Clin Radiol. Feb. 2009;64(2):178-83. [pmid: 19103348].
1910 Ohlschlegel C, Kradolfer D, Hell M, et al. Comparison of automated and manual FISH for evaluation of HER2 gene status on breast carcinoma core biopsies. BMC Clin Pathol. 2013;13:13. [pmid: 23601823].
1911 Okunade G, Green AR, Ying M, et al. Biological profile of oestrogen receptor positive primary breast cancers in the elderly and response to primary endocrine therapy. Crit Rev Oncol Hematol. Oct. 2009;72(1):76-82. [pmid: 19515574].
1912 O’Neil M, Madan R, Tawfik OW, et al. Lobular carcinoma in situ/atypical lobular hyperplasia on breast needle biopsies: does it warrant surgical excisional biopsy? A study of 27 cases. Ann Diagn Pathol. Aug. 2010;14(4):251-5. [pmid: 20637429].
1913 Ooi A, Inokuchi M, Harada S, et al. Gene amplification of ESR1 in breast cancers--fact or fiction? A fluorescence in situ hybridization and multiplex ligation-dependent probe amplification study. J Pathol. May. 2012;227(1):8-16. [pmid: 22170254].
1914 Oran ES, Gurdal SO, Yankol Y, et al. Management of idiopathic granulomatous mastitis diagnosed by core biopsy: a retrospective multicenter study. Breast J. Jul–Aug. 2013;19(4):411-8. [pmid: 23663101].
1915 Osborn G, Wilton F, Stevens G, et al. A review of needle core biopsy diagnosed radial scars in the Welsh Breast Screening Programme. Ann R Coll Surg Engl. Mar. 2011;93(2):123-6. [pmid: 21073820].
1916 O’Shea AM, Rakha EA, Hodi Z, et al. Histological grade of invasive carcinoma of the breast assessed on needle core biopsy - modifications to mitotic count assessment to improve agreement with surgical specimens. Histopathology. Sep. 2011;59(3):543-8. [pmid: 21906126].
1917 Ough M, Velasco J, Hieken TJ. A comparative analysis of core needle biopsy and final excision for breast cancer: histology and marker expression. Am J Surg. May. 2011;201(5):692-4. [pmid: 20850706].
1918 Ozdemir A, Voyvoda NK, Gultekin S, et al. Can core biopsy be used instead of surgical biopsy in the diagnosis and prognostic factor analysis of breast carcinoma?. Clin Breast Cancer. Oct. 2007;7(10):791-5. [pmid: 18021481].
1919 Ozel L, Unal A, Unal E, et al. Granulomatous mastitis: is it an autoimmune disease? Diagnostic and therapeutic dilemmas. Surg Today. Aug. 2012;42(8):729-33. [pmid: 22068681].
1920 Ozturk E, Akin M, Can MF, et al. Idiopathic granulomatous mastitis. Saudi Med J. Jan. 2009;30(1):45-9. [pmid: 19139772].
1921 Paajanen H, Hermunen H. Does preoperative core needle biopsy increase surgical site infections in breast cancer surgery? Randomized study of antibiotic prophylaxis. Surg Infect (Larchmt). Aug. 2009;10(4):317-21. [pmid: 19673597].
1922 Pachnicki JP, Czeczko NG, Tuon F, et al. Immunohistochemical evaluation of estrogen and progesterone receptors of pre and post-neoadjuvant chemotherapy for breast cancer. Rev Col Bras Cir. Apr. 2012;39(2):86-92. [pmid: 22664513].
1923 Papalas JA, Wylie JD, Dash RC. Recurrence risk and margin status in granular cell tumors of the breast: a clinicopathologic study of 13 patients. Arch Pathol Lab Med. Jul. 2011;135(7):890-5. [pmid: 21732779].
1924 Park HS, Kim HY, Park S, et al. A nomogram for predicting underestimation of invasiveness in ductal carcinoma in situ diagnosed by preoperative needle biopsy. Breast. Oct. 2013;22(5):869-73. [pmid: 23601760].
1925 Park HS, Park S, Cho J, et al. Risk predictors of underestimation and the need for sentinel node biopsy in patients diagnosed with ductal carcinoma in situ by preoperative needle biopsy. J Surg Oncol. Mar. 2013;107(4):388-92. [pmid: 23007901].
1926 Park HS, Park S, Kim JH, et al. Clinicopathologic features and outcomes of metaplastic breast carcinoma: comparison with invasive ductal carcinoma of the breast. Yonsei Med J. Nov. 2010;51(6):864-9. [pmid: 20879052].
1927 Park JS, Park YM, Kim EK, et al. Sonographic findings of high-grade and non-high-grade ductal carcinoma in situ of the breast. J Ultrasound Med. Dec. 2010;29(12):1687-97. [pmid: 21098839].
1928 Park KJ, Kang SH, Park DH, et al. Usefulness of thallium-201 SPECT for prediction of early progression in low-grade astrocytomas diagnosed by stereotactic biopsy. Clin Neurol Neurosurg. Apr. 2012;114(3):223-9. [pmid: 22104697].
1929 Parsian S, Rahbar H, Allison KH, et al. Nonmalignant breast lesions: ADCs of benign and high-risk subtypes assessed as false-positive at dynamic enhanced MR imaging. Radiology. Dec. 2012;265(3):696-706. [pmid: 23033500].
1930 Pathmanathan N, Albertini AF, Provan PJ, et al. Diagnostic evaluation of papillary lesions of the breast on core biopsy. Mod Pathol. Jul. 2010;23(7):1021-8. [pmid: 20473278].
1931 Pazaitou-Panayiotou K, Chemonidou C, Poupi A, et al. Gonadotropin-releasing hormone neuropeptides and receptor in human breast cancer: correlation to poor prognosis parameters. Peptides. Apr. 2013;42:15-24. [pmid: 23287110].
1932 Pediconi F, Kubik-Huch R, Chilla B, et al. Intra-individual randomised comparison of gadobutrol 1.0 M versus gadobenate dimeglumine 0.5 M in patients scheduled for preoperative breast MRI. Eur Radiol. Jan. 2013;23(1):84-92. [pmid: 22797979].
1933 Pediconi F, Padula S, Dominelli V, et al. Role of breast MR imaging for predicting malignancy of histologically borderline lesions diagnosed at core needle biopsy: prospective evaluation. Radiology. Dec. 2010;257(3):653-61. [pmid: 20884914].
1934 Penel N, Yazdanpanah Y, Chauvet MP, et al. Prevention of surgical site infection after breast cancer surgery by targeted prophylaxis antibiotic in patients at high risk of surgical site infection. J Surg Oncol. Aug. 1. 2007;96(2):124-9. [pmid: 17443747].
1935 Peres A, Barranger E, Becette V, et al. Rates of upgrade to malignancy for 271 cases of flat epithelial atypia (FEA) diagnosed by breast core biopsy. Breast Cancer Res Treat. Jun. 2012;133(2):659-66. [pmid: 22042365].
1936 Perono Biacchiardi C, Brizzi D, Genta F, et al. Breast cancer preoperative staging: does contrast-enhanced magnetic resonance mammography modify surgery?. Int J Breast Cancer. 2011;2011:757234. [pmid: 22295233].
1937 Peters NH, van Esser S, van den Bosch MA, et al. Preoperative MRI and surgical management in patients with nonpalpable breast cancer: the MONET - randomised controlled trial. Eur J Cancer. Apr. 2011;47(6):879-86. [pmid: 21195605].
1938 Petrarca CR, Brunetto AT, Duval V, et al. Survivin as a predictive biomarker of complete pathologic response to neoadjuvant chemotherapy in patients with stage II and stage III breast cancer. Clin Breast Cancer. Apr. 2011;11(2):129-34. [pmid: 21569999].
1939 Pettit K, Swatske ME, Gao F, et al. The impact of breast MRI on surgical decision-making: are patients at risk for mastectomy?. J Surg Oncol. Dec. 1. 2009;100(7):553-8. [pmid: 19757442].
1940 Picouleau E, Denis M, Lavoue V, et al. Atypical hyperplasia of the breast: the black hole of routine breast cancer screening. Anticancer Res. Dec. 2012;32(12):5441-6. [pmid: 23225449].
1941 Pilewskie M, Kennedy C, Shappell C, et al. Effect of MRI on the management of ductal carcinoma in situ of the breast. Ann Surg Oncol. May. 2013;20(5):1522-9. [pmid: 23224903].
1942 Pimiento JM, Lee MC, Esposito NN, et al. Role of axillary staging in women diagnosed with ductal carcinoma in situ with microinvasion. J Oncol Pract. Sep. 2011;7(5):309-13. [pmid: 22211128].
1943 Pinhel IF, Macneill FA, Hills MJ, et al. Extreme loss of immunoreactive p-Akt and p-Erk1/2 during routine fixation of primary breast cancer. Breast Cancer Res. 2010;12(5):R76. [pmid: 20920193].
1944 Piubello Q, Parisi A, Eccher A, et al. Flat epithelial atypia on core needle biopsy: which is the right management?. Am J Surg Pathol. Jul. 2009;33(7):1078-84. [pmid: 19390424].
1945 Poellinger A, Diekmann S, Dietz E, et al. In patients with DCIS: is it sufficient to histologically examine only those tissue specimens that contain microcalcifications?. Eur Radiol. May. 2008;18(5):925-30. [pmid: 18183402].
1946 Pohlodek K, Galbavy S, Bartosova M, et al. Semi-quantitative RT-PCR assessment of molecular markers in breast large-core needle biopsies. Neoplasma. 2004;51(6):415-21. [pmid: 15640949].
1947 Polat AK, Kanbour-Shakir A, Andacoglu O, et al. Atypical hyperplasia on core biopsy: is further surgery needed?. Am J Med Sci. Jul. 2012;344(1):28-31. [pmid: 22205116].
1948 Polom K, Murawa D, Pawelska A, et al. Atypical lobular hyperplasia and lobular carcinoma in situ without other high-risk lesions diagnosed on vacuum-assisted core needle biopsy. The problem of excisional biopsy. Tumori. Jan–Feb. 2009;95(1):32-5. [pmid: 19366053].
1949 Polom K, Murawa D, Wasiewicz J, et al. The role of sentinel node biopsy in ductal carcinoma in situ of the breast. Eur J Surg Oncol. Jan. 2009;35(1):43-7. [pmid: 18723312].
1950 Porter AJ, Evans EB, Foxcroft LM, et al. Mammographic and ultrasound features of invasive lobular carcinoma of the breast. J Med Imaging Radiat Oncol. 2013.
1951 Provencher L, Jacob S, Cote G, et al. Low frequency of cancer occurrence in same breast quadrant diagnosed with lobular neoplasia at percutaneous needle biopsy. Radiology. Apr. 2012;263(1):43-52. [pmid: 22344406].
1952 Puglisi F, Scalone S, Bazzocchi M, et al. Image-guided core breast biopsy: a suitable method for preoperative biological characterization of small (pT1) breast carcinomas. Cancer Lett. Nov. 27. 1998;133(2):223-9. [pmid: 10072173].
1953 Purdie CA, Jordan LB, McCullough JB, et al. HER2 assessment on core biopsy specimens using monoclonal antibody CB11 accurately determines HER2 status in breast carcinoma. Histopathology. May. 2010;56(6):702-7. [pmid: 20546335].
1954 Purdie CA, McLean D, Stormonth E, et al. Management of in situ lobular neoplasia detected on needle core biopsy of breast. J Clin Pathol. Nov. 2010;63(11):987-93. [pmid: 20972243].
1955 Radisky DC, Santisteban M, Berman HK, et al. p16(INK4a) expression and breast cancer risk in women with atypical hyperplasia. Cancer Prev Res (Phila). Dec. 2011;4(12):1953-60. [pmid: 21920875].
1956 Rahusen FD, Taets van Amerongen AH, van Diest PJ, et al. Ultrasound-guided lumpectomy of nonpalpable breast cancers: A feasibility study looking at the accuracy of obtained margins. J Surg Oncol. Oct. 1999;72(2):72-6. [pmid: 10518102].
1957 Railo M, Nordling S, Krogerus L, et al. Preoperative assessment of proliferative activity and hormonal receptor status in carcinoma of the breast: a comparison of needle aspiration and needle-core biopsies to the surgical specimen. Diagn Cytopathol. Sep. 1996;15(3):205-10. [pmid: 8955602].
1958 Rajan S, Shaaban AM, Dall BJ, et al. New patient pathway using vacuum-assisted biopsy reduces diagnostic surgery for B3 lesions. Clin Radiol. Mar. 2012;67(3):244-9. [pmid: 22014554].
1959 Rajan S, Sharma N, Dall BJ, et al. What is the significance of flat epithelial atypia and what are the management implications?. J Clin Pathol. Nov. 2011;64(11):1001-4. [pmid: 21725040].
1960 Rajan S, Wason AM, Carder PJ. Conservative management of screen-detected radial scars: role of mammotome excision. J Clin Pathol. Jan. 2011;64(1):65-8. [pmid: 21097791].
1961 Rakha EA, El-Sayed ME, Reed J, et al. Screen-detected breast lesions with malignant needle core biopsy diagnoses and no malignancy identified in subsequent surgical excision specimens (potential false-positive diagnosis). Eur J Cancer. May. 2009;45(7):1162-7. [pmid: 19121932].
1962 Rakha EA, Ho BC, Naik V, et al. Outcome of breast lesions diagnosed as lesion of uncertain malignant potential (B3) or suspicious of malignancy (B4) on needle core biopsy, including detailed review of epithelial atypia. Histopathology. Mar. 2011;58(4):626-32. [pmid: 21371081].
1963 Rakha EA, Lee AH, Jenkins JA, et al. Characterization and outcome of breast needle core biopsy diagnoses of lesions of uncertain malignant potential (B3) in abnormalities detected by mammographic screening. Int J Cancer. Sep. 15. 2011;129(6):1417-24. [pmid: 21128240].
1964 Rakha EA, Lee AH, Reed J, et al. Screen-detected malignant breast lesions diagnosed following benign (B2) or normal (B1) needle core biopsy diagnoses. Eur J Cancer. Jul. 2010;46(10):1835-40. [pmid: 20392631].
1965 Rakha EA, Shaaban AM, Haider SA, et al. Outcome of pure mucocele-like lesions diagnosed on breast core biopsy. Histopathology. May. 2013;62(6):894-8. [pmid: 23402386].
1966 Reefy S, Osman H, Chao C, et al. Surgical excision for B3 breast lesions diagnosed by vacuum-assisted core biopsy. Anticancer Res. Jun. 2010;30(6):2287-90. [pmid: 20651381].
1967 Reisenbichler ES, Adams AL, Hameed O. The predictive ability of a CK5/p63/CK8/18 antibody cocktail in stratifying breast papillary lesions on needle biopsy: an algorithmic approach works best. Am J Clin Pathol. Dec. 2013;140(6):767-79. [pmid: 24225742].
1968 Rendi MH, Dintzis SM, Lehman CD, et al. Lobular in-situ neoplasia on breast core needle biopsy: imaging indication and pathologic extent can identify which patients require excisional biopsy. Ann Surg Oncol. Mar. 2012;19(3):914-21. [pmid: 21861212].
1969 Renshaw AA. Improved reporting methods for atypia and atypical ductal hyperplasia in breast core needle biopsy specimens. Potential for interlaboratory comparisons. Am J Clin Pathol. Jul. 2001;116(1):87-91. [pmid: 11447757].
1970 Renshaw AA. Predicting invasion in the excision specimen from breast core needle biopsy specimens with only ductal carcinoma in situ. Arch Pathol Lab Med. Jan. 2002;126(1):39-41. [pmid: 11800645].
1971 Resetkova E, Edelweiss M, Albarracin CT, et al. Management of radial sclerosing lesions of the breast diagnosed using percutaneous vacuum-assisted core needle biopsy: recommendations for excision based on seven years’ of experience at a single institution. Breast Cancer Res Treat. Jun. 2011;127(2):335-43. [pmid: 18626769].
1972 Resetkova E, Khazai L, Albarracin CT, et al. Clinical and radiologic data and core needle biopsy findings should dictate management of cellular fibroepithelial tumors of the breast. Breast J. Nov–Dec. 2010;16(6):573-80. [pmid: 21070433].
1973 Revelon G, Sherman ME, Gatewood OM, et al. Focal fibrosis of the breast: imaging characteristics and histopathologic correlation. Radiology. Jul. 2000;216(1):255-9. [pmid: 10887257].
1974 Richard F, Segna KG, Filiberti E. Can large gauge core biopsies for high risk benign breast lesions eliminate the need for excisional biopsy: a correlation between breast biopsy and final surgical pathology. Am Surg. Aug. 2012;78(8):906-8. [pmid: 22856502].
1975 Richter-Ehrenstein C, Muller S, Noske A, et al. Diagnostic accuracy and prognostic value of core biopsy in the management of breast cancer: a series of 542 patients. Int J Surg Pathol. Aug. 2009;17(4):323-6. [pmid: 19029173].
1976 Richter-Ehrenstein C, Tombokan F, Fallenberg EM, et al. Intraductal papillomas of the breast: diagnosis and management of 151 patients. Breast. Dec. 2011;20(6):501-4. [pmid: 21640590].
1977 Riedl O, Fitzal F, Mader N, et al. Intraoperative frozen section analysis for breast-conserving therapy in 1016 patients with breast cancer. Eur J Surg Oncol. Mar. 2009;35(3):264-70. [pmid: 18706785].
1978 Rizzo M, Linebarger J, Lowe MC, et al. Management of papillary breast lesions diagnosed on core-needle biopsy: clinical pathologic and radiologic analysis of 276 cases with surgical follow-up. J Am Coll Surg. Mar. 2012;214(3):280-7. [pmid: 22244207].
1979 Romero Q, Bendahl PO, Klintman M, et al. Ki67 proliferation in core biopsies versus surgical samples - a model for neo-adjuvant breast cancer studies. BMC Cancer. 2011;11:341. [pmid: 21819622].
1980 Rosa M, Mohammadi A, Masood S. Lobular neoplasia displaying central necrosis: a potential diagnostic pitfall. Pathol Res Pract. Aug. 15. 2010;206(8):544-9. [pmid: 20359832].
1981 Ross DS, Liu YF, Pipa J, et al. The diagnostic utility of the minimal carcinoma triple stain in breast carcinomas. Am J Clin Pathol. Jan. 2013;139(1):62-70. [pmid: 23270900].
1982 Roth WD, von Smitten K, Heikkila P, et al. Automated stereotactic core needle biopsy of microcalcifications with correlation to surgical biopsy. Acta Radiol. Jul. 1999;40(4):390-3. [pmid: 10394866].
1983 Rotter K, Haentschel G, Koethe D, et al. Evaluation of mammographic and clinical follow-up after 755 stereotactic vacuum-assisted breast biopsies. Am J Surg. Aug. 2003;186(2):134-42. [pmid: 12885605].
1984 Rouse HC, Ussher S, Kavanagh AM, et al. Examining the sensitivity of ultrasound-guided large core biopsy for invasive breast carcinoma in a population screening programme. J Med Imaging Radiat Oncol. Aug. 2013;57(4):435-43. [pmid: 23870339].
1985 Ruidiaz ME, Cortes-Mateos MJ, Sandoval S, et al. Quantitative comparison of surgical margin histology following excision with traditional electrosurgery and a low-thermal-injury dissection device. J Surg Oncol. Dec. 2011;104(7):746-54. [pmid: 21744349].
1986 Ryden L, Boiesen P, Jonsson PE. Assessment of microvessel density in core needle biopsy specimen in breast cancer. Anticancer Res. Jan–Feb. 2004;24(1):371-5. [pmid: 15015623].
1987 Saadai P, Moezzi M, Menes T. Preoperative and intraoperative predictors of positive margins after breast-conserving surgery: a retrospective review. Breast Cancer. Jul. 2011;18(3):221-5. [pmid: 21465227].
1988 Saarenmaa I, Salminen T, Geiger U, et al. Validity of radiological examinations of patients with breast cancer in different age groups in a population based study. Breast. Feb. 2001;10(1):78-81. [pmid: 14965565].
1989 Sabine VS, Sims AH, Macaskill EJ, et al. Gene expression profiling of response to mTOR inhibitor everolimus in pre-operatively treated post-menopausal women with oestrogen receptor-positive breast cancer. Breast Cancer Res Treat. Jul. 2010;122(2):419-28. [pmid: 20480226].
1990 Saedi HS, Nasiri MRG, Shahidsales S, et al. Comparison of hormone receptor status in primary and recurrent breast cancer. Iran. J Cancer Prev. 2012;5(2):69-73.
1991 Sakr R, Antoine M, Barranger E, et al. Value of sentinel lymph node biopsy in breast ductal carcinoma in situ upstaged to invasive carcinoma. Breast J. Jan–Feb. 2008;14(1):55-60. [pmid: 18186866].
1992 Sakr R, Rouzier R, Salem C, et al. Risk of breast cancer associated with papilloma. Eur J Surg Oncol. Dec. 2008;34(12):1304-8. [pmid: 18440190].
1993 Salkowski LR, Fowler AM, Burnside ES, et al. Utility of 6-month follow-up imaging after a concordant benign breast biopsy result. Radiology. Feb. 2011;258(2):380-7. [pmid: 21079199].
1994 Sancho Perez B, Hernandez Sanchez L, Noguero Meseguer R, et al. Ductal carcinoma in situ: A risk factor for mastectomy?: Carcinoma ductal in situ, factor de riesgo de mastectomia?. Prog. Obstet Ginecol. 2011;54(6):281-93.
1995 Sanger N, Effenberger KE, Riethdorf S, et al. Disseminated tumor cells in the bone marrow of patients with ductal carcinoma in situ. Int J Cancer. Nov. 15. 2011;129(10):2522-6. [pmid: 21207426].
1996 Sangma MB, Panda K, Dasiah S. A clinico-pathological study on benign breast diseases. J Clin Diagn Res. Mar. 2013;7(3):503-6. [pmid: 23634406].
1997 Sanli Y, Kuyumcu S, Ozkan ZG, et al. Increased FDG uptake in breast cancer is associated with prognostic factors. Ann Nucl Med. May. 2012;26(4):345-50. [pmid: 22359222].
1998 Santamaria G, Velasco M, Farrus B, et al. Preoperative MRI of pure intraductal breast carcinoma--a valuable adjunct to mammography in assessing cancer extent. Breast. Apr. 2008;17(2):186-94. [pmid: 17964786].
1999 Saritas I. Prediction of breast cancer using artificial neural networks. J Med Syst. Oct. 2012;36(5):2901-7. [pmid: 21837454].
2000 Satheesha S, Cookson VJ, Coleman LJ, et al. Response to mTOR inhibition: activity of eIF4E predicts sensitivity in cell lines and acquired changes in eIF4E regulation in breast cancer. Mol Cancer. 2011;10:19. [pmid: 21320304].
2001 Sauer G, Schneiderhan-Marra N, Muche R, et al. Molecular indicators of non-sentinel node status in breast cancer determined in preoperative biopsies by multiplexed sandwich immunoassays. J Cancer Res Clin Oncol. Aug. 2011;137(8):1175-84. [pmid: 21516507].
2002 Scheiden R, Sand J, Tanous AM, et al. Consequences of a National Mammography Screening Program on diagnostic procedures and tumor sizes in breast cancer. A retrospective study of 1540 cases diagnosed and histologically confirmed between 1995 and 1997. Pathol Res Pract. 2001;197(7):467-74. [pmid: 11482576].
2003 Schell AM, Rosenkranz K, Lewis PJ. Role of breast MRI in the preoperative evaluation of patients with newly diagnosed breast cancer. AJR Am J Roentgenol. May. 2009;192(5):1438-44. [pmid: 19380574].
2004 Schiffmann S, Sandner J, Birod K, et al. Ceramide synthases and ceramide levels are increased in breast cancer tissue. Carcinogenesis. May. 2009;30(5):745-52. [pmid: 19279183].
2005 Schilling K, Narayanan D, Kalinyak JE, et al. Positron emission mammography in breast cancer presurgical planning: comparisons with magnetic resonance imaging. Eur J Nucl Med Mol Imaging. Jan. 2011;38(1):23-36. [pmid: 20871992].
2006 Schneider C, Trocha S, McKinley B, et al. The use of sentinel lymph node biopsy in ductal carcinoma in situ. Am Surg. Sep. 2010;76(9):943-6. [pmid: 20836339].
2007 Schoonjans JM, Brem RF. Sonographic appearance of ductal carcinoma in situ diagnosed with ultrasonographically guided large core needle biopsy: correlation with mammographic and pathologic findings. J Ultrasound Med. Jul. 2000;19(7):449-57. [pmid: 10898298].
2008 Schulz S, Sinn P, Golatta M, et al. Prediction of underestimated invasiveness in patients with ductal carcinoma in situ of the breast on percutaneous biopsy as rationale for recommending concurrent sentinel lymph node biopsy. Breast. Aug. 2013;22(4):537-42. [pmid: 23237921].
2009 Schwartz GF, Finkel GC, Garcia JC, et al. Subclinical ductal carcinoma in situ of the breast. Treatment by local excision and surveillance alone. Cancer. Nov. 15. 1992;70(10):2468-74. [pmid: 1330281].
2010 Sciallis AP, Chen B, Folpe AL. Cellular spindled histiocytic pseudotumor complicating mammary fat necrosis: a potential diagnostic pitfall. Am J Surg Pathol. Oct. 2012;36(10):1571-8. [pmid: 22982900].
2011 Scoggins M, Krishnamurthy S, Santiago L, et al. Lobular carcinoma in situ of the breast: clinical, radiological, and pathological correlation. Acad Radiol. Apr. 2013;20(4):463-70. [pmid: 23498988].
2012 Seferina SC, Nap M, van den Berkmortel F, et al. Reliability of receptor assessment on core needle biopsy in breast cancer patients. Tumour Biol. Apr. 2013;34(2):987-94. [pmid: 23269610].
2013 Segaert I, Mottaghy F, Ceyssens S, et al. Additional value of PET-CT in staging of clinical stage IIB and III breast cancer. Breast J. Nov–Dec. 2010;16(6):617-24. [pmid: 21070439].
2014 Senetta R, Campanino PP, Mariscotti G, et al. Columnar cell lesions associated with breast calcifications on vacuum-assisted core biopsies: clinical, radiographic, and histological correlations. Mod Pathol. Jun. 2009;22(6):762-9. [pmid: 19287465].
2015 Seo M, Chang JM, Kim WH, et al. Columnar cell lesions without atypia initially diagnosed on breast needle biopsies: is imaging follow-up enough?. AJR Am J Roentgenol. Oct. 2013;201(4):928-34. [pmid: 24059386].
2016 Shah-Khan MG, Geiger XJ, Reynolds C, et al. Long-term follow-up of lobular neoplasia (atypical lobular hyperplasia/lobular carcinoma in situ) diagnosed on core needle biopsy. Ann Surg Oncol. Oct. 2012;19(10):3131-8. [pmid: 22847124].
2017 Shamonki J, Chung A, Huynh KT, et al. Management of papillary lesions of the breast: can larger core needle biopsy samples identify patients who may avoid surgical excision?. Ann Surg Oncol. Dec. 2013;20(13):4137-44. [pmid: 23943035].
2018 Shimauchi A, Giger ML, Bhooshan N, et al. Evaluation of clinical breast MR imaging performed with prototype computer-aided diagnosis breast MR imaging workstation: reader study. Radiology. Mar. 2011;258(3):696-704. [pmid: 21212365].
2019 Shimizu D, Ishikawa T, Tanabe M, et al. Preoperative endocrine therapy with goserelin acetate and tamoxifen in hormone receptor-positive premenopausal breast cancer patients. Breast Cancer. 2012. Nov. 25. [pmid: 23184499].
2020 Shin HJ, Kim HH, Kim SM, et al. Screening-detected and symptomatic ductal carcinoma in situ: differences in the sonographic and pathologic features. AJR Am J Roentgenol. Feb. 2008;190(2):516-25. [pmid: 18212241].
2021 Shouhed D, Amersi FF, Spurrier R, et al. Intraductal papillary lesions of the breast: clinical and pathological correlation. Am Surg. Oct. 2012;78(10):1161-5. [pmid: 23025963].
2022 Shousha S, Peston D, Amo-Takyi B, et al. Evaluation of automated silver-enhanced in situ hybridization (SISH) for detection of HER2 gene amplification in breast carcinoma excision and core biopsy specimens. Histopathology. Jan. 2009;54(2):248-53. [pmid: 19207950].
2023 Shrestha DB, Ravichandran D, Baber Y, et al. Follow-up of benign screen-detected breast lesions with suspicious preoperative needle biopsies. Eur J Surg Oncol. Feb. 2009;35(2):156-8. [pmid: 18353607].
2024 Siegmann KC, Baur A, Vogel U, et al. Risk-benefit analysis of preoperative breast MRI in patients with primary breast cancer. Clin Radiol. Apr. 2009;64(4):403-13. [pmid: 19264186].
2025 Silberfein EJ, Hunt KK, Broglio K, et al. Clinicopathologic factors associated with involved margins after breast-conserving surgery for invasive lobular carcinoma. Clin Breast Cancer. Feb. 2010;10(1):52-8. [pmid: 20133259].
2026 Siziopikou KP, Jokich P, Cobleigh M. Pathologic findings in MRI-guided needle core biopsies of the breast in patients with newly diagnosed breast cancer. Int J Breast Cancer. 2011;2011:613285. [pmid: 22332013].
2027 Skenderi F, Krakonja F, Vranic S. Infarcted fibroadenoma of the breast: report of two new cases with review of the literature. Diagn Pathol. 2013;8:38. [pmid: 23445683].
2028 Sklair-Levy M, Sella T, Alweiss T, et al. Incidence and management of complex fibroadenomas. AJR Am J Roentgenol. Jan. 2008;190(1):214-8. [pmid: 18094314].
2029 Smith BL, Bertagnolli M, Klein BB, et al. Evaluation of the contralateral breast. The role of biopsy at the time of treatment of primary breast cancer. Ann Surg. Jul. 1992;216(1):17-21. [pmid: 1321595].
2030 Smitt MC, Horst K. Association of clinical and pathologic variables with lumpectomy surgical margin status after preoperative diagnosis or excisional biopsy of invasive breast cancer. Ann Surg Oncol. Mar. 2007;14(3):1040-4. [pmid: 17203329].
2031 Sohn V, Porta R, Brown T. Flat epithelial atypia of the breast on core needle biopsy: an indication for surgical excision. Mil Med. Nov. 2011;176(11):1347-50. [pmid: 22165668].
2032 Sohn VY, Causey MW, Steele SR, et al. The treatment of radial scars in the modern era--surgical excision is not required. Am Surg. May. 2010;76(5):522-5. [pmid: 20506884].
2033 Sohn YM, Park SH. Comparison of sonographically guided core needle biopsy and excision in breast papillomas: clinical and sonographic features predictive of malignancy. J Ultrasound Med. Feb. 2013;32(2):303-11. [pmid: 23341387].
2034 Solorzano S, Mesurolle B, Omeroglu A, et al. Flat epithelial atypia of the breast: pathological-radiological correlation. AJR Am J Roentgenol. Sep. 2011;197(3):740-6. [pmid: 21862819].
2035 Son EJ, Kim EK, Youk JH, et al. Imaging-histologic discordance after sonographically guided percutaneous breast biopsy: a prospective observational study. Ultrasound Med Biol. Nov. 2011;37(11):1771-8. [pmid: 21856068].
2036 Song HM, Styblo TM, Carlson GW, et al. The use of oncoplastic reduction techniques to reconstruct partial mastectomy defects in women with ductal carcinoma in situ. Breast J. Mar–Apr. 2010;16(2):141-6. [pmid: 20102367].
2037 Sonnenfeld MR, Frenna TH, Weidner N, et al. Lobular carcinoma in situ: mammographic-pathologic correlation of results of needle-directed biopsy. Radiology. Nov. 1991;181(2):363-7. [pmid: 1924773].
2038 Spangler ML, Zuley ML, Sumkin JH, et al. Detection and classification of calcifications on digital breast tomosynthesis and 2D digital mammography: a comparison. AJR Am J Roentgenol. Feb. 2011;196(2):320-4. [pmid: 21257882].
2039 Sperber F, Blank A, Metser U, et al. Diagnosis and treatment of breast fibroadenomas by ultrasound-guided vacuum-assisted biopsy. Arch Surg. Jul. 2003;138(7):796-800. [pmid: 12860764].
2040 Steffens RF, Wright HR, Hester MY, et al. Clinical, demographic, and situational factors linked to distress associated with benign breast biopsy. J Psychosoc Oncol. 2011;29(1):35-50. [pmid: 21240724].
2041 Stolier A, Stone JC, Moroz K, et al. A comparison of clinical and pathologic assessments for the prediction of occult nipple involvement in nipple-sparing mastectomies. Ann Surg Oncol. Jan. 2013;20(1):128-32. [pmid: 23010730].
2042 Stotter A, Walker R. Tumour markers predictive of successful treatment of breast cancer with primary endocrine therapy in patients over 70 years old: a prospective study. Crit Rev Oncol Hematol. Sep. 2010;75(3):249-56. [pmid: 19969469].
2043 Striebel JM, Bhargava R, Horbinski C, et al. The equivocally amplified HER2 FISH result on breast core biopsy: indications for further sampling do affect patient management. Am J Clin Pathol. Mar. 2008;129(3):383-90. [pmid: 18285260].
2044 Strien L, Leidenius M, Heikkila P. False-positive and false-negative sentinel node findings in 473 breast cancers. Hum Pathol. Nov. 2012;43(11):1940-7. [pmid: 22575258].
2045 Strigel RM, Eby PR, Demartini WB, et al. Frequency, upgrade rates, and characteristics of high-risk lesions initially identified with breast MRI. AJR Am J Roentgenol. Sep. 2010;195(3):792-8. [pmid: 20729462].
2046 Stuver SO, Zhu J, Simchowitz B, et al. Identifying women at risk of delayed breast cancer diagnosis. Jt Comm J Qual Patient Saf. Dec. 2011;37(12):568-75. [pmid: 22235542].
2047 Subhawong AP, Subhawong TK, Khouri N, et al. Incidental minimal atypical lobular hyperplasia on core needle biopsy: correlation with findings on follow-up excision. Am J Surg Pathol. Jun. 2010;34(6):822-8. [pmid: 20431477].
2048 Suh YJ, Kim MJ, Kim EK, et al. Comparison of the underestimation rate in cases with ductal carcinoma in situ at ultrasound-guided core biopsy: 14-gauge automated core-needle biopsy vs 8- or 11-gauge vacuum-assisted biopsy. Br J Radiol. Aug. 2012;85(1016):e349-56. [pmid: 22422382].
2049 Sullivan ME, Khan SA, Sullu Y, et al. Lobular carcinoma in situ variants in breast cores: potential for misdiagnosis, upgrade rates at surgical excision, and practical implications. Arch Pathol Lab Med. Jul. 2010;134(7):1024-8. [pmid: 20586632].
2050 Sutandyo N, Suzanna E, Haryono SJ, et al. Signaling pathways in early onset sporadic breast cancer of patients in Indonesia. Acta Med Indones. Jul. 2008;40(3):139-45. [pmid: 18838752].
2051 Sutela A, Vanninen R, Sudah M, et al. Surgical specimen can be replaced by core samples in assessment of ER, PR and HER-2 for invasive breast cancer. Acta Oncol. 2008;47(1):38-46. [pmid: 17851859].
2052 Sutton B, Davion S, Feldman M, et al. Mucocele-like lesions diagnosed on breast core biopsy: assessment of upgrade rate and need for surgical excision. Am J Clin Pathol. Dec. 2012;138(6):783-8. [pmid: 23161710].
2053 Swapp RE, Glazebrook KN, Jones KN, et al. Management of benign intraductal solitary papilloma diagnosed on core needle biopsy. Ann Surg Oncol. Jun. 2013;20(6):1900-5. [pmid: 23314624].
2054 Symmans WF, Ayers M, Clark EA, et al. Total RNA yield and microarray gene expression profiles from fine-needle aspiration biopsy and core-needle biopsy samples of breast carcinoma. Cancer. Jun. 15. 2003;97(12):2960-71. [pmid: 12784330].
2055 Szynglarewicz B, Matkowski R, Halon A, et al. Lobular neoplasia found on breast biopsy: marker of increased risk of malignancy or direct pre-cancerous lesion?. Folia Histochem Cytobiol. 2011;49(3):417-24. [pmid: 22038220].
2056 Tagaya N, Nakagawa A, Ishikawa Y, et al. Experience with ultrasonographically guided vacuum-assisted resection of benign breast tumors. Clin Radiol. Apr. 2008;63(4):396-400. [pmid: 18325359].
2057 Tamaki K, Sasano H, Ishida T, et al. Comparison of core needle biopsy (CNB) and surgical specimens for accurate preoperative evaluation of ER, PgR and HER2 status of breast cancer patients. Cancer Sci. Sep. 2010;101(9):2074-9. [pmid: 20557310].
2058 Tan H, Li R, Peng W, et al. Radiological and clinical features of adult non-puerperal mastitis. Br J Radiol. Apr. 2013;86(1024):20120657. [pmid: 23392197].
2059 Tang SW, Parker H, Winterbottom L, et al. Early primary breast cancer in the elderly - pattern of presentation and treatment. Surg Oncol. Mar. 2011;20(1):7-12. [pmid: 19679464].
2060 Taskin F, Koseoglu K, Ozbas S, et al. Sonographic features of histopathologically benign solid breast lesions that have been classified as BI-RADS 4 on sonography. J Clin Ultrasound. Jun. 2012;40(5):261-5. [pmid: 22508447].
2061 Taskin F, Unsal A, Ozbas S, et al. Fibrotic lesions of the breast: radiological findings and core-neddle biopsy results. Eur J Radiol. Dec. 2011;80(3):e231-6. [pmid: 21071162].
2062 Taucher S, Rudas M, Mader RM, et al. Prognostic markers in breast cancer: the reliability of HER2/neu status in core needle biopsy of 325 patients with primary breast cancer. Wien Klin Wochenschr. Jan. 31. 2004;116(1–2):26-31. [pmid: 15030120].
2063 Taylor D, Lazberger J, Ives A, et al. Reducing delay in the diagnosis of pregnancy-associated breast cancer: how imaging can help us. J Med Imaging Radiat Oncol. Feb. 2011;55(1):33-42. [pmid: 21382187].
2064 Tebbit CL, Zhai J, Untch BR, et al. Novel tumor sampling strategies to enable microarray gene expression signatures in breast cancer: a study to determine feasibility and reproducibility in the context of clinical care. Breast Cancer Res Treat. Dec. 2009;118(3):635-43. [pmid: 19224362].
2065 Teng-Swan Ho J, Tan PH, Hee SW, et al. Underestimation of malignancy of atypical ductal hyperplasia diagnosed on 11-gauge stereotactically guided Mammotome breast biopsy: an Asian breast screen experience. Breast. Aug. 2008;17(4):401-6. [pmid: 18455920].
2066 Tennant SL, Evans A, Hamilton LJ, et al. Vacuum-assisted excision of breast lesions of uncertain malignant potential (B3) - an alternative to surgery in selected cases. Breast. Dec. 2008;17(6):546-9. [pmid: 18829318].
2067 Tewari M, Pradhan S, Singh U, et al. Assessment of predictive markers of response to neoadjuvant chemotherapy in breast cancer. Asian J Surg. Oct. 2010;33(4):157-67. [pmid: 21377101].
2068 Tfayli A, Yang J, Kojouri K, et al. Neoadjuvant therapy with celecoxib to women with early stage breast cancer. Neoplasma. 2008;55(2):122-6. [pmid: 18237249].
2069 Tham TM, Iyengar KR, Taib NA, et al. Fine needle aspiration biopsy, core needle biopsy or excision biopsy to diagnose breast cancer - which is the ideal method?. Asian Pac J Cancer Prev. Jan–Mar. 2009;10(1):155-8. [pmid: 19469645].
2070 Thomssen C, Harbeck N, Dittmer J, et al. Feasibility of measuring the prognostic factors uPA and PAI-1 in core needle biopsy breast cancer specimens. J Natl Cancer Inst. Jul. 15. 2009;101(14):1028-9. [pmid: 19535782].
2071 Tohno E, Ueno E. Ultrasound (US) diagnosis of nonpalpable breast cancer. Breast Cancer. 2005;12(4):267-71. [pmid: 16286906].
2072 Tomasino RM, Morello V, Gullo A, et al. Assessment of “grading” with Ki-67 and c-kit immunohistochemical expressions may be a helpful tool in management of patients with flat epithelial atypia (FEA) and columnar cell lesions (CCLs) on core breast biopsy. J Cell Physiol. Nov. 2009;221(2):343-9. [pmid: 19585492].
2073 Tomasovic-Loncaric C, Milanovic R, Lambasa S, et al. Intraoperative imprint cytological assessment of the subareolar tissue of the nipple areola complex (NAC). Coll Antropol. Jun. 2010;34(2):431-5. [pmid: 20698114].
2074 Tonegutti M, Girardi V, Ciatto S, et al. B3 breast lesions determined by vacuum-assisted biopsy: how to reduce the frequency of benign excision biopsies. Radiol Med. Dec. 2010;115(8):1246-57. [pmid: 20852955].
2075 Trentin C, Dominelli V, Maisonneuve P, et al. Predictors of invasive breast cancer and lymph node involvement in ductal carcinoma in situ initially diagnosed by vacuum-assisted breast biopsy: experience of 733 cases. Breast. Oct. 2012;21(5):635-40. [pmid: 22795363].
2076 Tsang AK, Chan SK, Lam CC, et al. Phyllodes tumours of the breast - differentiating features in core needle biopsy. Histopathology. Oct. 2011;59(4):600-8. [pmid: 21916949].
2077 Tse GM, Tan PH, Lacambra MD, et al. Papillary lesions of the breast--accuracy of core biopsy. Histopathology. Mar. 2010;56(4):481-8. [pmid: 20459555].
2078 Tseng HS, Chen YL, Chen ST, et al. The management of papillary lesion of the breast by core needle biopsy. Eur J Surg Oncol. Jan. 2009;35(1):21-4. [pmid: 18640002].
2079 Tsuda H, Kurosumi M, Umemura S, et al. HER2 testing on core needle biopsy specimens from primary breast cancers: interobserver reproducibility and concordance with surgically resected specimens. BMC Cancer. 2010;10:534. [pmid: 20925963].
2080 Tunon-de-Lara C, Giard S, Buttarelli M, et al. Sentinel node procedure is warranted in ductal carcinoma in situ with high risk of occult invasive carcinoma and microinvasive carcinoma treated by mastectomy. Breast J. Mar–Apr. 2008;14(2):135-40. [pmid: 18315691].
2081 Turnbull L, Brown S, Harvey I, et al. Comparative effectiveness of MRI in breast cancer (COMICE) trial: a randomised controlled trial. Lancet. Feb. 13. 2010;375(9714):563-71. [pmid: 20159292].
2082 Turnbull LW, Brown SR, Olivier C, et al. Multicentre randomised controlled trial examining the cost-effectiveness of contrast-enhanced high field magnetic resonance imaging in women with primary breast cancer scheduled for wide local excision (COMICE). Health Technol Assess. Jan. 2010;14(1):1-182. [pmid: 20025837].
2083 Tvrdik D, Skalova H, Dundr P, et al. Apoptosis - associated genes and their role in predicting responses to neoadjuvant breast cancer treatment. Med Sci Monit. Jan. 2012;18(1):BR60-7. [pmid: 22207111].
2084 Uematsu T, Kasami M. Soft-copy reading in digital mammography of mass: diagnostic performance of a 5-megapixel cathode ray tube monitor versus a 3-megapixel liquid crystal display monitor in a diagnostic setting. Acta Radiol. Jul. 2008;49(6):623-9. [pmid: 18568553].
2085 Uematsu T, Yuen S, Kasami M, et al. Comparison of magnetic resonance imaging, multidetector row computed tomography, ultrasonography, and mammography for tumor extension of breast cancer. Breast Cancer Res Treat. Dec. 2008;112(3):461-74. [pmid: 18193352].
2086 Ugburo AO, Olajide TO, Fadeyibi IO, et al. Differential diagnosis and management of giant fibroadenoma: comparing excision with reduction mammoplasty incision and excision with inframammary incision. J Plast Surg Hand Surg. Oct. 2012;46(5):354-8. [pmid: 22998148].
2087 Usami S, Moriya T, Amari M, et al. Reliability of prognostic factors in breast carcinoma determined by core needle biopsy. Jpn J Clin Oncol. Apr. 2007;37(4):250-5. [pmid: 17485439].
2088 Usmani S, Khan HA, Al Saleh N, et al. Selective approach to radionuclide-guided sentinel lymph node biopsy in high-risk ductal carcinoma in situ of the breast. Nucl Med Commun. Nov. 2011;32(11):1084-7. [pmid: 21862942].
2089 Usmani S, Khan HA, Niaz K, et al. Tc-99m-methoxy isobutyl isonitrile scintimammography: imaging postexcision biopsy for residual and multifocal breast tumor. Nucl Med Commun. Sep. 2008;29(9):826-9. [pmid: 18677211].
2090 Uy GB, Laudico AV, Carnate JM Jr, et al. Breast cancer hormone receptor assay results of core needle biopsy and modified radical mastectomy specimens from the same patients. Clin Breast Cancer. Apr. 2010;10(2):154-9. [pmid: 20299318].
2091 Uzan C, Mazouni C, Ferchiou M, et al. A model to predict the risk of upgrade to malignancy at surgery in atypical breast lesions discovered on percutaneous biopsy specimens. Ann Surg Oncol. Sep. 2013;20(9):2850-7. [pmid: 23702641].
2092 Uzoaru I, Morgan BR, Liu ZG, et al. Flat epithelial atypia with and without atypical ductal hyperplasia: to re-excise or not. Results of a 5-year prospective study. Virchows Arch. Oct. 2012;461(4):419-23. [pmid: 22961104].
2093 Vamesu S. Angiogenesis and tumor grading in primary breast cancer patients: an analysis of 158 needle core biopsies. Rom J Morphol Embryol. 2006;47(3):251-7. [pmid: 17308684].
2094 Vamesu S. Angiogenesis and ER/PR status in primary breast cancer patients: an analysis of 158 needle core biopsies. Rom J Morphol Embryol. 2007;48(1):25-31. [pmid: 17502947].
2095 Vamesu S. Angiogenesis and tumor histologic type in primary breast cancer patients: an analysis of 155 needle core biopsies. Rom J Morphol Embryol. 2008;49(2):181-8. [pmid: 18516324].
2096 Vamesu S. Angiogenesis and co-expressed of ER and c-erbB-2 (HER2/neu) protein in primary breast cancer patients: an analysis of 158 needle core biopsies. Rom J Morphol Embryol. 2008;49(4):469-78. [pmid: 19050794].
2097 van Esser S, Peters NH, van den Bosch MA, et al. Surgical outcome of patients with core-biopsy-proven nonpalpable breast carcinoma: a large cohort follow-up study. Ann Surg Oncol. Aug. 2009;16(8):2252-8. [pmid: 19437077].
2098 van Esser S, Stapper G, van Diest PJ, et al. Ultrasound-guided laser-induced thermal therapy for small palpable invasive breast carcinomas: a feasibility study. Ann Surg Oncol. Aug. 2009;16(8):2259-63. [pmid: 19506958].
2099 Vandenbussche CJ, Khouri N, Sbaity E, et al. Borderline atypical ductal hyperplasia/low-grade ductal carcinoma in situ on breast needle core biopsy should be managed conservatively. Am J Surg Pathol. Jun. 2013;37(6):913-23. [pmid: 23598968].
2100 Venta LA, Wiley EL, Gabriel H, et al. Imaging features of focal breast fibrosis: mammographic-pathologic correlation of noncalcified breast lesions. AJR Am J Roentgenol. Aug. 1999;173(2):309-16. [pmid: 10430125].
2101 Veronesi U, Luini A, Botteri E, et al. Nonpalpable breast carcinomas: long-term evaluation of 1,258 cases. Oncologist. 2010;15(12):1248-52. [pmid: 21147866].
2102 Verschuur-Maes AH, Van Diest PJ. The mucinous variant of columnar cell lesions. Histopathology. May. 2011;58(6):847-53. [pmid: 21585423].
2103 Verschuur-Maes AH, Witkamp AJ, de Bruin PC, et al. Progression risk of columnar cell lesions of the breast diagnosed in core needle biopsies. Int J Cancer. Dec. 1. 2011;129(11):2674-80. [pmid: 21225627].
2104 Vicini FA, Kestin LL, Goldstein NS, et al. Relationship between excision volume, margin status, and tumor size with the development of local recurrence in patients with ductal carcinoma-in-situ treated with breast-conserving therapy. J Surg Oncol. Apr. 2001;76(4):245-54. [pmid: 11320515].
2105 Vicini FA, Lacerna MD, Goldstein NS, et al. Ductal carcinoma in situ detected in the mammographic era: an analysis of clinical, pathologic, and treatment-related factors affecting outcome with breast-conserving therapy. Int J Radiat Oncol Biol Phys. Oct. 1. 1997;39(3):627-35. [pmid: 9336142].
2106 Vicini FA, Shaitelman S, Wilkinson JB, et al. Long-term impact of young age at diagnosis on treatment outcome and patterns of failure in patients with ductal carcinoma in situ treated with breast-conserving therapy. Breast J. Jul–Aug. 2013;19(4):365-73. [pmid: 23815268].
2107 Vilar VS, Goldman SM, Ricci MD, et al. Analysis by MRI of residual tumor after radiofrequency ablation for early stage breast cancer. AJR Am J Roentgenol. Mar. 2012;198(3):W285-91. [pmid: 22358027].
2108 Vilardell F, Novell A, Martin J, et al. Importance of assessing CK19 immunostaining in core biopsies in patients subjected to sentinel node study by OSNA. Virchows Arch. Jun. 2012;460(6):569-75. [pmid: 22555942].
2109 Villa A, Tagliafico A, Chiesa F, et al. Atypical ductal hyperplasia diagnosed at 11-gauge vacuum-assisted breast biopsy performed on suspicious clustered microcalcifications: could patients without residual microcalcifications be managed conservatively?. AJR Am J Roentgenol. Oct. 2011;197(4):1012-8. [pmid: 21940593].
2110 von Minckwitz G, Darb-Esfahani S, Loibl S, et al. Responsiveness of adjacent ductal carcinoma in situ and changes in HER2 status after neoadjuvant chemotherapy/trastuzumab treatment in early breast cancer--results from the GeparQuattro study (GBG 40). Breast Cancer Res Treat. Apr. 2012;132(3):863-70. [pmid: 21667238].
2111 Voros A, Csorgo E, Nyari T, et al. An intra- and interobserver reproducibility analysis of the Ki-67 proliferation marker assessment on core biopsies of breast cancer patients and its potential clinical implications. Pathobiology. 2013;80(3):111-8. [pmid: 23258384].
2112 Wagoner MJ, Laronga C, Acs G. Extent and histologic pattern of atypical ductal hyperplasia present on core needle biopsy specimens of the breast can predict ductal carcinoma in situ in subsequent excision. Am J Clin Pathol. Jan. 2009;131(1):112-21. [pmid: 19095574].
2113 Walker LC, Harris GC, Wells JE, et al. Association of chromosome band 8q22 copy number gain with high grade invasive breast carcinomas by assessment of core needle biopsies. Genes Chromosomes Cancer. May. 2008;47(5):405-17. [pmid: 18273837].
2114 Walls J, Knox F, Baildam AD, et al. Can preoperative factors predict for residual malignancy after breast biopsy for invasive cancer?. Ann R Coll Surg Engl. Jul. 1995;77(4):248-51. [pmid: 7574313].
2115 Wang ZL, Li JL, Su L, et al. An evaluation of a 10-gauge vacuum-assisted system for ultrasound-guided excision of clinically benign breast lesions. Breast. Jun. 2009;18(3):192-6. [pmid: 19446453].
2116 Wang ZL, Liu G, Li JL, et al. Breast lesions with imaging-histologic discordance during 16-gauge core needle biopsy system: would vacuum-assisted removal get significantly more definitive histologic diagnosis than vacuum-assisted biopsy?. Breast J. Sep–Oct. 2011;17(5):456-61. [pmid: 21762244].
2117 Wani SQ, Khan T, Wani SY, et al. Clinicoepidemiological analysis of female breast cancer patients in Kashmir. J Cancer Res Ther. Jul–Sep. 2012;8(3):389-93. [pmid: 23174720].
2118 Ward ST, Jewkes AJ, Jones BG, et al. The sensitivity of needle core biopsy in combination with other investigations for the diagnosis of phyllodes tumours of the breast. Int J Surg. 2012;10(9):527-31. [pmid: 22892094].
2119 Warner E, Causer PA, Wong JW, et al. Improvement in DCIS detection rates by MRI over time in a high-risk breast screening study. Breast J. Jan–Feb. 2011;17(1):9-17. [pmid: 21251121].
2120 Watson P, Lieberman R, Snyder C, et al. Detecting BRCA2 protein truncation in tissue biopsies to identify breast cancers that arise in BRCA2 gene mutation carriers. J Clin Oncol. Aug. 20. 2009;27(24):3894-900. [pmid: 19620486].
2121 Wei S, Kragel CP, Zhang K, et al. Factors associated with residual disease after initial breast-conserving surgery for ductal carcinoma in situ. Hum Pathol. Jul. 2012;43(7):986-93. [pmid: 22221704].
2122 Weigel S, Decker T, Korsching E, et al. Minimal invasive biopsy results of “uncertain malignant potential” in digital mammography screening: high prevalence but also high predictive value for malignancy. Rofo. Aug. 2011;183(8):743-8. [pmid: 21506072].
2123 Whiffen A, El-Tamer M, Taback B, et al. Predictors of breast cancer development in women with atypical ductal hyperplasia and atypical lobular hyperplasia. Ann Surg Oncol. Feb. 2011;18(2):463-7. [pmid: 20878246].
2124 White V, Pruden M, Kitchen P, et al. The impact of publication of Australian treatment recommendations for DCIS on clinical practice: A population-based, “before-after” study. Eur J Surg Oncol. Oct. 2010;36(10):949-56. [pmid: 20724103].
2125 Whitworth PW, Simpson JF, Poller WR, et al. Definitive diagnosis for high-risk breast lesions without open surgical excision: the Intact Percutaneous Excision Trial (IPET). Ann Surg Oncol. Oct. 2011;18(11):3047-52. [pmid: 21947585].
2126 Wieman SM, Landercasper J, Johnson JM, et al. Tumoral pseudoangiomatous stromal hyperplasia of the breast. Am Surg. Dec. 2008;74(12):1211-4. [pmid: 19097540].
2127 Wilke LG, Ballman KV, McCall LM, et al. Adherence to the National Quality Forum (NQF) breast cancer measures within cancer clinical trials: a review from ACOSOG Z0010. Ann Surg Oncol. Aug. 2010;17(8):1989-94. [pmid: 20309640].
2128 Williams RT, Yao K, Stewart AK, et al. Needle versus excisional biopsy for noninvasive and invasive breast cancer: report from the National Cancer Data Base, 2003–2008. Ann Surg Oncol. Dec. 2011;18(13):3802-10. [pmid: 21630122].
2129 Wiratkapun C, Chansanti O, Wibulpolprasert B, et al. Focal fibrosis of the breast diagnosed by core needle biopsy under imaging guidance. J Med Assoc Thai. Mar. 2013;96(3):340-5. [pmid: 23539939].
2130 Wiratkapun C, Keeratitragoon T, Lertsithichai P, et al. Upgrading rate of papillary breast lesions diagnosed by core-needle biopsy. Diagn Interv Radiol. Sep–Oct. 2013;19(5):371-6. [pmid: 23748032].
2131 Wiratkapun C, Patanajareet P, Wibulpholprasert B, et al. Factors associated with upstaging of ductal carcinoma in situ diagnosed by core needle biopsy using imaging guidance. Jpn J Radiol. Oct. 2011;29(8):547-53. [pmid: 21927996].
2132 Wisinski KB, Faerber A, Wagner S, et al. Predictors of willingness to participate in window-of-opportunity breast trials. Clin Med Res. Sep. 2013;11(3):107-12. [pmid: 23580787].
2133 Wisner DJ, Hwang ES, Chang CB, et al. Features of occult invasion in biopsy-proven DCIS at breast MRI. Breast J. Nov–Dec. 2013;19(6):650-8. [pmid: 24165314].
2134 Wojnar A, Bartosz Pula B, Podhorska-Okolow M, et al. Discrepancies between HER2 assessment from core needle biopsies and surgical specimens of invasive ductal breast carcinoma. Adv Clin Exp Med. Jan–Feb. 2013;22(1):27-31. [pmid: 23468259].
2135 Xu HN, Tchou J, Chance B, et al. Imaging the redox states of human breast cancer core biopsies. Adv Exp Med Biol. 2013;765:343-9. [pmid: 22879054].
2136 Xu ZL, Zhu XQ, Lu P, et al. Activation of tumor-infiltrating antigen presenting cells by high intensity focused ultrasound ablation of human breast cancer. Ultrasound Med Biol. Jan. 2009;35(1):50-7. [pmid: 18950932].
2137 Yamaguchi R, Tanaka M, Mizushima Y, et al. Myxomatous fibroadenoma of the breast: correlation with clinicopathologic and radiologic features. Hum Pathol. Mar. 2011;42(3):419-23. [pmid: 21195451].
2138 Yamaguchi R, Tanaka M, Tse GM, et al. Pure flat epithelial atypia is uncommon in subsequent breast excisions for atypical epithelial proliferation. Cancer Sci. Aug. 2012;103(8):1580-5. [pmid: 22533984].
2139 Yamaguchi R, Tsuchiya S, Koshikawa T, et al. Evaluation of inadequate, indeterminate, false-negative and false-positive cases in cytological examination for breast cancer according to histological type. Diagn Pathol. 2012;7:53. [pmid: 22607447].
2140 Yamashita M, Hovanessian-Larsen L, Sener SF. The role of axillary ultrasound in the detection of metastases from primary breast cancers. Am J Surg. Mar. 2013;205(3):242-4. discussion 4-5. [pmid: 23369307].
2141 Yang H, Liu H, Peng W, et al. Magnetic resonance imaging of the breast in evaluating residual diseases at lumpectomy site soon after excisional biopsy. J Comput Assist Tomogr. Mar–Apr. 2012;36(2):196-9. [pmid: 22446359].
2142 Yildiz-Aktas IZ, Dabbs DJ, Bhargava R. The effect of cold ischemic time on the immunohistochemical evaluation of estrogen receptor, progesterone receptor, and HER2 expression in invasive breast carcinoma. Mod Pathol. Aug. 2012;25(8):1098-105. [pmid: 22460807].
2143 Yohe S, Yeh IT. “Missed” diagnoses of phyllodes tumor on breast biopsy: pathologic clues to its recognition. Int J Surg Pathol. Apr. 2008;16(2):137-42. [pmid: 18417670].
2144 Yoshida M, Tsuda H, Yamamoto S, et al. Loss of heterozygosity on chromosome 16q suggests malignancy in core needle biopsy specimens of intraductal papillary breast lesions. Virchows Arch. May. 2012;460(5):497-504. [pmid: 22476400].
2145 Youk JH, Jung I, Kim EK, et al. US follow-up protocol in concordant benign result after US-guided 14-gauge core needle breast biopsy. Breast Cancer Res Treat. Apr. 2012;132(3):1089-97. [pmid: 22218886].
2146 Youk JH, Kim EK, Kim MJ. Atypical ductal hyperplasia diagnosed at sonographically guided 14-gauge core needle biopsy of breast mass. AJR Am J Roentgenol. Apr. 2009;192(4):1135-41. [pmid: 19304725].
2147 Youk JH, Kim EK, Kim MJ, et al. Analysis of false-negative results after US-guided 14-gauge core needle breast biopsy. Eur Radiol. Apr. 2010;20(4):782-9. [pmid: 19862531].
2148 Youk JH, Kim EK, Kwak JY, et al. Atypical papilloma diagnosed by sonographically guided 14-gauge core needle biopsy of breast mass. AJR Am J Roentgenol. May. 2010;194(5):1397-402. [pmid: 20410431].
2149 Youk JH, Kim EK, Kwak JY, et al. Benign papilloma without atypia diagnosed at US-guided 14-gauge core-needle biopsy: clinical and US features predictive of upgrade to malignancy. Radiology. Jan. 2011;258(1):81-8. [pmid: 20971773].
2150 Youk JH, Kim MJ, Son EJ, et al. US-guided vacuum-assisted percutaneous excision for management of benign papilloma without atypia diagnosed at US-guided 14-gauge core needle biopsy. Ann Surg Oncol. Mar. 2012;19(3):922-8. [pmid: 21863359].
2151 Youn I, Choi SH, Moon HJ, et al. Phyllodes tumors of the breast: ultrasonographic findings and diagnostic performance of ultrasound-guided core needle biopsy. Ultrasound Med Biol. Jun. 2013;39(6):987-92. [pmid: 23499344].
2152 Yu CC, Chiang KC, Kuo WL, et al. Low re-excision rate for positive margins in patients treated with ultrasound-guided breast-conserving surgery. Breast. Oct. 2013;22(5):698-702. [pmid: 23333255].
2153 Yu J, Monaco SE, Onisko A, et al. A validation study of quantum dot multispectral imaging to evaluate hormone receptor status in ductal carcinoma in situ of the breast. Hum Pathol. Mar. 2013;44(3):394-401. [pmid: 23039940].
2154 Yuan XM, Wang N, Ouyang T, et al. Current status of diagnosis and treatment of primary breast cancer in beijing, 2008. Chin J Cancer Res. Mar. 2011;23(1):38-42. [pmid: 23467615].
2155 Zagouri F, Sergentanis TN, Nonni A, et al. Comparison of molecular markers expression in vacuum-assisted biopsies and surgical specimens of human breast carcinomas. Pathol Res Pract. Jan. 15. 2010;206(1):30-3. [pmid: 19836148].
2156 Zhang X, Wu X, Su P, et al. Doxorubicin influences the expression of glucosylceramide synthase in invasive ductal breast cancer. PLoS One. 2012;7(11):e48492. [pmid: 23133636].
2157 Zhao C, Desouki MM, Florea A, et al. Pathologic findings of follow-up surgical excision for lobular neoplasia on breast core biopsy performed for calcification. Am J Clin Pathol. Jul. 2012;138(1):72-8. [pmid: 22706860].
2158 Zheng J, Alsaadi T, Blaichman J, et al. Invasive ductal carcinoma of the breast: correlation between tumor grade determined by ultrasound-guided core biopsy and surgical pathology. AJR Am J Roentgenol. Jan. 2013;200(1):W71-4. [pmid: 23255773].
2159 Zhou W, Zha X, Liu X, et al. US-guided percutaneous microwave coagulation of small breast cancers: a clinical study. Radiology. May. 2012;263(2):364-73. [pmid: 22438362].
2160 Zhu Y, Li Q, Gao J, et al. Clinical features and treatment response of solid neuroendocrine breast carcinoma to adjuvant chemotherapy and endocrine therapy. Breast J. Jul–Aug. 2013;19(4):382-7. [pmid: 23721399].
2161 Zito FA, Verderio P, Simone G, et al. Reproducibility in the diagnosis of needle core biopsies of non-palpable breast lesions: an international study using virtual slides published on the world-wide web. Histopathology. May. 2010;56(6):720-6. [pmid: 20546337].
2162 Zografos GC, Zagouri F, Sergentanis TN, et al. Diagnosing papillary lesions using vacuum-assisted breast biopsy: should conservative or surgical management follow?. Onkologie. Dec. 2008;31(12):653-6. [pmid: 19060502].
2163 Zwart W, Koornstra R, Wesseling J, et al. A carrier-assisted ChIP-seq method for estrogen receptor-chromatin interactions from breast cancer core needle biopsy samples. BMC Genomics. 2013;14(1):232. [pmid: 23565824].
2164 Zysk AM, Nguyen FT, Chaney EJ, et al. Clinical feasibility of microscopically-guided breast needle biopsy using a fiber-optic probe with computer-aided detection. Technol Cancer Res Treat. Oct. 2009;8(5):315-21. [pmid: 19754207].