# Search Strategy

Search strategy for CINAHL/Embase/Medline, adapted from the 2009 Comparative Effectiveness Review, “Comparative Effectiveness of Core Needle Biopsy and Open Surgical Biopsy for the Diagnosis of Breast Lesions”

Set Number | Concept | Search statement
1 | Breast biopsy | (breast biopsy or stereotactic breast biopsy or directional vacuum assisted biopsy).de.
2 | Breast | Breast
3 | Breast diseases | Exp breast cancer/di or exp breast neoplasms/di or exp breast disease/di or exp breast diseases/di
4 | | (breast or mammar$) and (Papilloma or calcification$ or calcinosis or tum?or$ or lesion$ or cancer or carcinoma$ or lump$)
5 | Combine sets | or/2–4
6 | Biopsy | 5 and ((Biopsy or tumor biopsy).de. or biops$)
7 | Large core needle biopsy | 6 and ((needle biopsy or biopsy needle or percutaneous biopsy).de. or (large core or needle or mammotome or mammatome or vacuum))
8 | Open biopsy | 6 and (breast/su or breast tumor/su)
9 | | 6 and (su.fs. or open or excision$ or incision$ or surgical)
10 | Combine sets | 8 or 9
11 | Combine sets | or/1,7,10
12 | Limit by publication type | 11 not ((letter or editorial or news or comment or case reports or note or conference paper).de. or (letter or editorial or news or comment or case reports).pt.)
13 | Diagnostics filter | 12 and (exp prediction and forecasting/ or (predictive value of tests or receiver operating characteristic or ROC curve or sensitivity and specificity or accuracy or diagnostic accuracy or precision or likelihood).de. or ((false or true) adj (positive or negative)))
14 | Clinical trials filter | 13 and ((Randomized controlled trials or random allocation or double-blind method or single-blind method or placebos or crossover studies or crossover procedure or double blind procedure or single blind procedure or placebos or latin square design or crossover design or double-blind studies or single-blind studies or triple-blind studies or random assignment or exp controlled study/ or exp clinical trial/ or exp comparative study/ or cohort analysis or follow-up studies.de. or intermethod comparison or parallel design or control group or prospective study or retrospective study or case control study or major clinical study).de. or Case control studies/ or Cohort/ or Longitudinal studies/ or Evaluation studies/ or Follow-up studies/ or Prospective studies/ or Retrospective studies/ or Case control study/ or Cohort analysis/ or Longitudinal study/ or Follow up/ or Cohort analysis/ or Followup studies/ or random$.hw. or random$.ti. or placebo$.mp. or ((singl$ or doubl$ or tripl$ or trebl$) and (dummy or blind or sham or mask)).mp. or latin square.mp. or (time adj series) or (case adj (study or studies) or ISRCTN$.mp. or ACTRN$.mp. or (NCT$ not nctc$)))
15 | Combine sets | 13 or 14
16 | Eliminate overlap
17 | Seeding | 12 and seeding.ti,ab.
18 | Patient satisfactionQOL | 12 and ((patient satisfaction or pain measurement or pain assessment or visual analog scale or quality of life).de. or satisf$ or QOL or preference$)
19 | Adverse events | 12 and ((ae or co).fs. or cross infection or drainage or surgical wound infection).de.)
20 | Disfiguration | 12 and (disfigur$ or deform$)
21 | Combine sets | Or/16–20