# Abbreviations

ADH: Atypical ductal hyperplasia
AHRQ: Agency for healthcare Research and Quality
CrI: Credible interval
DCIS: Ductal carcinoma in situ
EPC: Evidence-based Practice Center
FN: False negative
FP: False positive
MRI: Magnetic resonance imaging
PICOTS: Populations-Interventions-Comparators-Outcomes-Timing-Setting
PRISMA: Preferred Reporting Items for Systematic Reviews and Meta-Analyses
QUADAS: Quality Assessment of Diagnostic Accuracy Studies
ROC: Received operating characteristic
SRDR: Systematic Review Data Repository
STARD: Standards for Reporting of Diagnostic Accuracy
TEP: Technical expert panel
TOO: Task Order Officer
TN: True negative
TP: True positive
US: Ultrasound