# References

1 Adams K, Corrigan E. Priority Areas for Quality Improvement. Washington, DC. Institute of Medicine of the National Academies, The National Academies Press. 2003.
2 Kohn LT, Corrigan J, Donaldson MS. To Err is Human: Building A Safer Health System. Washington, DC. National Academy Press. 2000.
3 McGlynn EA, Asch SM, Adams J, et al. The quality of health care delivered to adults in the United States. N Engl J Med. Jun. 26. 2003;348(26):2635-45. Epub: 2003/06/27. [pmid: 12826639].
4 Zhan C, Arispe I, Kelley E, et al. Ambulatory care visits for treating adverse drug effects in the United States, 1995-2001. Jt Comm J Qual Patient Saf. Jul. 2005;31(7):372-8. Epub: 2005/09/01. [pmid: 16130980].
5 Gurwitz JH, Rochon P. Food and Drug Administration. Improving the quality of medication use in elderly patients: a not-so-simple prescription. Arch Intern Med. Aug. 12-26. 2002;162(15):1670-2. Epub: 2002/08/03. [pmid: 12153368].
6 Lazarou J, Pomeranz BH, Corey PN. Incidence of adverse drug reactions in hospitalized patients: a meta-analysis of prospective studies. JAMA. Apr. 15. 1998;279(15):1200-5. Epub: 1998/04/29. [pmid: 9555760].
7 Warholak TL, Nau DP. Quality and Safety in Pharmacy Practice. New York, NY. McGraw-Hill Medical. 2010.
8 Mahan D. Out-of-Bounds: Rising Prescription Drug Prices for Seniors. Families USA Foundation Publication No. 03-106. Washington, DC. July. 2003.
9 Kaufman DW, Kelly JP, Rosenberg L, et al. Recent patterns of medication use in the ambulatory adult population of the United States: the Slone survey. JAMA. Jan. 16. 2002;287(3):337-44. Epub: 2002/01/16. [pmid: 11790213].
10 Pellegrino AN, Martin MT, Tilton JJ, et al. Medication therapy management services: definitions and outcomes. Drugs. 2009;69(4):393-406. Epub: 2009/03/28. [pmid: 19323584].
11 Lewin Group. Medication therapy management services: a critical review. J Am Pharm Assoc (2003). Sep-Oct. 2005;45(5):580-7. Epub: 2005/11/22. [pmid: 16295643].
12 108th U.S. Congress. Medicare Prescription Drug, Improvement, and Modernization Act of 2003. 2003.
13 Bluml BM. Definition of medication therapy management: development of professionwide consensus. J Am Pharm Assoc (2003). Sep-Oct. 2005;45(5):566-72. Epub: 2005/11/22. [pmid: 16295641].
14 American Pharmacists Association. APhA MTM Central. What is medication therapy management?. Washington, DC. American Pharmacists Association. 2014. www.pharmacist.com/mtm. March 6, 2014.
15 Association of Chain Drug Stores Foundation. Medication therapy management in pharmacy practice: core elements of an MTM service model (version 2.0). J Am Pharm Assoc (2003). May-Jun. 2008;48(3):341-53. Epub: 2008/07/04. [pmid: 18595820].
16 Pharmacist Services Technical Advisory Coalition. Medication Therapy Management Service Codes. PSTAC. 2010. www.pstac.org/services/mtms-codes.html. March 5, 2013.
17 McInnis T, Strand LM, Webb CE, et al. The Patient-Centered Medical Home: Integrating Comprehensive Medication Management to Optimize Patient Outcomes. Resource Guide. Patient-Centered Primary Care Collaborative. Washington, DC. June. 2012. www.pcpcc.org/sites/default/files/media/medmanagement.pdf.
18 Department of Veterans Affairs, Veterans Health Administration. Pharmacy General Requirements. Washington, DC. Veterans Health Administration. 2008. April. 17. www.va.gov/vhapublications/ViewPublication.asp?pub_ID=1678. February 20, 2013.
19 Tudor CG. Contract Year 2014 Medication Therapy Management Program Guidance and Submission Instructions. Baltimore, MD. Centers for Medicare & Medicaid Services. 2013. www.cms.gov/Medicare/Prescription-Drug-Coverage/PrescriptionDrugCovContra/Downloads/Memo-Contract-Year-2014-Medication-Therapy-Management-MTM-Program-Submission-v040513.pdf. May 2, 2014.
20 Isetts BJ, Buffington DE. CPT code-change proposal: national data on pharmacists' medication therapy management services. Consult Pharm. Aug. 2007;22(8):684-9. Epub: 2008/01/22. [pmid: 18203409].
21 American Medical Association. CPT changes 2006: an insider's view. Chicago, IL. American Medical Association. 2005:309-12.
22 CPT Assistant. Transitional Care Management Services. CPT Assistant. 2013. www.sccma-mcms.org/Portals/19/assets/docs/TCM%20CPT%20Assist%20Article.pdf.
23 Bodenheimer T, Berry-Millett R. Care management of patients with complex health care needs. Robert Wood Johnson Research Synthesis Report No. 19. San Francisco, CA. December. 2009. www.rwjf.org/content/dam/farm/reports/issue_briefs/2009/rwjf49853/subassets/rwjf49853_1.
24 Hassol A, Shoemaker SJ. Exploratory Research on Medication Therapy Management. (Prepared by Abt Associates under Contract #HHSM-500-2005-00181/TO#3). Baltimore, MD. Centers for Medicare & Medicaid Services. July. 8. 2008. www.cms.gov/Research-Statistics-Data-and-Systems/Statistics-Trends-and-Reports/Reports/downloads/blackwell.pdf.
25 Agency for Healthcare Research and Quality. Evidence-based Practice Center Systematic Review Protocol. Project Title: Medication Therapy Management. Rockville, MD. AHRQ. 2013. July. 24. http://effectivehealthcare.ahrq.gov/ehc/products/516/1601/medication-therapy-management-protocol-130724.pdf. September 7, 2013.
26 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. J Clin Epidemiol. Oct. 2009;62(10):1006-12. Epub: 2009/07/28. [pmid: 19631508].
27 Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. Epub: 2007/02/17. [pmid: 17302989].
28 Viswanathan M, Ansari MT, Berkman ND, et al. Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions. Agency for Healthcare Research and Quality. Methods Guide for Comparative Effectiveness Reviews AHRQ Publication No. 12-EHC047-EF. Rockville, MD. March. 2012. www.effectivehealthcare.ahrq.gov/.
29 Higgins JP, Altman DG, Gotzsche PC, et al. The Cochrane Collaboration's tool for assessing risk of bias in randomised trials. BMJ. 2011;343:d5928. Epub: 2011/10/20. [pmid: 22008217].
30 Viswanathan M, Berkman ND. Development of the RTI item bank on risk of bias and precision of observational studies. J Clin Epidemiol. Feb. 2012;65(2):163-78. Epub: 2011/10/01. [pmid: 21959223].
31 West SL, Gartlehner G, Mansfield AJ, et al. Comparative Effectiveness Review Methods: Clinical Heterogeneity. Agency for Healthcare Research and Quality Methods Research Paper. AHRQ Publication No. 10-EHC070-EF. Rockville, MD. September. 2010. http://effectivehealthcare.ahrq.gov/.
32 Berkman ND, Lohr KN, Ansari M, et al. Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Comparative Effectiveness Reviews. (Prepared by the RTI-UNC Evidence-based Practice Center under Contract No. 290-2007-10056-I) AHRQ Publication No. 13(14)-EHC130-EF. Rockville, MD. Agency for Healthcare Research and Quality. November. 2013. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
33 Guyatt GH, Oxman AD, Kunz R, et al. GRADE guidelines 6. Rating the quality of evidence--imprecision. J Clin Epidemiol. Dec. 2011;64(12):1283-93. Epub: 2011/08/16. [pmid: 21839614].
34 Guyatt GH, Oxman AD, Vist G, et al. GRADE guidelines: 4. Rating the quality of evidence--study limitations (risk of bias). J Clin Epidemiol. Apr. 2011;64(4):407-15. Epub: 2011/01/21. [pmid: 21247734].
35 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--Agency for Healthcare Research and Quality and the Effective Health-Care Program. J Clin Epidemiol. May. 2010;63(5):513-23. Epub: 2009/07/15. [pmid: 19595577].
36 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1198-207. Epub: 2011/04/06. [pmid: 21463926].
37 Fox D, Ried LD, Klein GE, et al. A medication therapy management program's impact on low-density lipoprotein cholesterol goal attainment in Medicare Part D patients with diabetes. J Am Pharm Assoc (2003). Mar-Apr. 2009;49(2):192-9. Epub: 2009/03/18. [pmid: 19289345].
38 Jeong E, Hui R, Gallagher M, et al. Clinical Economical and Humanistic Outcomes from a Pharmacist-managed Medication Therapy Management Program (MTMP) in Medicare Patients from an Integrated Healthcare Delivery System. Kaiser Permanante. 2009:1-31.
39 Moczygemba LR, Barner JC, Gabrillo ER. Outcomes of a Medicare Part D telephone medication therapy management program. 2012;52:E144.
40 Moczygemba LR, Barner JC, Lawson KA, et al. Impact of telephone medication therapy management on medication and health-related problems, medication adherence, and Medicare Part D drug costs: a 6-month follow up. Am J Geriatr Pharmacother. Oct. 2011;9(5):328-38. Epub: 2011/08/26. [pmid: 21865093].
41 Moczygemba LR, Barner JC, Gabrillo ER, et al. Development and implementation of a telephone medication therapy management program for Medicare beneficiaries. Am J Health Syst Pharm. Sep. 1. 2008;65(17):1655-60. Epub: 2008/08/21. [pmid: 18714113].
42 Pindolia VK, Stebelsky L, Romain TM, et al. Mitigation of medication mishaps via medication therapy management. Ann Pharmacother. Apr. 2009;43(4):611-20. Epub: 2009/04/02. [pmid: 19336646].
43 Staresinic AG. Early experience with medication management - Description and preliminary outcomes of a Medicare Part D medication therapy management program. J Pharm Soc Wis. SEP-OCT. 2007:8-0.
44 Welch EK, Delate T, Chester EA, et al. Assessment of the impact of medication therapy management delivered to home-based Medicare beneficiaries. Ann Pharmacother. Apr. 2009;43(4):603-10. Epub: 2009/03/26. [pmid: 19318600].
45 Moore JM, Shartle D, Faudskar L, et al. Impact of a patient-centered pharmacy program and intervention in a high-risk group. J Manag Care Pharm. Apr. 2013;19(3):228-36. Epub: 2013/03/30. [pmid: 23537457].
46 Jeong E, Pitcher K, Fredriks D, et al. Clinical & Safety Outcomes from a Pharmacist-managed Medicare Medication Therapy Management Program. Kaiser Permanente.
47 Jeong E, Deguzman L, Fredriks D, et al. Comprehensive Medication Reviews Improve Hospitalization and Emergency Department Outcomes. Kaiser Permanente. 2012.
48 Yamada B. Comparison of Outcomes in the Medicare Medication Therapy Management Program within Kaiser Permanente California. 2012.
49 Christensen DB, Roth M, Trygstad T, et al. Evaluation of a pilot medication therapy management project within the North Carolina State Health Plan. J Am Pharm Assoc (2003). Jul-Aug. 2007;47(4):471-83. Epub: 2007/07/10. [pmid: 17616493].
50 Jameson J, VanNoord G, Vanderwoud K. The impact of a pharmacotherapy consultation on the cost and outcome of medical therapy. J Fam Pract. Nov. 1995;41(5):469-72. Epub: 1995/11/01. [pmid: 7595265].
51 Malone DC, Carter BL, Billups SJ, et al. An economic analysis of a randomized, controlled, multicenter study of clinical pharmacist interventions for high-risk veterans: the IMPROVE study. Impact of Managed Pharmaceutical Care Resource Utilization and Outcomes in Veterans Affairs Medical Centers. Pharmacotherapy. Oct. 2000;20(10):1149-58. Epub: 2000/10/18. [pmid: 11034037].
52 Ellis SL, Billups SJ, Malone DC, et al. Types of interventions made by clinical pharmacists in the IMPROVE study. Impact of Managed Pharmaceutical Care on Resource Utilization and Outcomes in Veterans Affairs Medical Centers. Pharmacotherapy. Apr. 2000;20(4):429-35. Epub: 2000/04/20. [pmid: 10772374].
53 Ellis SL, Carter BL, Malone DC, et al. Clinical and economic impact of ambulatory care clinical pharmacists in management of dyslipidemia in older adults: the IMPROVE study. Impact of Managed Pharmaceutical Care on Resource Utilization and Outcomes in Veterans Affairs Medical Centers. Pharmacotherapy. Dec. 2000;20(12):1508-16. Epub: 2000/12/29. [pmid: 11130223].
54 Malone DC, Carter BL, Billups SJ, et al. Can clinical pharmacists affect SF-36 scores in veterans at high risk for medication-related problems?. Med Care. Feb. 2001;39(2):113-22. Epub: 2001/02/15. [pmid: 11176549].
55 Sellors J, Kaczorowski J, Sellors C, et al. A randomized controlled trial of a pharmacist consultation program for family physicians and their elderly patients. CMAJ. Jul. 8. 2003;169(1):17-22. Epub: 2003/07/09. [pmid: 12847034].
56 Sidel VW, Beizer JL, Lisi-Fazio D, et al. Controlled study of the impact of educational home visits by pharmacists to high-risk older patients. J Community Health. Jun. 1990;15(3):163-74. Epub: 1990/06/01. [pmid: 2195066].
57 Winston S, Lin YS. Impact on drug cost and use of Medicare part D of medication therapy management services delivered in 2007. J Am Pharm Assoc (2003). Nov-Dec. 2009;49(6):813-20. Epub: 2009/10/28. [pmid: 19858047].
58 Witry MJ, Doucette WR, Gainer KL. Evaluation of the pharmaceutical case management program implemented in a private sector health plan. J Am Pharm Assoc (2003). Sep-Oct. 2011;51(5):631-5. Epub: 2011/09/08. [pmid: 21896463].
59 Gattis WA, Hasselblad V, Whellan DJ, et al. Reduction in heart failure events by the addition of a clinical pharmacist to the heart failure management team: results of the Pharmacist in Heart Failure Assessment Recommendation and Monitoring (PHARM) Study. Arch Intern Med. Sep. 13. 1999;159(16):1939-45. Epub: 1999/09/24. [pmid: 10493325].
60 Shimp LA, Kucukarslan SN, Elder J, et al. Employer-based patient-centered medication therapy management program: evidence and recommendations for future programs. J Am Pharm Assoc (2003). 2012;52(6):768-76. Epub: 2012/12/12. [pmid: 23229963].
61 Sellors C, Dalby DM, Howard M, et al. A pharmacist consultation service in community-based family practices: a randomized, controlled trial in seniors. J Pharm Technol. 2001;(6):264-9.
62 Perlroth D, Marrufo G, Montesinos A, et al. Medication Therapy Management in Chronically Ill Populations: Final Report. Contract # HHSM-500-2011-00012I/TOT0001. Baltimore, MD. Centers for Medicare & Medicaid Services (CMS) Center for Medicare & Medicaid Innovation. 2013. http://innovation.cms.gov/Files/reports/MTM_Final_Report.pdf.
63 McDonough RP, Doucette WR, Kumbera P, et al. An evaluation of managing and educating patients on the risk of glucocorticoid-induced osteoporosis. Value Health. Jan-Feb. 2005;8(1):24-31. Epub: 2005/04/22. [pmid: 15841891].
64 Bernsten C, Bjorkman I, Caramona M, et al. Improving the well-being of elderly patients via community pharmacy-based provision of pharmaceutical care: a multicentre study in seven European countries. Drugs Aging. 2001;18(1):63-77. Epub: 2001/03/10. [pmid: 11232739].
65 Sturgess IK, McElnay JC, Hughes CM, et al. Community pharmacy based provision of pharmaceutical care to older patients. Pharm World Sci. Oct. 2003;25(5):218-26. Epub: 2003/10/31. [pmid: 14584229].
66 Brummel AR, Soliman AM, Carlson AM, et al. Optimal diabetes care outcomes following face-to-face medication therapy management services. Popul Health Manag. Feb. 2013;16(1):28-34. Epub: 2012/11/02. [pmid: 23113628].
67 Soliman AM, Carlson AM, MacLehose RF, et al. Patient characteristics predicting the frequency of medication therapy management visits for patients with diabetes. Clin Ther. Apr. 2013;35(4):534-40. Epub: 2013/04/02. [pmid: 23541131].
68 Ramalho de Oliveira D, Brummel AR, Miller DB. Medication therapy management: 10 years of experience in a large integrated health care system. J Manag Care Pharm. Apr. 2010;16(3):185-95. Epub: 2010/03/25. [pmid: 20331323].
69 Touchette DR, Masica AL, Dolor RJ, et al. Safety-focused medication therapy management: a randomized controlled trial. J Am Pharm Assoc (2003). Sep-Oct. 2012;52(5):603-12. Epub: 2012/10/02. [pmid: 23023840].
70 Carter BL, Barnette DJ, Chrischilles E, et al. Evaluation of hypertensive patients after care provided by community pharmacists in a rural setting. Pharmacotherapy. Nov-Dec. 1997;17(6):1274-85. Epub: 1997/12/17. [pmid: 9399611].
71 Barnette DJ, Murphy CM, Carter BL. Clinical skill development for community pharmacists. J Am Pharm Assoc (Wash). Sep. 1996;NS36(9):573-80. Epub: 1996/09/01. [pmid: 8824077].
72 Clifford RM, Batty KT, Davis TME, et al. A randomised controlled trial of a pharmaceutical care programme in high-risk diabetic patients in an outpatient clinic. Int J Pharm Pract. 2002;10(2):85-9.
73 Pai AB, Boyd A, Depczynski J, et al. Reduced drug use and hospitalization rates in patients undergoing hemodialysis who received pharmaceutical care: a 2-year, randomized, controlled study. Pharmacotherapy. Dec. 2009;29(12):1433-40. Epub: 2009/12/02. [pmid: 19947803].
74 Pai AB, Boyd A, Chavez A, et al. Health-related quality of life is maintained in hemodialysis patients receiving pharmaceutical care: a 2-year randomized, controlled study. Hemodial Int. Jan. 2009;13(1):72-9. Epub: 2009/02/13. [pmid: 19210281].
75 Marques LA, Galduroz JC, Fernandes MR, et al. Assessment of the effectiveness of pharmacotherapy follow-up in patients treated for depression. J Manag Care Pharm. Apr. 2013;19(3):218-27. Epub: 2013/03/30. [pmid: 23537456].
76 Hirsch JD, Gonzales M, Rosenquist A, et al. Antiretroviral therapy adherence, medication use, and health care costs during 3 years of a community pharmacy medication therapy management program for Medi-Cal beneficiaries with HIV/AIDS. J Manag Care Pharm. Apr. 2011;17(3):213-23. Epub: 2011/03/26. [pmid: 21434698].
77 Hirsch JD, Rosenquist A, Best BM, et al. Evaluation of the first year of a pilot program in community pharmacy: HIV/AIDS medication therapy management for Medi-Cal beneficiaries. J Manag Care Pharm. Jan-Feb. 2009;15(1):32-41. Epub: 2009/01/08. [pmid: 19125548].
78 Roughead EE, Barratt JD, Ramsay E, et al. The effectiveness of collaborative medicine reviews in delaying time to next hospitalization for patients with heart failure in the practice setting: results of a cohort study. Circ Heart Fail. Sep. 2009;2(5):424-8. Epub: 2009/10/08. [pmid: 19808372].
79 Chrischilles EA, Carter BL, Lund BC, et al. Evaluation of the Iowa Medicaid pharmaceutical case management program. J Am Pharm Assoc (2003). May-Jun. 2004;44(3):337-49. Epub: 2004/06/12. [pmid: 15191244].
80 Wittayanukorn S, Westrick SC, Hansen RA, et al. Evaluation of medication therapy management services for patients with cardiovascular disease in a self-insured employer health plan. J Manag Care Pharm. Jun. 2013;19(5):385-95. Epub: 2013/05/24. [pmid: 23697476].
81 Isetts BJ, Schondelmeyer SW, Artz MB, et al. Clinical and economic outcomes of medication therapy management services: the Minnesota experience. J Am Pharm Assoc. Mar-Apr. 2008;48(2):203-11. 3 p following 11. Epub: 2008/03/25. [pmid: 18359733].
82 Fischer LR, Defor TA, Cooper S, et al. Pharmaceutical care and health care utilization in an HMO. Eff Clin Pract. Mar-Apr. 2002;5(2):49-57. Epub: 2002/05/07. [pmid: 11990212].
83 Fischer LR, Scott LM, Boonstra DM, et al. Pharmaceutical care for patients with chronic conditions. J Am Pharm Assoc (Wash). Mar-Apr. 2000;40(2):174-80. Epub: 2000/03/24. [pmid: 10730021].
84 Hanlon JT, Weinberger M, Samsa GP, et al. A randomized, controlled trial of a clinical pharmacist intervention to improve inappropriate prescribing in elderly outpatients with polypharmacy. Am J Med. Apr. 1996;100(4):428-37. Epub: 1996/04/01. [pmid: 8610730].
85 Taylor CT, Byrd DC, Krueger K. Improving primary care in rural Alabama with a pharmacy initiative. Am J Health Syst Pharm. Jun. 1. 2003;60(11):1123-9. Epub: 2003/06/21. [pmid: 12816022].
86 Volume CI, Farris KB, Kassam R, et al. Pharmaceutical care research and education project: patient outcomes. J Am Pharm Assoc (Wash). May-Jun. 2001;41(3):411-20. Epub: 2001/05/25. [pmid: 11372906].
87 Kassam R, Farris KB, Burback L, et al. Pharmaceutical care research and education project: pharmacists' interventions. J Am Pharm Assoc (Wash). May-Jun. 2001;41(3):401-10. Epub: 2001/05/25. [pmid: 11372905].
88 Grymonpre RE, Williamson DA, Montgomery PR. Impact of a pharmaceutical care model for non-institutionalised elderly: results of a randomised, controlled trial. Int J Pharm Pract. 2001;(4):235-41.
89 Park JJ, Kelly P, Carter BL, et al. Comprehensive pharmaceutical care in the chain setting. J Am Pharm Assoc (Wash). Jul. 1996;NS36(7):443-51. Epub: 1996/07/01. [pmid: 8840744].
90 Planas LG, Crosby KM, Mitchell KD, et al. Evaluation of a hypertension medication therapy management program in patients with diabetes. J Am Pharm Assoc (2003). Mar-Apr. 2009;49(2):164-70. Epub: 2009/03/18. [pmid: 19289342].
91 Krska J, Cromarty JA, Arris F, et al. Pharmacist-led medication review in patients over 65: a randomized, controlled trial in primary care. Age Ageing. May. 2001;30(3):205-11. Epub: 2001/07/10. [pmid: 11443021].
92 Williams ME, Pulliam CC, Hunter R, et al. The short-term effect of interdisciplinary medication review on function and cost in ambulatory elderly people. J Am Geriatr Soc. Jan. 2004;52(1):93-8. Epub: 2003/12/23. [pmid: 14687321].
93 Blakey SA, Hixson-Wallace JA. Clinical and economic effects of pharmacy services in a geriatric ambulatory clinic (Structured abstract). Pharmacotherapy. 2000;(10):1198-203. NHSEED-22000001609. [pmid: 11034043].
94 Cowper PA, Weinberger M, Hanlon JT, et al. The cost-effectiveness of a clinical pharmacist intervention among elderly outpatients. Pharmacotherapy. Mar-Apr. 1998;18(2):327-32. Epub: 1998/04/17. [pmid: 9545151].
95 Chisholm-Burns MA, Kim Lee J, Spivey CA, et al. US pharmacists' effect as team members on patient care: systematic review and meta-analyses. Med Care. Oct. 2010;48(10):923-33. Epub: 2010/08/20. [pmid: 20720510].
96 Bradley EH, Curry LA, Ramanadhan S, et al. Research in action: using positive deviance to improve quality of health care. Implement Sci. 2009;4:25. Epub: 2009/05/12. [pmid: 19426507].
97 Brown CA, Lilford RJ. The stepped wedge trial design: A systematic review. BMC Med Res Methodol. 2006;6:54. Epub: 2006/11/10. [pmid: 17092344].