# Introduction

## Context

Used appropriately, medications can alleviate distressing symptoms that compromise physical and psychological well-being, help prevent the onset of many acute and chronic health illnesses, and improve patient health outcomes. Too often, however, medications are not used appropriately. The Institute of Medicine and other prominent organizations have recognized that medication-related problems plague our health care system.1-3 In the United States in 2001, an estimated 4.3 million ambulatory visits were for adverse drug events.4 A cohort study of Medicare enrollees estimated the overall rate of adverse drug events at 50.1 per 1,000 person-years.5 The study rated more than one-third of the adverse drug events as serious, life-threatening, or fatal; more than 40 percent of these more severe adverse drug events were classified as preventable. Another study found that more than 12 percent of hospitalized patients experienced an adverse drug event within 3 weeks following hospital discharge.6

In addition to problems involving adverse drug events, many patients are not prescribed optimal treatment for chronic conditions such as high blood pressure and hyperlipidemia that increase their risk of cardiovascular disease and its complications. Moreover, even when optimal therapy is prescribed, patient inability to adhere closely to medication regimens may lead to poor health outcomes.7

Medication-related problems are especially pronounced among older adults.5 Individuals 65 years or older constitute 13 percent of the U.S. population, but they consume more than 30 percent of all prescription medications.5,8 A 2006 report found that nearly 60 percent of people in this age group were taking five or more medications and that nearly 20 percent were taking 10 or more medications,9 placing them at increased risk for experiencing adverse drug events. Moreover, these figures reflect a substantial increase in the prevalence of polypharmacy since 1998.^9^

Medication therapy management (MTM) services are intended to address issues of polypharmacy, preventable adverse drug events, medication adherence, and medication misuse.10 MTM services are designed to be distinct from medication-dispensing services; in particular, they employ a patient-centric and comprehensive approach, rather than an individual product or episodic perspective.11

MTM is the current term that represents a suite of health care services that have evolved out of the philosophy and processes described in the early 1990s as “pharmaceutical care.”10 Similar to the concept of medical care or nursing care, pharmaceutical care is a term that describes professional pharmacy practice, not a discrete intervention. The Medicare Prescription Drug, Improvement, and Modernization Act of 2003 (Public Law 108-173)12 expanded patient access to MTM services and identified the following as goals for MTM services within Medicare Part D: (1) educate and counsel to improve patient understanding of their medications, (2) improve adherence, and (3) detect adverse drug reactions and improper medication use. This law also established the requirements that Medicare Part D Prescription Drug Benefit Plan sponsors have to meet with respect to cost, quality, and the requirements for MTM programs sponsored by Part D drug benefit plans. The law established oversight for Part D MTM programs by the Centers for Medicare & Medicaid Services (CMS) and provided a general framework for MTM programs but allowed Part D Plan sponsors flexibility in design, including the patient eligibility criteria for services. The CMS requirements for Part D MTM programs have evolved since their implementation in 2006.

Within a year of the passage of Medicare Part D, 11 national pharmacy organizations established a consensus definition of MTM.13 “MTM is a distinct service or group of services that optimize therapeutic outcomes for individual patietns.”13, ^p. 572^ This definition further describes MTM as “a broad range of professional activities and responsibilities within the licensed pharmacist's, or other qualified healthcare provider's scope of practice.”13, ^p. 72^ Table 1 lists the types of services that can be considered under the umbrella MTM definition.

Table 1 MTM services

Services defined as MTM14
Medication therapy reviews
Pharmacotherapy consults Disease management coach/support
Pharmacogenomic applications
Anticoagulation management
Immunizations
Health, wellness, and public health
Medication safety surveillance
Other clinical services

The pharmacy profession has developed or supported additional efforts to standardize and establish the infrastructure for MTM service delivery. In 2008, a subset of national pharmacy organizations published the second version of core elements for an MTM service model. This model established five core elements for use in practice, including a medication therapy review, a personal medication record, a medication-related action plan, intervention and/or referral, and documentation and followup.10,15 Also in 2008, Current Procedural Terminology (CPT^®^) codes were established to provide a mechanism for reimbursement for services related to medication management. These CPT codes define MTM as “services provided by a pharmacist to optimize the response to medications for the management of treatment-related medication problems or complications.” More recently, the Patient-centered Primary Care Collaborative established its definition of comprehensive medication management to describe MTM in the context of a patient-centered medical home, which includes elements of the CPT definition.16,17 The evolution from isolated research interventions studying the impact of pharmaceutical care interventions to large-scale, commercial MTM programs or collaborative medication management within primary care represents a journey along a continuum of practice settings, patient populations, and intervention components and features. Over time, the practice and standards for these services have evolved, as have standards for describing and conducting research studies involving these interventions. Thus, establishing the scope of this review was very challenging. A broadly defined scope (all clinical pharmacist interventions regardless of setting or patient population) risks including studies that may be too different from each other to allow for meaningful comparison and synthesis. A narrowly defined scope (e.g., a focus exclusively on Medicare Part D-defined MTM programs) risks the omission of studies that met the definition of MTM, but that predated the Part D era, were conducted in other countries, or used patient eligibility criteria that are less restrictive than Part D. In the next section, we describe background related to population, intervention, comparison, outcomes, timing, and setting (“PICOTS”) that we relied on to establish the scope of this review. Throughout this review, we will use the term MTM to describe the general class of intervention. However, when describing individual studies included in this review, we will defer to the terms used by the study author to describe the intervention they were evaluating (e.g., pharmaceutical care, clinical pharmacy services, or MTM).

### Populations

Adult patients with multiple chronic conditions who take many different prescription or nonprescription medications, herbal products, or diet supplements (and combinations of these) are the target population for most outpatient-based MTM services.11 Because older adults are more likely to take multiple medications, MTM services generally target them. However, MTM interventions may also target patients taking a single high-risk medication (e.g., Coumadin) or may target patients at high risk for an adverse drug event, for example, during a transition in care from a hospital to home setting. Although some children with complex medication regimens may benefit from MTM, these program are typically designed and delivered to adults.

As part of Medicare Part D implementation, CMS required that MTM programs target Medicare Part D enrollees, who have multiple chronic diseases, are taking multiple Part D drugs, and are likely to incur annual costs for covered Part D drugs that exceed a predetermined level (“annual cost threshold”). To be eligible for CMS reimbursement, MTM programs originally had to offer services for at least four of seven core chronic diseases: hypertension, chronic heart failure, diabetes, dyslipidemia, respiratory disease (e.g., asthma, chronic obstructive pulmonary disease), bone disease (e.g., osteoporosis, osteoarthritis, rheumatoid arthritis), and mental health diseases. As of January 2013, this criterion specifies at least five of nine core chronic conditions—Alzheimer's disease and end-stage renal disease were the added conditions. Programs may require no more than eight Part D drugs, although they may set the maximum at any number between two and eight. CMS set the annual cost threshold at $4,000 in 2006, lowered it to $3,000 in 2010, and increased it by an annual percentage each year beginning in 2012. The cost threshold for 2013 is $3,144. CMS reimburses for MTM services for both community-dwelling beneficiaries and beneficiaries in long-term care settings. Although initial Part D MTM programs were designed as “opt-in,” more recently, MTM programs must enroll eligible beneficiaries using an “opt-out” approach.

Health care systems, pharmacy benefit management organizations, large self-insured employers, community pharmacies, or individual medical practices may also provide MTM services to beneficiaries who do not have Medicare Part D or who do not meet the CMS Part D criteria. For example, the Veterans Health Administration (VHA) includes MTM as one of several clinical activities provided to VHA health beneficiaries by VHA pharmacy services.18 The VHA does not specify patient eligibility criteria for MTM services. Non-Part D MTM programs and research studies of MTM interventions may define their own patient eligibility criteria, which may or may not be similar to current CMS criteria, for example, requiring only one chronic condition to be eligible for services.

### Interventions and Comparators

As discussed, several pharmacy organizations have proposed core elements for an MTM service model.10,11 These features can be summarized as follows:

- A comprehensive medication review (CMR) to identify and resolve medication-related problems.
- The generation of a personal medication report, which is a written list of the patient's prescription and nonprescription drugs, herbal products, and dietary supplements.
- A patient-directed medication action developed in collaboration with the patient.
- Education, counseling, and resources to enhance patients' understanding about using the medication and to improve adherence.
- Coordination of care, including documenting MTM services and providing that documentation to the patient's other providers and referring patients to other providers as needed.

CMS requires that each beneficiary enrolled in a Part D MTM program be offered a minimum level of MTM services. These include:

- Interventions for both beneficiaries and prescribers;
- An annual CMR with written summaries in CMS's standardized format:
  ○ The beneficiary's CMR must include an interactive, person-to-person, or telehealth consultation that is performed by a pharmacist or other qualified provider (e.g., a nurse or a physician) and may result in a recommended medication action plan.
  ○ If a beneficiary is offered the annual CMR and is unable to accept the offer to participate, the pharmacist or other qualified provider may perform the CMR with the beneficiary's prescriber, caregiver, or other authorized individual; and
- Quarterly targeted medication reviews with followup interventions when necessary.

CMS expects the CMR to meet the following professional service definition: “a systematic process of collecting patient-specific information, assessing medication therapies to identify medication-related problems, and developing a prioritized list of medication-related problems, and creating a plan to resolve them with the patient, caregiver, and/or prescriber.”19, ^p. 6^ In addition, CMS expects the CMR to be “an interactive person-to-person or telehealth medication review and consultation conducted in real time between the patient and/or other authorized individual, such as [a] prescriber or caregiver, and the pharmacist or other qualified provider. It is designed to improve patients' knowledge of their prescriptions, over-the-counter medications, herbal therapies, and dietary supplements; identify and address problems or concerns that patients may have; and empower patients to self-manage their medications and their health conditions.”19, ^p.6^ Written summaries of the CMR are to be provided in CMS's standardized written format that includes a beneficiary cover letter, medication action plan, and personal medication list.19

The service-level expectations of a CMR align closely with the definition of MTMs contained in the official health-reporting nomenclature of CPT.^®^20,21 The CPT MTM codes define three components that may each vary in complexity or time required to complete. These components are (1) assessment of drug-related needs, (2) identification of drug therapy problems, and (3) complexity of care planning and followup evaluation. Recently, transitional management CPT codes have been established for use within the first 29 days of patient discharge from an acute care facility. These codes also include elements of medication management, specifically medication reconciliation. MTM CPT codes cannot be used by the same professional in the same time frame as transitional care management codes, suggesting that the medication management activities during transitions of care are a distinct category of MTM services.22

Disease-management, case-management, and self-management interventions have components that overlap with MTM components—for example, provision of education and counseling to increase medication adherence or coordination of care. Our preliminary literature search yielded many pharmacist-led interventions that were termed as one of these three types of interventions (e.g., a pharmacist-led diabetes disease management intervention). We relied on the descriptions in the Robert Wood Johnson Foundation Research Synthesis Report “Care management of patients with complex health care needs” for guidance to make distinctions between MTM and care management, case management, and disease management interventions.23 We determined that our inclusion and exclusion criteria related to the intervention needed to define specific MTM intervention components, such that we would identify relevant studies whether they were called “MTM” or not. We also considered the topic nominator's original request, which was to consider different models for assisting patients in managing their medications for chronic disease among patients with multiple conditions. Thus, we synthesized our findings from the preliminary literature search; our exploration of case management, care management, and disease management definitions; and the topic nominator's original request to determine that our intervention criteria needed to narrowly define multiple intervention components related to medication management, but that these components needed to be applied broadly to patients across their entire medication regimen. As a result, MTM services such as pharmacist-led single-disease management programs or anticoagulation clinics would not be considered for inclusion in our review. By bounding the review in this way, we end up with a more homogenous set of studies to synthesize.

### Outcomes

MTM is thought to influence a wide variety of outcomes. Two of the most common outcomes measured in MTM studies are drug therapy problems identified and drug therapy problems resolved. Taxonomies to describe drug therapy problems exist, but our preliminary literature search revealed many different approaches to measuring and reporting these outcomes. Other MTM outcomes relate to intermediate health outcomes measured typically by laboratory or other biometric tests for common chronic conditions; these may include hemoglobin A_1c_, blood pressure, cholesterol (e.g., total, low-density lipoprotein, and high-density lipoprotein cholesterol), and cardiac or pulmonary function (e.g., left ventricular ejection fraction, spirometry). Finally, still other MTM services relate to patient-centered outcomes (e.g., morbidity, mortality, adverse drug events, missed days of work or school, patient satisfaction with care, health-related quality of life).24 The impact of MTM on health care utilization, intermediate health outcomes, and patient-centered outcomes may derive from identification and resolution of drug therapy problems, including improved medication adherence, fewer drug-related adverse events, and more efficient coordination of care.

### Settings

MTM services can be delivered in a variety of settings. These include inpatient facilities, ambulatory care settings (e.g., outpatient clinics, physician practices), retail pharmacies in the community, and long-term care settings such as assisted living or skilled nursing facilities. In addition, telephone-based MTM services may be provided to community-dwelling adults by professional staff (often pharmacists) employed by pharmacy benefits management companies or other commercial health care companies that have centralized call centers. The setting in which MTM is delivered depends on the type of provider delivering the service and the goals and scope of the MTM program. Because MTM refers to a wide variety of services, a review of such interventions needs to be bounded to ensure that the interventions synthesized in the review are reasonably comparable. For example, studies focused on MTM services provided during and shortly after an acute hospital stay may not be comparable to MTM services provided to outpatients because the goals of therapy and the acuity of the patient's status are very different. Based on our preliminary literature search, we found that most studies in inpatient settings were focused either on single-medication reconciliation interventions during or at discharge or focused on integrated clinical pharmacy management in acute settings. We also considered the topic nominator's proposed research questions, which were decidedly focused on MTM provided to outpatients.

### Timing

Because MTM is used to define a broad range of services, MTM services can be provided as one-time interventions or longitudinally during multiple episodes of care depending on the specific type of MTM service and care setting. For example, medication reconciliation or immunization is a type of MTM service that is typically done during a single episode of care. The pharmacy profession consensus definition for MTM includes monitoring and evaluation of a patient's response to therapy, and the MTM Core Service Model includes followup as a component. Similarly, CPT codes for MTM services include a component involving complexity of care planning and followup. Requirements for Medicare Part D MTM programs include a followup component at least quarterly following an initial comprehensive medication review. Thus, we determined that we needed to establish inclusion criteria to distinguish interventions designed to support longitudinal medication management as opposed to studies of one-time interventions.

### Contextual Factors

Our preliminary literature search identified pharmacists as the typical interventionist for providing MTM services. CMS guidelines require that MTM be delivered by a pharmacist or other qualified health care provider. Professional pharmacy organizations have been actively involved in proposing delivery models, standards, and recommendations for MTM services. Pharmacist training varies considerably. Before the 1990s, individuals could become registered pharmacists with a bachelor of science (B.S.) degree that required a minimum of 5 years of study. Current regulations require that individuals have a doctor of pharmacy (Pharm.D.) degree, which requires a minimum of 6 years of study and provides more clinical training than B.S. programs. In addition, many Pharm.D. graduates pursue advanced training through residency, fellowship, and certificate programs. Some of these programs focus on areas such as MTM. The influence that interventionist type (e.g., physician, nurse pharmacist), education, and MTM-specific training have on MTM effectiveness is unknown.

Numerous factors other than clinical specialty may affect the quality of MTM services. Mode, frequency, and interval of delivery may influence MTM success, as may specific MTM components and the fidelity of their implementation. One key factor is how well an MTM provider understands the patient-specific goals of medication therapy. Integrating MTM services with usual care may help ensure that the goals of MTM are achieved. Integration of services and usual care refers to the ability of the MTM provider to bidirectionally communicate with patients and multiple prescribers and ease of MTM interventionist access to patients' medical records.

Health care reimbursement systems may also influence the delivery of MTM services. Not all private insurers cover MTM services. The degree to which MTM component services differ for Medicare beneficiaries when compared with non-Medicare beneficiaries is not known.

Finally, certain patient populations may have considerable difficulty accessing or participating in MTM services. Examples include individuals who are homebound, individuals who have physical or cognitive disabilities, patients without health insurance, and patients living in rural areas.

## Scope and Key Questions

### Scope of the Review

MTM is a complex intervention, which could have different components depending on the goals and scope of the MTM program. This review seeks to catalog outpatient-based MTM interventions, assess the overall effectiveness of outpatient-based MTM in comparison with usual care, examine the factors under which outpatient-based MTM is effective and optimally delivered, assess what types of patients are likely to benefit from outpatient-based MTM services, and assess what types of patients may be at risk of harms from such programs. This review does not address (1) MTM services provided within inpatient settings or shortly after hospital discharge, (2) disease management services provided by pharmacists, or (3) interventions designed as a single episode of contact. The rationale for limiting the scope to exclude some types of MTM interventions is to ensure that included studies are reasonably comparable with respect to intended goals and purpose of the MTM intervention.

### Relevance of Research Question to Clinical Decisionmaking or Policymaking

The Key Questions (KQs) we address are highly relevant to both clinical decisionmaking and policies regarding MTM services. Identifying demonstrably effective models and components of MTM services will help patients and their health care providers achieve important intermediate and long-term health-related outcomes. Our findings will help providers of MTM services, particularly pharmacists and pharmacy benefit managers, understand what works well in which settings and with which patients; the findings will have the potential to improve the efficiency of delivery and thus improve the value of MTM services. Lastly, a better understanding of the comparative effectiveness of MTM services will assist CMS with future revisions or enhancements to the policies governing coverage for MTM services.

### Key Questions

The KQs are listed below and placed in relation to another and the PICOs in the analytic framework (Figure 1). Specific details regarding patient population, intervention components, and outcomes are provided in the section that follows the analytic framework.

Figure 1 Analytic framework for outpatient medication therapy management

^a^ The population, intervention, outcomes, and setting are described in detail in the text.

Abbreviations: KQ = Key Question; MTM = medication therapy management.

Figure 1 depicts the Analytic Framework which places the key questions within the context of the PICOTS, which are described in the next section. In general, the figure illustrates how medication therapy management (MTM) may lead to changes in intermediate outcomes (KQ2), such as patient laboratory or biometric values (e.g., HgbA1c, blood pressure), medication adherence, identification and resolution of drug therapy problems, goals of therapy met, and patient engagement; changes in patient-centered outcomes (KQ2), such as disease-specific or all-cause morbidity and mortality, adverse drug events, health-related quality of life, activities of daily living, patient satisfaction with health care, work or school absenteeism, and patient participation in medical care and decision making; or changes in resource utilization outcomes (KQ2), such as prescription drug costs, other health care costs, and avoidable healthcare utilization. In addition, the figure illustrates how features of MTM implementation (described in KQ1), including mode of delivery, the type of professional delivering initial and follow-up services, the frequency and interval of follow-up, specific MTM components, the fidelity of implementation, goals of therapy established and communicated, the setting in which MTM is delivered, how patients are enrolled, integration of MTM with usual care, health system characteristics, and reimbursement characteristics, may affect the comparative effectiveness of MTM services (KQ3). Demographic and other patient factors, such as age, sex, race and ethnicity, socioeconomic status, health insurance status, educational level, health literacy status, cognitive impairment, number and types of chronic conditions, number and types of medications, social support, and urban or rural status, may also influence outcomes (KQ4). Also, harms may occur at any point after the MTM is received and may include increased adverse drug events, care fragmentation, patient confusion, anxiety, decisional conflict and dissatisfaction, or prescriber confusion and dissatisfaction (KQ5). Specific outcomes and features are defined in greater detail in the PICOTS section of the Introduction.

#### Analytic Framework

KQ 1: What are the components and implementation features of outpatient MTM interventions?

KQ 2: In adults with one or more chronic diseases who are taking prescription medications, is MTM effective in improving the following:

a. Intermediate outcomes, including biometric and laboratory measures, drug therapy problems identified, drug therapy problems resolved, medication adherence, goals of therapy met, and patient engagement in medication management?
b. Patient-centered outcomes, such as disease-specific morbidity, disease-specific or all-cause mortality, adverse drug events, health-related quality of life, activities of daily living, patient satisfaction with health care, work or school absenteeism, and patient and caregiver participation in medical care and decisionmaking?
c. Resource utilization, such as prescription drug costs, other health care costs, and health care utilization?

KQ 3: Does the effectiveness of MTM differ by MTM components and implementation features?

KQ 4: Does the effectiveness of MTM differ by patient characteristics, including but not limited to patient demographics and numbers and types of conditions and medications?

KQ 5: Are there harms of MTM, and if so, what are they?

## Populations, Interventions, Comparators, Outcomes, Timing, and Setting (PICOTS)

Table 2 lays out the PICOTS for this review. For this review, we take a broad perspective on the population evaluated; we do not limit the review to populations meeting CMS Part D MTM eligibility criteria. Specifically, we did not require multiple chronic conditions or a minimum number or level of expenditures on prescription drugs. For the intervention, we required a comprehensive medication review, patient-directed education or counseling, an element of provider followup, and care coordination as the minimum intervention criteria. We established several eligible comparators and detailed intermediate process or health outcomes, patient-centered outcomes, and health care utilization outcomes. We also identified some potential harm outcomes, including patient confusion or decision conflict. Lastly, we established exclusion criteria related to studies conducted in inpatient settings or shortly after an inpatient stay and required the intervention to be designed such that followup to patients was available, regardless of whether the patient actually received any followup.

Table 2 Populations, interventions, comparators, outcomes, timing, and settings

PICOTS | Inclusion and Exclusion Criteria and Relevant Factors for Study Abstraction
Populations | Inclusion criteria; - Patients ages 18 or older with one or more chronic conditions requiring the use of prescription medication to manage symptoms or prevent progression of chronic disease; Exclusion criteria; - Patients in long-term or acute care settings without access or control over their own medication administration.; Relevant factors; - Patient characteristics that may influence intervention effectiveness:; ○ Age, sex, race and ethnicity, socioeconomic status, health insurance status, education level, health literacy status, cognitive impairment, number and types of chronic conditions, social support, and urban/rural status
Interventions | Inclusion criteria; - A bundle of medication-related services described by the term “MTM” or “pharmaceutical care” or “clinical pharmacy services” or a similar phrase, that include at a minimum the following three elements:; ○ Comprehensive medication review covering all prescription and nonprescription drugs, herbs, and supplements taken by the patient; ○ Patient-directed education and counseling or other resources to enhance understanding of the use of medication; ○ Coordination of care, including prescriber-directed interventions; documentation of MTM services for use by the patient's other providers; and referral to other providers, clinicians, or resources when appropriate19; Exclusion criteria; - The following types of interventions will be excluded:; ○ Medication reconciliation interventions that did not include all three elements as described above; - The following types of interventions may include MTM services, but MTM may represent only one component of the overall intervention:; ○ Disease-management interventions23; ○ Case- or care-management interventions23; ○ Patient-centered medical home models of care; ○ Fully integrated, collaborative care models involving multiple disciplines and specialties; - These types of interventions will be excluded unless studies contain the same level of overall medical care or services among different study arms such that the effect of MTM can be isolated. For example, a study with two arms that has one arm with a care management intervention that includes MTM services and the other arm that has the care management intervention without MTM services could be included. By contrast, a study that includes a care management intervention with MTM in one arm and usual medical care (no care management intervention) in the other arm would not be included.; Relevant factors; - Implementation features that may influence intervention effectiveness include the following:; ○ Mode of delivery: telephone, face-to-face, virtual (Web/online/Internet), and remote video; ○ Type of professional providing initial and followup MTM service: pharmacist, nurse, physician, other clinician; ○ Frequency and interval of followup for MTM services; ○ Specific MTM components used; ○ Fidelity in implementing MTM components: to what extent were services delivered as designed or intended; ○ Establishing and communicating goals of drug therapy to patients and among care providers; ○ Method of identifying patients for enrollment (e.g., population health data, provider referral for services, enrollment during a transition in care, targeting highly activated patients, targeting patients at time of high risk for event [e.g., when prescribing a new drug]); ○ Level of integration of MTM with usual care, which includes access to real-time clinical information and laboratory values, and regular and consistent communication among prescribers and persons providing MTM services; ○ Reimbursement characteristics (e.g., who is paying for cost of MTM services, who is reimbursed for MTM services, whether services are separately reimbursable); ○ Health system characteristics (e.g., are services being provided within an accountable care organization, patient-centered medical home, or some other unique system setting, such as the Veterans Health Administration, the Indian Health Service, non–U.S. single-payer system)
Comparators | Inclusion criteria; - Usual care, as defined by the studies; - Different bundles of MTM services (e.g., five components vs. three components); - Same MTM services provided by different health care professionals (e.g., pharmacist vs., physician or nurse); - Same bundle of MTM services delivered by different modes (e.g., telephone vs. in person); - Same bundle of MTM services provided at different intensities, frequencies, or level of integration with prescribers
Outcomes | Inclusion criteria; - Studies must report at least one eligible outcome:; ○ Intermediate outcomes:; – Disease-specific laboratory or biometric outcomes (e.g., hemoglobin A_1c_; blood pressure; total, low-density lipoprotein, or high-density lipoprotein cholesterol; pulmonary function; renal function; left ventricular ejection fraction; or other laboratory or biometric outcome specific to diseases covered); – Drug therapy problems identified as defined by primary studies but typically include the following: medications being taken but not indicated; medications indicated but not prescribed; patient adherence issues; supratherapeutic doses; subtherapeutic doses; generic, formulary, or therapeutic substitution issue; complex regimen that can be simplified with same therapeutic benefit; and potential for drug-drug interactions or adverse event.; – Drug therapy problems that are resolved as defined by primary studies but typically include the following: needed drug initiated; unnecessary drug discontinued; change in drug dose, form, or frequency; or generic, formulary, or therapeutic substitution; – Medication adherence; – Goals of therapy met; – Patient engagement (e.g., initial and continuing patient participation in the MTM program); ○ Patient-centered outcomes; – Disease-specific morbidity, including falls and fall-related morbidity, and outcomes specific to the patient's underlying chronic conditions (e.g., Patient Health Questionnaire 9 [PHQ9], disease-specific symptoms, reduced number of disease-specific acute exacerbations or events); – Disease-specific or all-cause mortality, including fall-related mortality; – Reduced (actual) adverse drug events (frequency and/or severity); – Health-related quality of life as measured by generally accepted generic health-related quality-of-life measures (e.g., short-form questionnaires, EuroQOL) or disease-specific measures; – Activities of daily living as measured by generally accepted standardized measures of basic and/or instrumental activities of daily living (e.g., Katz, Lawton, or Bristol instruments) or with instruments that have demonstrated validity and reliability; – Patient satisfaction with MTM care; – Work or school absenteeism; – Patient and caregiver participation in medical care and decisionmaking; ○ Resource utilization; – Prescription drug costs and appropriate prescription drug expenditures; – Other health care costs; – Health care utilization (hospitalizations, emergency department visits, and physician office visits); ○ Harms; – Care fragmentation; – Patient confusion; – Patient decisional conflict; – Patient anxiety; – Increased (actual) adverse drug events; – Patient dissatisfaction with care; – Prescriber confusion; – Prescriber dissatisfaction
Timing | Inclusion criteria; - Interventions should have at least two separately identifiable episodes of patient-directed MTM services, with any interval of time in between episodes.; - For studies that report outcomes at different points in time, we only considered outcomes measured after the second episode of care and will use the longest-term outcomes reported by the study.; Exclusion criteria; - Interventions designed as single-episode interventions without any provision for followup and monitoring.
Setting | Inclusion criteria; - Ambulatory settings (e.g., outpatient clinics or private physician offices), long-term-care (e.g., assisted living) settings if residents have control over medication self-administration, or retail pharmacy settings; - Home setting; - Interventions conducted in the United States; - Interventions conducted in non-U.S. countries published in English; Exclusion criteria; - MTM services that are delivered exclusively in inpatient settings.; - MTM services delivered at the time of hospital discharge or shortly after (e.g., within a few weeks); Relevant factors; - The MTM intervention itself may be delivered by home visits, by telephone, via the Web, or in other non–face-to-face modalities, such as video teleconferencing.

Abbreviations: MTM = medication therapy management; PICOTS = populations, interventions, comparators, outcomes, timing, and setting; PHQ9 = Patient Health Questionnaire 9.

## Organization of This Report

The remainder of this report describes our methods, presents the results of our synthesis of the literature, discusses our conclusions, and provides other information relevant to the interpretation of this work. The Methods section describes our scientific approach for this systematic review in detail. The Results section presents our findings for all five of the KQs and includes summary and strength-of-evidence tables. In the Discussion section, we summarize the findings and discuss the implications for clinical practice and further research. A complete list of references, acronyms, and abbreviations follows the Discussion section.

This report contains the following appendixes: Appendix A contains the exact search strings we used in our literature searches. Appendix B documents the title and abstract and full-text review forms. Studies excluded at the stage of reviewing full-text articles with reasons for exclusion are presented in Appendix C. Evidence tables appear in Appendix D. Appendix E lists studies rated high risk of bias and reasons for excluding them from relevant KQ analyses. Quantitative analyses are presented in Appendix F.