# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Rowena Dolor, M.D., M.H.S.
  Primary Care Research Consortium
  Duke Clinical Research Institute
  Duke University
  Durham, NC
- William Doucette, Ph.D.
  College of Pharmacy
  University of Iowa
  Iowa City, IA
- C. Bernie Good, M.D., M.P.H.
  Center for Health Equity Research and Promotion
  VA Pittsburgh Healthcare System
  Pittsburgh, PA
- Steve Handler, M.D., Ph.D.
  Department of Biomedical Informatics and Division of Geriatric Medicine
  University of Pittsburgh
  Pittsburgh, PA
- Brian Isetts, Ph.D., B.C.P.S., FAPhA
  College of Pharmacy
  University of Minnesota
  Minneapolis, MN
- Julie Kuhle, R.Ph.
  Senior Director, Performance Measurement
  Pharmacy Quality Alliance, Inc.
  Springfield, VA
- Andrew Masica, M.D., M.S.C.I.
  Baylor Scott & White Health
  Dallas, TX
- James Owen, Pharm.D., B.C.P.S.
  Practice & Science Affairs
  American Pharmacists Association
  Washington, DC
- Alan Zilich, Pharm.D.
  Research Scientist, Roudebush VA Medical Center, Center of Health Information and Communication
  Indianapolis, IN
  Associate Professor, Purdue University College of Pharmacy
  West Lafayette, IN