# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Jamie C. Barner, Ph.D.
  College of Pharmacy
  The University of Texas at Austin
  Austin, TX
- Steve Handler, M.D., Ph.D.
  Department of Biomedical Informatics and Division of Geriatric Medicine
  University of Pittsburgh
  Pittsburgh, PA
- Joseph Hill, M.A.
  American Society of Health-System Pharmacists
  Bethesda, MD
- Brian Isetts, Ph.D., B.C.P.S., FAPhA
  College of Pharmacy
  University of Minnesota
  Minneapolis, MN
- Michelle Ketcham, Pharm.D., M.B.A.
  Medicare Drug Benefit Group
  Centers for Medicare & Medicaid Services
  Baltimore, MD
- Julie Kuhle, R.Ph.
  Senior Director, Performance Measurement
  Pharmacy Quality Alliance, Inc.
  Springfield, VA
- James Owen, Pharm.D., B.C.P.S.
  Practice & Science Affairs
  American Pharmacists Association
  Washington, DC