# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Jamie C. Barner, Ph.D.
  College of Pharmacy
  The University of Texas at Austin
  Austin, TX
- Steve Handler, M.D., Ph.D.
  Department of Biomedical Informatics and Division of Geriatric Medicine
  University of Pittsburgh
  Pittsburgh, PA
- Joseph Hill, M.A.
  American Society of Health-System Pharmacists
  Bethesda, MD
- Brian Isetts, Ph.D., B.C.P.S., FAPhA
  College of Pharmacy
  University of Minnesota
  Minneapolis, MN
- Michelle Ketcham, Pharm.D., M.B.A.
  Medicare Drug Benefit Group
  Centers for Medicare & Medicaid Services
  Baltimore, MD
- Julie Kuhle, R.Ph.
  Senior Director, Performance Measurement
  Pharmacy Quality Alliance, Inc.
  Springfield, VA
- James Owen, Pharm.D., B.C.P.S.
  Practice & Science Affairs
  American Pharmacists Association
  Washington, DC