# Acknowledgments

The authors gratefully acknowledge the continuing support of our AHRQ Task Order Officer, Carmen Y. Kelly, Pharm.D., M.P.H., R.Ph.; the guidance of Christine Chang, M.D., M.P.H., and Aysegul Gozu, M.D., M.P.H., of AHRQ; and our Associate Editor, Margaret Maglione, M.P.P. We extend our appreciation to our Key Informants and members of our Technical Expert Panel (listed below), all of whom provided thoughtful advice and input during our research process. The investigators deeply appreciate the considerable support, commitment, and contributions of the EPC team staff at RTI International and the University of North Carolina at Chapel Hill. We express our gratitude to the following individuals for their contributions to this project: Carol Woodell, B.S.P.H., our Project Manager; Christine DeLong Jones, M.D., M.S., and Justinne E. Guyton, Pharm.D., C.P.P., our Content Experts; Christiane Voison, M.S.L.S., our EPC Librarian; Mahima Ashok, Ph.D., Sarah Selenich, M.P.P., and Catherine Aspden Grodensky, M.P.H., our Research Associates; Stefanie Knauer, M.A., Amy Greenblatt, B.A., and Claire Baker, B.A., our Research Assistants; Sharon Barrel, Jennifer Drolet, and Carol Offen, our EPC Editors; and Loraine Monroe, our EPC Publications Specialist.