# Meta-Analyses

Figure F1 Effect of MTM on SF-36 physical functioning domain

Low or medium risk-of-bias RCTs

Figure F1 displays a forest plot showing the effect of MTM on mean SF-36 Physical Functioning Domain scores from baseline to 12-month follow-up for three low or medium risk-of-bias studies of MTM versus no-MTM control groups. Our meta-analysis found no difference in Physical Functioning Domain scores between those receiving MTM and those receiving usual care (WMD, 1.17; 95% CI, -3.87 to 6.21; p-value: 0.649).

Figure F2 Effect of MTM on SF-36 role physical domain

Low or medium risk-of-bias RCTs

Figure F2 displays a forest plot showing the effect of MTM on mean SF-36 Role Physical Domain scores from baseline to 12-month follow-up for three low or medium risk-of-bias studies of MTM versus no-MTM control groups. Our meta-analysis found no difference in Role Physical Domain scores between those receiving MTM and those receiving usual care (WMD, 3.392; 95% CI, -1.223 to 8.007; p-value: 0.150).

Figure F3 Effect of MTM on SF-36 bodily pain domain

Low or medium risk-of-bias RCTs

Figure F3 displays a forest plot showing the effect of MTM on mean SF-36 Bodily Pain Domain scores from baseline to 12-month follow-up for three low or medium risk-of-bias studies of MTM versus no-MTM control groups. Our meta-analysis found no difference in Bodily Pain Domain scores between those receiving MTM and those receiving usual care (WMD, 3.32; 95% CI, -0.79 to 7.43; p-value: 0.114).

Figure F4 Effect of MTM on SF-36 general health perception domain

Low or medium risk-of-bias RCTs

Figure F4 displays a forest plot showing the effect of MTM on mean SF-36 General Health Perception Domain scores from baseline to 12-month follow-up for three low or medium risk-of-bias studies of MTM versus no-MTM control groups. Our meta-analysis found no difference in General Health Perception Domain scores between those receiving MTM and those receiving usual care (WMD, 1.92; 95% CI, -0.01 to 3.84; p-value: 0.051).

Figure F5 Effect of MTM on SF-36 vitality domain

Low or medium risk-of-bias RCTs

Figure F5 displays a forest plot showing the effect of MTM on mean SF-36 Vitality Domain scores from baseline to 12-month follow-up for three low or medium risk-of-bias studies of MTM versus no-MTM control groups. Our meta-analysis found a significant difference in favor of those receiving MTM versus those receiving usual care (WMD, 2.80; 95% CI, 0.66 to 4.94; p-value: 0.010).

Figure F6 Effect of MTM on SF-36 social functioning domain

Low or medium risk-of-bias RCTs

Figure F6 displays a forest plot showing the effect of MTM on mean SF-36 Social Functioning Domain scores from baseline to 12-month follow-up for three low or medium risk-of-bias studies of MTM versus no-MTM control groups. Our meta-analysis found no difference in Social Functioning Domain scores between those receiving MTM and those receiving usual care (WMD, 2.93; 95% CI, -0.09 to 5.95; p-value: 0.057).

Figure F7 Effect of MTM on SF-36 role emotional domain

Low or medium risk-of-bias RCTs

Figure F7 displays a forest plot showing the effect of MTM on mean SF-36 Role Emotional Domain scores from baseline to 12-month follow-up for three low or medium risk-of-bias studies of MTM versus no-MTM control groups. Our meta-analysis found no difference in Role Emotional Domain scores between those receiving MTM and those receiving usual care (WMD, 5.39; 95% CI, -7.24 to 18.02; p-value: 0.403).

Figure F8 Effect of MTM on SF-36 mental health domain

Low or medium risk-of-bias RCTs

Figure F8 displays a forest plot showing the effect of MTM on mean SF-36 Mental Health Domain scores from baseline to 12-month follow-up for three low or medium risk-of-bias studies of MTM versus no-MTM control groups. Our meta-analysis found no difference in Mental Health Domain scores between those receiving MTM and those receiving usual care (WMD, 1.62; 95% CI, -0.36 to 3.59; p-value: 0.109).

Figure F9 Effect of MTM on outpatient visits

Low or medium risk-of-bias RCTs

Figure F9 displays a forest plot showing the effect of MTM on the number of outpatient visits at 3-to-6-month, 5-month, and 12-month follow-up for three low or medium risk-of-bias randomized controlled trials of MTM versus no-MTM control groups, using the basic arm of the Touchette study. Our meta-analysis found no difference in the number of outpatient visits between those receiving MTM and those receiving usual care (standardized mean difference, 0.05; 95% CI, -0.03 to 0.13; p-value: 0.247).

Figure F10 Effect of MTM on mean number of hospitalizations

Low or medium risk-of-bias RCTs

Figure F10 displays a forest plot showing the effect of MTM on mean number of hospitalizations at follow-up for three low or medium risk-of-bias randomized controlled trials of MTM versus no-MTM control groups, using the basic arm of the Touchette study. Our meta-analysis found no difference in number of hospitalizations between those receiving MTM and those receiving usual care (WMD, 0.04; 95% CI, -0.006 to 0.080; p-value: 0.085).