# Risk of Bias Evaluations and Rationale

Table E1 Risk of bias domains and ratings: Part 1

Table E2 Risk of bias domains and ratings: Part 2

Table E3 Rationale for high and medium risk of bias ratings

## References

1 Bernsten C, Bjorkman I, Caramona M, et al. Improving the well-being of elderly patients via community pharmacy-based provision of pharmaceutical care: a multicentre study in seven European countries. Drugs Aging. 2001;18(1):63-77. [pmid: 11232739].
2 Sturgess IK, McElnay JC, Hughes CM, et al. Community pharmacy based provision of pharmaceutical care to older patients. Pharm World Sci. Oct. 2003;25(5):218-26. [pmid: 14584229].
3 Blakey SA, Hixson-Wallace JA. Clinical and economic effects of pharmacy services in a geriatric ambulatory clinic. (Structured abstract). Pharmacotherapy. 2000;(10):1198-203. [pmid: 11034043].
4 Brummel AR, Soliman AM, Carlson AM, et al. Optimal diabetes care outcomes following face-to-face medication therapy management services. Popul Health Manag. Feb. 2013;16(1):28-34. [pmid: 23113628].
5 Soliman AM, Carlson AM, MacLehose RF, et al. Patient characteristics predicting the frequency of medication therapy management visits for patients with diabetes. Clin Ther. Apr. 2013;35(4):534-40. [pmid: 23541131].
6 Ramalho de Oliveira D, Brummel AR, Miller DB. Medication therapy management: 10 years of experience in a large integrated health care system. J Manag Care Pharm. Apr. 2010;16(3):185-95. [pmid: 20331323].
7 Carter BL, Barnette DJ, Chrischilles E, et al. Evaluation of hypertensive patients after care provided by community pharmacists in a rural settin. Pharmacotherapy. Nov-Dec. 1997;17(6):1274-85. [pmid: 9399611].
8 Barnette DJ, Murphy CM, Carter BL. Clinical skill development for community pharmacists. J Am Pharm Assoc (Wash). Sep. 1996;NS36(9):573-80. [pmid: 8824077].
9 Chrischilles EA, Carter BL, Lund BC, et al. Evaluation of the Iowa Medicaid pharmaceutical case management progra. J Am Pharm Assoc (2003). May-Jun. 2004;44(3):337-49. [pmid: 15191244].
10 Christensen DB, Roth M, Trygstad T, et al. Evaluation of a pilot medication therapy management project within the North Carolina State Health Pla. J Am Pharm Assoc (2003). Jul-Aug. 2007;47(4):471-83. [pmid: 17616493].
11 Clifford RM, Batty KT, Davis TME, et al. A randomised controlled trial of a pharmaceutical care programme in high-risk diabetic patients in an outpatient clinic. Int J Pharm Pract. 2002;10(2):85-9.
12 Fischer LR, Scott LM, Boonstra DM, et al. Pharmaceutical care for patients with chronic conditions. J Am Pharm Assoc (Wash). Mar-Apr. 2000;40(2):174-80. [pmid: 10730021].
13 Fischer LR, Defor TA, Cooper S, et al. Pharmaceutical care and health care utilization in an HM. Eff Clin Pract. Mar-Apr. 2002;5(2):49-57. [pmid: 11990212].
14 Fox D, Ried LD, Klein GE, et al. A medication therapy management program's impact on low-density lipoprotein cholesterol goal attainment in Medicare Part D patients with diabete. J Am Pharm Assoc (2003). Mar-Apr. 2009;49(2):192-9. [pmid: 19289345].
15 Gattis WA, Hasselblad V, Whellan DJ, et al. Reduction in heart failure events by the addition of a clinical pharmacist to the heart failure management team: results of the Pharmacist in Heart Failure Assessment Recommendation and Monitoring (PHARM) Study. Arch Intern Med. Sep. 13. 1999;159(16):1939-45. [pmid: 10493325].
16 Grymonpre RE, Williamson DA, Montgomery PR. Impact of a pharmaceutical care model for non-institutionalised elderly: Results of a randomised, controlled trial. Int J Pharm Pract. 2001;(4):235-41.
17 Hanlon JT, Weinberger M, Samsa GP, et al. A randomized, controlled trial of a clinical pharmacist intervention to improve inappropriate prescribing in elderly outpatients with polypharmacy. Am J Med. Apr. 1996;100(4):428-37. [pmid: 8610730].
18 Cowper PA, Weinberger M, Hanlon JT, et al. The cost-effectiveness of a clinical pharmacist intervention among elderly outpatient. Pharmacotherapy. Mar-Apr. 1998;18(2):327-32. [pmid: 9545151].
19 Hirsch JD, Gonzales M, Rosenquist A, et al. Antiretroviral therapy adherence, medication use, and health care costs during 3 years of a community pharmacy medication therapy management program for Medi-Cal beneficiaries with HIV/AIDS. J Manag Care Pharm. Apr. 2011;17(3):213-23. [pmid: 21434698].
20 Hirsch JD, Rosenquist A, Best BM, et al. Evaluation of the first year of a pilot program in community pharmacy: HIV/AIDS medication therapy management for Medi-Cal beneficiarie. J Manag Care Pharm. Jan-Feb. 2009;15(1):32-41. [pmid: 19125548].
21 Rosenquist A, Best BM, Miller TA, et al. Medication therapy management services in community pharmacy: a pilot programme in HIV specialty pharmacies. J Eval Clin Pract. Dec. 2010;16(6):1142-6. [pmid: 21143346].
22 Isetts BJ, Schondelmeyer SW, Artz MB, et al. Clinical and economic outcomes of medication therapy management services: the Minnesota experience. J Am Pharm Assoc. Mar-Apr. 2008;48(2):203-11. 3 p following 11. [pmid: 18359733].
23 Jameson J, VanNoord G, Vanderwoud K. The impact of a pharmacotherapy consultation on the cost and outcome of medical therapy. J Fam Pract. Nov. 1995;41(5):469-72. [pmid: 7595265].
24 Jeong EW, Gallagher MW, Fredriks D, et al. Impact of a pharmacist-managed medication therapy management (MTM) progra. ASHP Midyear Clinical Meeting. 2007;42(DEC).
25 Jeong E, Hui R, Gallagher M, et al. Clinical, Economical and Humanistic Outcomes from a Pharmacist-managed Medication Therapy Management Program (MTMP) in Medicare Patients from an Integrated Healthcare Delivery System. Kaiser Permanante. 2009:1-31.
26 Jeong E, Pitcher K, Fredriks D, et al. Clinical & Safety Outcomes from a Pharmacist-managed Medicare Medication Therapy Management Program. Kaiser Permanente.
27 Jeong E, Deguzman L, Fredriks D, et al. Comprehensive Medication Reviews Improve Hospitalization and Emergency Department Outcomes. Kaiser Permanente. 2012.
28 Krska J, Cromarty JA, Arris F, et al. Pharmacist-led medication review in patients over 65: a randomized, controlled trial in primary care. Age Ageing. May. 2001;30(3):205-11. [pmid: 11443021].
29 Malone DC, Carter BL, Billups SJ, et al. An economic analysis of a randomized, controlled, multicenter study of clinical pharmacist interventions for high-risk veterans: the IMPROVE study. Impact of Managed Pharmaceutical Care Resource Utilization and Outcomes in Veterans Affairs Medical Centers. Pharmacotherapy. Oct. 2000;20(10):1149-58. [pmid: 11034037].
30 Ellis SL, Billups SJ, Malone DC, et al. Types of interventions made by clinical pharmacists in the IMPROVE study. Impact of Managed Pharmaceutical Care on Resource Utilization and Outcomes in Veterans Affairs Medical Centers. Pharmacotherapy. Apr. 2000;20(4):429-35. [pmid: 10772374].
31 Malone DC, Carter BL, Billups SJ, et al. Can clinical pharmacists affect SF-36 scores in veterans at high risk for medication-related problems?. Med Car. Feb. 2001;39(2):113-22. [pmid: 11176549].
32 Ellis SL, Carter BL, Malone DC, et al. Clinical and economic impact of ambulatory care clinical pharmacists in management of dyslipidemia in older adults: the IMPROVE study. Impact of Managed Pharmaceutical Care on Resource Utilization and Outcomes in Veterans Affairs Medical Centers. Pharmacotherapy. Dec. 2000;20(12):1508-16. [pmid: 11130223].
33 Marques LA, Galduroz JC, Fernandes MR, et al. Assessment of the effectiveness of pharmacotherapy follow-up in patients treated for depression. J Manag Care Pharm. Apr. 2013;19(3):218-27. [pmid: 23537456].
34 Marrufo G, Dixit A, Perlroth D, et al. Medication Therapy Management in a Chronically Ill Population: Interim Report. (Prepared by Acumen LLC under Contract #HHSM-500-2011-00012I/TOT#0001). Baltimore, MD. Services Centers for Medicare & Medicaid Services. 2013.
35 Perlroth D, Marrufo G, Montesinos A, et al. Medication Therapy Management in Chronically Ill Populations: Final Report. Contract # HHSM-500-2011-00012I/TOT0001. Baltimore, MD. Centers for Medicare & Medicaid Services (CMS) Center for Medicare & Medicaid Innovation. 2013. http://innovation.cms.gov/Files/reports/MTM_Final_Report.pdf.
36 McDonough RP, Doucette WR, Kumbera P, et al. An evaluation of managing and educating patients on the risk of glucocorticoid-induced osteoporosi. Value Health. Jan-Feb. 2005;8(1):24-31. [pmid: 15841891].
37 Moczygemba LR, Barner JC, Lawson KA, et al. Impact of telephone medication therapy management on medication and health-related problems, medication adherence, and Medicare Part D drug costs: a 6-month follow up. Am J Geriatr Pharmacother. Oct. 2011;9(5):328-38. [pmid: 21865093].
38 Moczygemba LR, Barner JC, Gabrillo ER, et al. Development and implementation of a telephone medication therapy management program for Medicare beneficiaries. Am J Health Syst Pharm. Sep. 1. 2008;65(17):1655-60. [pmid: 18714113].
39 Moczygemba LR, Barner JC, Gabrillo ER. Outcomes of a Medicare Part D telephone medication therapy management program. 2012;52:E144.
40 Moore JM, Shartle D, Faudskar L, et al. Impact of a patient-centered pharmacy program and intervention in a high-risk group. J Manag Care Pharm. Apr. 2013;19(3):228-36. [pmid: 23537457].
41 Pai AB, Boyd A, Depczynski J, et al. Reduced drug use and hospitalization rates in patients undergoing hemodialysis who received pharmaceutical care: a 2-year, randomized, controlled study. Pharmacotherapy. Dec. 2009;29(12):1433-40. [pmid: 19947803].
42 Pai AB, Boyd A, Chavez A, et al. Health-related quality of life is maintained in hemodialysis patients receiving pharmaceutical care: a 2-year randomized, controlled study. Hemodial Int. Jan. 2009;13(1):72-9. [pmid: 19210281].
43 Park JJ, Kelly P, Carter BL, et al. Comprehensive pharmaceutical care in the chain setting. J Am Pharm Assoc (Wash). Jul. 1996;NS36(7):443-51. [pmid: 8840744].
44 Pindolia VK, Stebelsky L, Romain TM, et al. Mitigation of medication mishaps via medication therapy management. Ann Pharmacother. Apr. 2009;43(4):611-20. [pmid: 19336646].
45 Planas LG, Crosby KM, Mitchell KD, et al. Evaluation of a hypertension medication therapy management program in patients with diabete. J Am Pharm Assoc (2003). Mar-Apr. 2009;49(2):164-70. [pmid: 19289342].
46 Roughead EE, Barratt JD, Ramsay E, et al. The effectiveness of collaborative medicine reviews in delaying time to next hospitalization for patients with heart failure in the practice setting: results of a cohort study. Circ Heart Fail. Sep. 2009;2(5):424-8. [pmid: 19808372].
47 Sellors J, Kaczorowski J, Sellors C, et al. A randomized controlled trial of a pharmacist consultation program for family physicians and their elderly patients. CMAJ. Jul. 8. 2003;169(1):17-22. [pmid: 12847034].
48 Shimp LA, Kucukarslan SN, Elder J, et al. Employer-based patient-centered medication therapy management program: Evidence and recommendations for future programs. 768.
49 Sidel VW, Beizer JL, Lisi-Fazio D, et al. Controlled study of the impact of educational home visits by pharmacists to high-risk older patients. J Community Health. Jun. 1990;15(3):163-74. [pmid: 2195066].
50 Staresinic AG. Early experience with medication management - Description and preliminary outcomes of a Medicare Part D medication therapy management program. J Pharm Soc Wis. 2007;(SEP-OCT):8-0.
51 Taylor CT, Byrd DC, Krueger K. Improving primary care in rural Alabama with a pharmacy initiative. Am J Health Syst Pharm. Jun. 1. 2003;60(11):1123-9. [pmid: 12816022].
52 Touchette DR, Masica AL, Dolor RJ, et al. Safety-focused medication therapy management: a randomized controlled tria. J Am Pharm Assoc (2003). Sep-Oct. 2012;52(5):603-12. [pmid: 23023840].
53 Volume CI, Farris KB, Kassam R, et al. Pharmaceutical care research and education project: patient outcomes. J Am Pharm Assoc (Wash). May-Jun. 2001;41(3):411-20. [pmid: 11372906].
54 Kassam R, Farris KB, Burback L, et al. Pharmaceutical care research and education project: pharmacists' interventions. J Am Pharm Assoc (Wash). May-Jun. 2001;41(3):401-10. [pmid: 11372905].
55 Welch EK, Delate T, Chester EA, et al. Assessment of the impact of medication therapy management delivered to home-based Medicare beneficiaries. Ann Pharmacother. Apr. 2009;43(4):603-10. [pmid: 19318600].
56 Williams ME, Pulliam CC, Hunter R, et al. The short-term effect of interdisciplinary medication review on function and cost in ambulatory elderly people. J Am Geriatr Soc. Jan. 2004;52(1):93-8. [pmid: 14687321].
57 Winston S, Lin YS. Impact on drug cost and use of Medicare part D of medication therapy management services delivered in 200. J Am Pharm Assoc (2003). Nov-Dec. 2009;49(6):813-20. [pmid: 19858047].
58 Witry MJ, Doucette WR, Gainer KL. Evaluation of the pharmaceutical case management program implemented in a private sector health plan. J Am Pharm Assoc (2003). Sep-Oct. 2011;51(5):631-5. [pmid: 21896463].
59 Wittayanukorn S, Westrick SC, Hansen RA, et al. Evaluation of medication therapy management services for patients with cardiovascular disease in a self-insured employer health plan. J Manag Care Pharm. Jun. 2013;19(5):385-95. [pmid: 23697476].
60 Yamada B. Comparison of Outcomes in the Medicare Medication Therapy Management Program within Kaiser Permanente California. 2012.