# Studies Excluded After Full-Text Level Review

- X1 = Ineligible Publication
- X2 = Ineligible or No Intervention
- X3 = Ineligible Population
- X4 = Ineligible Study Design
- X5 = Ineligible Comparator
- X6 = Ineligible Outcomes
- X7 = Ineligible Setting
- X8 = Insufficient Information to Determine Eligibility

1 Patients confirm that medication counseling helps. Am J Hosp Pharm. Jul. 1. 1994;51(13):1606. 8. Exclusion Code: X2. [pmid: 7942886].
2 The MEDMAN study: a randomized controlled trial of community pharmacy-led medicines management for patients with coronary heart disease. Fam Pract. Apr. 2007;24(2):189-200. Exclusion Code: X2.
3 MTM program increased statin use. Dis Manag Advis. Oct. suppl 1-3. 2008;14(10):1. Exclusion Code: X1. [pmid: 19031586].
4 What's expected for med reconciliation?. OR Manager. Mar. 2008;24(3):21. 3. Exclusion Code: X1. [pmid: 18438074].
5 Hospitals collaborate to reduce ED overuse. Hosp Case Manag. Oct. 2012;20(10):151-3. Exclusion Code: X1. [pmid: 23091842].
6 First, do no harm: avoiding medication mishaps. Johns Hopkins Med Lett Health After 50. Summer. 2013;24(6):1-4. Exclusion Code: X1. [pmid: 24000429].
7 Cut readmissions through med adherence. Hosp Peer Rev. Feb. 2013;38(2):19-20. Exclusion Code: X1.
8 Optimising medicines management?. Drug Ther Bull. Apr. 2013;51(4):37. Exclusion Code: X1. [pmid: 23575602].
9 Aguiar PM, Balisa-Rocha BJ, Brito GC, et al. Pharmaceutical care in hypertensive patients: a systematic literature review (Provisional abstract). DARE. 2012;(4):383-96. Exclusion Code: X2.
10 Al-Ghamdi SA, Mahmoud MA, Alammari MA, et al. The outcome of pharmacist counseling at the time of hospital discharge: an observational nonrandomized study. Ann Saudi Med. Sep-Oct. 2012;32(5):492-7. Exclusion Code: X2. [pmid: 22871618].
11 Alsuwaidan S, Malone DC, Billups SJ, et al. Characteristics of ambulatory care clinics and pharmacists in Veterans Affairs medical centers. IMPROVE investigators. Impact of Managed Pharmaceutical Care on Resource Utilization and Outcomes in Veterans Affairs Medical Centers. Am J Health Syst Pharm. Jan. 1. 1998;55(1):68-72. Exclusion Code: X2. [pmid: 9437478].
12 Altman JS. Medication therapy management and the new practitioner. Am J Health Syst Pharm. Mar. 15. 2007;64(6):590-2. Exclusion Code: X1. [pmid: 17353567].
13 Anonymous. Prescribing and research in medicines management (UK & Ireland) Conference 2013 Imperial Hotel London January 24th 2013 “Intelligent polypharmacy … It's not all about the number” abstract. Pharmacoepidemiol Drug Saf. 22:670. Exclusion Code: X1.
14 Armour CL, Reddel HK, LeMay KS, et al. Feasibility and effectiveness of an evidence-based asthma service in Australian community pharmacies: a pragmatic cluster randomized trial. J Asthma. Apr. 2013;50(3):302-9. Exclusion Code: X2. [pmid: 23270495].
15 Asis ML, Greene R. A cost-effectiveness analysis of a peak flow-based asthma education and self-management plan in a high-cost population. (Structured abstract). J Asthma. 2004;(5):559-65. Exclusion Code: X2. [pmid: 15360065].
16 Atkinson WL, Frey D. Integration of a medication management model into outcome-based quality improvement: a pilot program in a rural propriety home healthcare agency. Home Health Care Serv Q. 2005;24(1-2):29-45. Exclusion Code: X4. [pmid: 16236657].
17 Avery AJ, Rodgers S, Cantrill JA, et al. Protocol for the PINCER trial: a cluster randomised trial comparing the effectiveness of a pharmacist-led IT-based intervention with simple feedback in reducing rates of clinically important errors in medicines management in general practices. Trials. 2009;10:28. Exclusion Code: X2. [pmid: 19409095].
18 Avery AJ, Rodgers S, Cantrill JA, et al. Correction: Protocol for the PINCER trial: a cluster randomised trial comparing the effectiveness of a pharmacist-led IT-based intervention with simple feedback in reducing rates of clinically important errors in medicines management in general practices. Trials. 2010;23. Exclusion Code: X1.
19 Bandres MA, Mendoza MA, Nicolas FG, et al. Pharmacist-led medication reconciliation to reduce discrepancies in transitions of care in Spain. 1083. Exclusion Code: X2.
20 Bates DW. Role of pharmacists in the medical home. Am J Health Syst Pharm. Jun. 15. 2009;66(12):1116-8. Exclusion Code: X1. [pmid: 19498128].
21 Bayoumi I, Howard M, Holbrook AM, et al. Interventions to improve medication reconciliation in primary care. (Structured abstract). Ann Pharmacother. 2009;(10):1667-75. Exclusion Code: X2. [pmid: 19737997].
22 Bell JS, Vaananen M, Ovaskainen H, et al. Providing patient care in community pharmacies: practice and research in Finland. Ann Pharmacother. Jun. 2007;41(6):1039-46. Exclusion Code: X1. [pmid: 17504836].
23 Bellone JM, Barner JC, Lopez DA. Postdischarge interventions by pharmacists and impact on hospital readmission rates. J Am Pharm Assoc (2003). May-Jun. 2012;52(3):358-62. Exclusion Code: X2. [pmid: 22618976].
24 Bennett MI, Bagnall AM, Raine G, et al. Educational interventions by pharmacists to patients with chronic pain: systematic review and meta-analysis. Clin J Pain. Sep. 2011;27(7):623-30. Exclusion Code: X3. [pmid: 21610491].
25 Benrimoj SI, Langford JH, Berry G, et al. Economic impact of increased clinical intervention rates in community pharmacy. A randomised trial of the effect of education and a professional allowance. Pharmacoeconomics. Nov. 2000;18(5):459-68. Exclusion Code: X2. [pmid: 11151399].
26 Bergkvist A, Midlov P, Hoglund P, et al. Improved quality in the hospital discharge summary reduces medication errors--LIMM: Landskrona Integrated Medicines Management. Eur J Clin Pharmacol. Oct. 2009;65(10):1037-46. Exclusion Code: X7. [pmid: 19557400].
27 Bergkvist A, Midlov P, Hoglund P, et al. A multi-intervention approach on drug therapy can lead to a more appropriate drug use in the elderly. LIMM-Landskrona Integrated Medicines Management. J Eval Clin Pract. Aug. 2009;15(4):660-7. Exclusion Code: X7. [pmid: 19674217].
28 Berjis M, Ho MI, Gray DR. Evaluation of patient outcome and pharmaceutical care in an HIV clinic. ASHP Midyear Clinical Meeting. 1996;31(Dec). P-E. Exclusion Code: X6.
29 Bertino J, Villa T, Corbett A, et al. Effects of optimal medication therapy management of depression in human immunodeficiency virus (HIV) infected patients on associated virologic and immunologic outcomes. J Pharm Pract. 2008;21(Jan):78. Exclusion Code: X2.
30 Billups SJ, Okano G, Malone D, et al. Assessing the structure and process for providing pharmaceutical care in Veterans Affairs medical centers. Am J Health Syst Pharm. Jan. 1. 2000;57(1):29-39. Exclusion Code: X6. [pmid: 10630554].
31 Bilyeu KM, Gumm CJ, Fitzgerald JM, et al. Cultivating quality: Reducing the use of potentially inappropriate medications in older adults. Am J Nurs. Jan. 2011;111(1):47-52. Exclusion Code: X2. [pmid: 21191234].
32 Bland CM, Tritsch AM, Bookstaver DA, et al. Hypertension and diabetes mellitus medication management in sleeve gastrectomy patients. Am J Health Syst Pharm. Jun. 15. 2013;70(12):1018-20. Exclusion Code: X2. [pmid: 23719877].
33 Blennerhassett JD, Cusack BM, Smith CD, et al. A novel medicines management pathway. J Pharm Pract Res. 2006;36(Mar):175-9. Exclusion Code: X7.
34 Blozik E, Born AM, Stuck AE, et al. Reduction of inappropriate medications among older nursing-home residents: a nurse-led, pre/post-design, intervention study. Drugs Aging. Dec. 1. 2010;27(12):1009-17. Exclusion Code: X7. [pmid: 21087070].
35 Bonnet-Zamponi D, d'Arailh L, Konrat C, et al. Drug-related readmissions to medical units of older adults discharged from acute geriatric units: results of the Optimization of Medication in AGEd multicenter randomized controlled trial. J Am Geriatr Soc. Jan. 2013;61(1):113-21. Exclusion Code: X7. [pmid: 23252914].
36 Borges AP, Guidoni CM, Ferreira LD, et al. The pharmaceutical care of patients with type 2 diabetes mellitus. Pharm World Sci. Dec. 2010;32(6):730-6. Exclusion Code: X8. [pmid: 20734138].
37 Borges AP, Guidoni CM, Freitas O, et al. Economic evaluation of outpatients with type 2 diabetes mellitus assisted by a pharmaceutical care service. Arq Bras Endocrinol Metabol. Dec. 2011;55(9):686-91. Exclusion Code: X8. [pmid: 22231970].
38 Borgsdorf LR, Miano JS, Knapp KK. Pharmacist-managed medication review in a managed care system. Am J Hosp Pharm. Mar. 15. 1994;51(6):772-7. Exclusion Code: X4. [pmid: 8010315].
39 Branham AR, Katz AJ, Moose JS, et al. Retrospective Analysis of Estimated Cost Avoidance Following Pharmacist-Provided Medication Therapy Management Services. 420. Exclusion Code: X4.
40 Bratcher CR, Bello E. Traditional or centralized models of diabetes care: the multidisciplinary diabetes team approach. J Fam Pract. Nov. 2011;60(11 Suppl):S6-11. Exclusion Code: X1. [pmid: 22336928].
41 Brooks JM, Unni EJ, Klepser DG, et al. Factors affecting demand among older adults for medication therapy management services. Res Social Adm Pharm. Dec. 2008;4(4):309-19. Exclusion Code: X2. [pmid: 19064238].
42 Brown DL, Wolff DJ, Smith LD, et al. Computer-supported medication counseling for discharged patients. Am J Hosp Pharm. Sep. 1986;43(9):2232-5. Exclusion Code: X2. [pmid: 3766581].
43 Brown EV. Reconcilable differences. Health Manag Technol. Jan. 2008;29(1):12-4. 6. Exclusion Code: X1. [pmid: 18286931].
44 Brusig E, Davies W. PSTAC survey in 2006 was instrumental in obtaining permanent (category I) CPT codes for MTM services performed by pharmacists. J Manag Care Pharm. Jan-Feb. 2008;14(1):86-7. Exclusion Code: X1. [pmid: 18240887].
45 Bucci C, Jackevicius C, McFarlane K, et al. Pharmacist's contribution in a heart function clinic: patient perception and medication appropriateness. Can J Cardiol. Mar. 31. 2003;19(4):391-6. Exclusion Code: X8. [pmid: 12704485].
46 Bunting BA, Cranor CW. The Asheville Project: long-term clinical, humanistic, and economic outcomes of a community-based medication therapy management program for asthma. J Am Pharm Assoc (2003). Mar-Apr. 2006;46(2):133-47. Exclusion Code: X2. [pmid: 16602223].
47 Bunting BA, Smith BH, Sutherland SE. The Asheville Project: clinical and economic outcomes of a community-based long-term medication therapy management program for hypertension and dyslipidemia. J Am Pharm Assoc (2003). Jan-Feb. 2008;48(1):23-31. Exclusion Code: X4. [pmid: 18192127].
48 Burnett KM, Scott MG, Fleming GF, et al. Effects of an integrated medicines management program on medication appropriateness in hospitalized patients. Am J Health Syst Pharm. May. 1. 2009;66(9):854-9. Exclusion Code: X2. [pmid: 19386949].
49 Butler CD. Medication therapy management for adverse drug event preventive care. J Am Pharm Assoc (2003). Jul-Aug. 2010;50(4):449. Exclusion Code: X1. [pmid: 20621858].
50 Cadth. Medication reconciliation at discharge: a review of the clinical evidence and guidelines. (Structured abstract). Health Technology Assessment Database. 2012;(1). Exclusion Code: X2.
51 Cahill JA, Manasse HR Jr. Medication therapy management programs: to optimize pharmacy outcomes. J Manag Care Pharm. Mar. 2005;11(2):179. Exclusion Code: X1. [pmid: 15766326].
52 Cantwell KM. Collaborating for successful medication therapy management programs. Am J Health Syst Pharm. Mar. 15. 2005;62(6):583. Exclusion Code: X1. [pmid: 15757878].
53 Carey N, Courtenay M, James J, et al. An evaluation of a Diabetes Specialist Nurse prescriber on the system of delivering medicines to patients with diabetes. J Clin Nurs. Jun. 2008;17(12):1635-44. Exclusion Code: X7. [pmid: 18482124].
54 Carter BL, Ardery G, Dawson JD, et al. Physician and pharmacist collaboration to improve blood pressure control. Arch Intern Med. Nov. 23. 2009;169(21):1996-2002. Exclusion Code: X2. [pmid: 19933962].
55 Carter BL, Lund BC, Hayase N, et al. A longitudinal analysis of antihypertensive drug interactions in a Medicaid population. Am J Hypertens. May. 2004;17(5 Pt 1):421-7. Exclusion Code: X5. [pmid: 15110901].
56 Carter BL, Malone DC, Billups SJ, et al. Interpreting the findings of the IMPROVE study. Am J Health Syst Pharm. Jul. 15. 2001;58(14):1330-7. Exclusion Code: X1. [pmid: 11471481].
57 Carter BL, Malone DC, Ellis SL, et al. Antihypertensive Drug Utilization in Hypertensive Veterans With Complex Medication Profiles. J Clin Hypertens (Greenwich). May. 2000;2(3):172-80. Exclusion Code: X5. [pmid: 11416643].
58 Carter BL, Malone DC, Valuck RJ, et al. The IMPROVE study: background and study design. Impact of Managed Pharmaceutical Care on Resource Utilization and Outcomes in Veterans Affairs Medical Centers. Am J Health Syst Pharm. Jan. 1. 1998;55(1):62-7. Exclusion Code: X6. [pmid: 9437477].
59 Carter BL, Zillich AJ, Elliott WJ. How pharmacists can assist physicians with controlling blood pressure. J Clin Hypertens (Greenwich). Jan-Feb. 2003;5(1):31-7. Exclusion Code: X1. [pmid: 12556651].
60 Casteel C, Blalock SJ, Ferreri S, et al. Implementation of a community pharmacy-based falls prevention program. Am J Geriatr Pharmacother. Oct. 2011;9(5):310-9 e2. Exclusion Code: X2. [pmid: 21925959].
61 Castro R, Leung J, Song J, et al. Outcomes of implementing a medication therapy management service for dialysis patients. 056. Exclusion Code: X2.
62 Cauchi R. Medication therapy management: catching errors, saving lives and money. NCSL Legisbrief. Jan. 2010;18(4):1-2. Exclusion Code: X1. [pmid: 20196247].
63 Centers for Medicare & Medicaid Services. Medicare Part D Medication Therapy Management (MTM) Programs: 2009 Fact Sheet. 2009. Exclusion Code: X4.
64 Centers for Medicare & Medicaid Services. 2010 Medicare Part D Medication Therapy Management (MTM) Programs Fact Sheet. 2010. Exclusion Code: X4.
65 Centers for Medicare & Medicaid Services. 2012 Medicare Part D Medication Therapy Management (MTM) Programs Fact Sheet. 2012. Exclusion Code: X4.
66 Cestac P, Tavassoli N, Vellas B, et al. Improving medication use in the nursing homes: a European perspective. J Am Med Dir Assoc. Jan. 2013;14(1):6-9. Exclusion Code: X1. [pmid: 23158846].
67 Chapman NR, Fotis MA, Yarnold PR, et al. Pharmacist interventions to improve the management of coronary artery disease. Am J Health Syst Pharm. Dec. 15. 2004;61(24):2672-8. Exclusion Code: X2. [pmid: 15646702].
68 Charrois TL, Zolezzi M, Koshman SL, et al. A systematic review of the evidence for pharmacist care of patients with dyslipidemia. Pharmacotherapy. Mar. 2012;32(3):222-33. Exclusion Code: X2. [pmid: 22392455].
69 Cheng Y, Raisch DW, Borrego ME, et al. Economic, clinical, and humanistic outcomes (ECHOs) of pharmaceutical care services for minority patients: A literature review. 311. Exclusion Code: X2.
70 Ching MM, Chen T, Bounthavong M. Medication therapy management programs at a VA medical facility: effectson blood cholesterol in high risk patients. CA J Health-Sys Pharm. 23:15. Exclusion Code: X2.
71 Chisholm MA, Mulloy LL, Jagadeesan M, et al. Effect of clinical pharmacy services on the blood pressure of African-American renal transplant patients. Ethn Dis. Summer. 2002;12(3):392-7. Exclusion Code: X7. [pmid: 12148711].
72 Chisholm MA, Reinhardt BO, Vollenweider LJ, et al. Effect of pharmaceutical care services on renal transplant patients' blood glucose levels. ASHP Midyear Clinical Meeting. 1999;34(Dec). P-E. Exclusion Code: X4.
73 Chisholm MA, Spivey CA, Mulloy LL. Effects of a medication assistance program with medication therapy management on the health of renal transplant recipients. Am J Health Syst Pharm. Jul. 15. 2007;64(14):1506-12. Exclusion Code: X5. [pmid: 17617501].
74 Choe HM, Mitrovich S, Dubay D, et al. Proactive case management of high-risk patients with type 2 diabetes mellitus by a clinical pharmacist: a randomized controlled trial. Am J Manag Care. Apr. 2005;11(4):253-60. Exclusion Code: X2. [pmid: 15839185].
75 Christensen DB, Campbell WH, Madsen S, et al. Documenting outpatient problem intervention activities of pharmacists in an HMO. Med Care. Jan. 1981;19(1):104-17. Exclusion Code: X4. [pmid: 7464303].
76 Christensen DB, Holmes G, Fassett WE, et al. Principal findings from the Washington State cognitive services demonstration project. Manag Care Interface. Jul. 1998;11(7):60-2. 4. Exclusion Code: X2. [pmid: 10181572].
77 Cioffi ST, Caron MF, Kalus JS, et al. Glycosylated hemoglobin, cardiovascular, and renal outcomes in a pharmacist-managed clinic. Ann Pharmacother. May. 2004;38(5):771-5. Exclusion Code: X4. [pmid: 15031417].
78 Coast-Senior EA, Kroner BA, Kelley CL, et al. Management of patients with type 2 diabetes by pharmacists in primary care clinics. Ann Pharmacother. Jun. 1998;32(6):636-41. Exclusion Code: X4. [pmid: 9640480].
79 Collins C, Kramer A, O'Day ME, et al. Evaluation of patient and provider satisfaction with a pharmacist-managed lipid clinic in a Veterans Affairs medical center. Am J Health Syst Pharm. Sep. 15. 2006;63(18):1723-7. Exclusion Code: X4. [pmid: 16960256].
80 Cordina M, McElnay JC, Hughes CM. Assessment of a community pharmacy-based program for patients with asthma. Pharmacotherapy. Oct. 2001;21(10):1196-203. Exclusion Code: X2. [pmid: 11601666].
81 Cote I, Gregoire JP, Moisan J, et al. A pharmacy-based health promotion programme in hypertension: cost-benefit analysis. Pharmacoeconomics. 2003;21(6):415-28. Exclusion Code: X2. [pmid: 12678568].
82 Cotterell CC, Dombroske L, Fischermann EA. Comprehensive drug-use evaluation program in a health maintenance organization. Am J Hosp Pharm. Aug. 1991;48(8):1712-7. Exclusion Code: X1. [pmid: 1897551].
83 Couturaud F, Proust A, Frachon I, et al. Education and self-management: a one-year randomized trial in stable adult asthmatic patients. J Asthma. Sep. 2002;39(6):493-500. Exclusion Code: X2. [pmid: 12375708].
84 Cranor CW, Bunting BA, Christensen DB. The Asheville Project: long-term clinical and economic outcomes of a community pharmacy diabetes care program. J Am Pharm Assoc (Wash). Mar-Apr. 2003;43(2):173-84. Exclusion Code: X4. [pmid: 12688435].
85 Curwain B. Hampshire medicines management project saves NHS over British pound sterling1 million. Pharm J (England). 2007;278(Feb). PM1-PM2. Exclusion Code: X2.
86 Degnin FD. Difficult patients, overmedication, and groupthink. J Clin Ethics. Spring. 2009;20(1):64-74. Exclusion Code: X1. [pmid: 19385324].
87 Dersch D. Patient assessment tool for pharmacists. Am J Health Syst Pharm. Apr. 15. 2008;65(8):702-3. Exclusion Code: X1. [pmid: 18387897].
88 Donohue JM, Zhang Y, Aiju M, et al. Impact of Medicare Part D on antidepressant treatment, medication choice, and adherence among older adults with depression. Am J Geriatr Psychiatry. Dec. 2011;19(12):989-97. Exclusion Code: X2. [pmid: 22123272].
89 Doucette WR, McDonough RP, Klepser D, et al. Comprehensive medication therapy management: identifying and resolving drug-related issues in a community pharmacy. Clin Ther. Jul. 2005;27(7):1104-11. Exclusion Code: X4. [pmid: 16154490].
90 Doucette WR, Witry MJ, Alkhateeb F, et al. Attitudes of Medicare beneficiaries toward pharmacist-provided medication therapy management activities as part of the Medicare Part D benefit. J Am Pharm Assoc (2003). Nov-Dec. 2007;47(6):758-62. Exclusion Code: X4. [pmid: 18032140].
91 Dougherty L. Medicine management and infection prevention. Br J Nurs. Jul 28-Aug 4. 2011;20(14):S3. Exclusion Code: X1. [pmid: 21841665].
92 Downie G, Cromarty E, Ellis G, et al. Assessment of medicine management in people ages 75 years or over living in the community in Grampian, Scotland. ASHP Midyear Clinical Meeting. 2001;36(Dec). P-E. Exclusion Code: X4.
93 Dudas V, Bookwalter T, Kerr KM, et al. The impact of follow-up telephone calls to patients after hospitalization. Dis Mon. Apr. 2002;48(4):239-48. Exclusion Code: X2. [pmid: 12021756].
94 Eden M, Avery A, Rodgers S, et al. Ensuring accuracy in routinely collected data in a cluster randomised controlled trial (RCT) comparing the effectiveness of a pharmacist-led IT-based intervention with simple feedback in reducing rates of clinically important errors in medicines management: The PINCER Trial. Int J Pharm Pract. 2010:60-1. Exclusion Code: X1.
95 Elkjaer M. E-health: Web-guided therapy and disease self-management in ulcerative colitis. Impact on disease outcome, quality of life and compliance. Dan Med J. Jul. 2012;59(7):B4478. Exclusion Code: X2. [pmid: 22759851].
96 Elliott RA, Martinac G, Campbell S, et al. Pharmacist-led medication review to identify medication-related problems in older people referred to an Aged Care Assessment Team: a randomized comparative study. Drugs Aging. Jul. 1. 2012;29(7):593-605. Exclusion Code: X2. [pmid: 22715865].
97 Emmerton L, Shaw J, Kheir N. Asthma management by New Zealand pharmacists: a pharmaceutical care demonstration project. J Clin Pharm Ther. Oct. 2003;28(5):395-402. Exclusion Code: X2. [pmid: 14632964].
98 Epplen K, Dusing-Wiest M, Freedlund J, et al. Stepwise approach to implementing ambulatory clinical pharmacy services. Am J Health Syst Pharm. May. 1. 2007;64(9):945-51. Exclusion Code: X2. [pmid: 17468149].
99 Epplen K, Marsden LM, Murphy C. Reimbursement for medication therapy management services. Am J Health Syst Pharm. May. 15. 2008;65(10):906-8. Exclusion Code: X1. [pmid: 18463337].
100 Ermer M, Harder S. Medication review of community-dwelling seniors using intensified home-care service. Int J Clin Pharmacol Ther. Mar. 2011;49(3):179-84. Exclusion Code: X2. [pmid: 21329619].
101 Farris KB, Ganther-Urmie JM, Fang G, et al. Population-based medication reviews: a descriptive analysis of the medication issues identified in a medicare not-for-profit prescription discount program. Ann Pharmacother. Nov. 2004;38(11):1823-9. Exclusion Code: X2. [pmid: 15479770].
102 Farris KB, Kumbera P, Halterman T, et al. Outcomes-based pharmacist reimbursement: Reimbursing pharmacists for cognitive services - (Part 1 of a 2-part series). J Manag Care Pharm. 2002;8(May):383-93. Exclusion Code: X4. [pmid: 14613406].
103 Feldman PH, Totten AM, Foust J, et al. Medication management: evidence brief. Center for Home Care Policy & Research. Home Healthc Nurse. Jun. 2009;27(6):379-86. Exclusion Code: X1. [pmid: 19509525].
104 Feldman SM. Pharmaceutical care and the consultant pharmacist. A model for drug therapy management. Am Pharm. Suppl. 1995:19-21. Exclusion Code: X1. [pmid: 7677061].
105 Fera T, Bluml BM, Ellis WM, et al. The Diabetes Ten City Challenge: interim clinical and humanistic outcomes of a multisite community pharmacy diabetes care program. J Am Pharm Assoc (2003). Mar-Apr. 2008;48(2):181-90. Exclusion Code: X2. [pmid: 18359731].
106 Figge HL. Interoperable health information exchange between medication therapy management services and the medical home. Am J Health Syst Pharm. Feb. 1. 2010;67(3):190-1. Exclusion Code: X1. [pmid: 20101060].
107 Finley PR, Bluml BM, Bunting BA, et al. Clinical and economic outcomes of a pilot project examining pharmacist-focused collaborative care treatment for depression. J Am Pharm Assoc (2003). Jan-Feb. 2011;51(1):40-9. Exclusion Code: X2. [pmid: 21247825].
108 Finley PR, Rens HR, Pont JT, et al. Impact of a collaborative care model on depression in a primary care setting: a randomized controlled trial. Pharmacotherapy. Sep. 2003;23(9):1175-85. Exclusion Code: X2. [pmid: 14524649].
109 Fisher JE, Zhang Y, Sketris I, et al. The effect of an educational intervention on meperidine use in Nova Scotia, Canada: a time series analysis. Pharmacoepidemiol Drug Saf. Feb. 2012;21(2):177-83. Exclusion Code: X2. [pmid: 22081471].
110 Fletcher J, Hogg W, Farrell B, et al. Effect of nurse practitioner and pharmacist counseling on inappropriate medication use in family practice. Can Fam Physician. Aug. 2012;58(8):862-8. Exclusion Code: X2. [pmid: 22893340].
111 Forster AJ, Auger C. Using information technology to improve the monitoring of outpatient prescribing. JAMA Intern Med. Mar. 11. 2013;173(5):382-4. Exclusion Code: X2. [pmid: 23381469].
112 Frew EJ, Kluettgens B, Gilday N, et al. The impact of a medicines management service on patients with cystic fibrosis. 686. Exclusion Code: X4.
113 Gadzhanova SV, Roughead EE, Bartlett MJ. Improving cardiovascular disease management in Australia: NPS MedicineWise. Med J Aust. Aug. 5. 2013;199(3):192-5. Exclusion Code: X5. [pmid: 23909542].
114 Garcao JA, Cabrita J. Evaluation of a pharmaceutical care program for hypertensive patients in rural Portugal. J Am Pharm Assoc (Wash). Nov-Dec. 2002;42(6):858-64. Exclusion Code: X2. [pmid: 12482009].
115 Gardella JE, Cardwell TB, Nnadi M. Improving medication safety with accurate preadmission medication lists and postdischarge education. Jt Comm J Qual Patient Saf. Oct. 2012;38(10):452-8. Exclusion Code: X2. [pmid: 23130391].
116 Garrett DG, Bluml BM. Patient self-management program for diabetes: first-year clinical, humanistic, and economic outcomes. J Am Pharm Assoc (2003). Mar-Apr. 2005;45(2):130-7. Exclusion Code: X2. [pmid: 15868754].
117 Garrett DG, Bluml BM. Patient self-management program for diabetes. J Pharm Soc Wis. 2005;(C):17-27. Exclusion Code: X4.
118 Geletko SM, Poulakos MN. Pharmaceutical services in an HIV clinic. Am J Health Syst Pharm. Apr. 15. 2002;59(8):709-13. Exclusion Code: X4. [pmid: 11977854].
119 Gerber RA, Liu G, McCombs JS. Impact of pharmacist consultations provided to patients with diabetes on healthcare costs in a health maintenance organization. Am J Manag Care. Jul. 1998;4(7):991-1000. Exclusion Code: X2. [pmid: 10181997].
120 Gilbert AL, Roughead EE, Beilby J, et al. Collaborative medication management services: improving patient care. Med J Aust. Aug. 19. 2002;177(4):189-92. Exclusion Code: X4. [pmid: 12175322].
121 Gillespie U, Alassaad A, Hammarlund-Udenaes M, et al. Effects of pharmacists' interventions on appropriateness of prescribing and evaluation of the instruments' (MAI, STOPP and STARTs') ability to predict hospitalization--analyses from a randomized controlled trial. PLoS One. 2013;8(5):e62401. Exclusion Code: X7. [pmid: 23690938].
122 Gizzi L, Slain D, Hare J, et al. An assessment of a pharmacy-based enhancement to the hospital medication reconciliation process. Exclusion Code: X2.
123 Goode JV, Swiger K, Bluml BM. Regional osteoporosis screening, referral, and monitoring program in community pharmacies: findings from Project ImPACT: Osteoporosis. J Am Pharm Assoc (2003). Mar-Apr. 2004;44(2):152-60. Exclusion Code: X2. [pmid: 15098849].
124 Gourley GA, Portner TS, Gourley DR, et al. Humanistic outcomes in the hypertension and COPD arms of a multicenter outcomes study. J Am Pharm Assoc (Wash). 1998;(5):586-97. Exclusion Code: X2. [pmid: 9782692].
125 Grantham D. Idaho behavioral health optimizes med management visits using telehealth. Behav Healthc. Oct. 2011;31(7):46-7. Exclusion Code: X1. [pmid: 22117294].
126 Griffiths M. Medicines management. Nurs Stand. Oct. 1-7. 2008;23(4):28. Exclusion Code: X1. [pmid: 19051531].
127 Griffiths M. Medicines management. Nurs Stand. Sep. 23-29. 2009;24(3):28. Exclusion Code: X1. [pmid: 19856642].
128 Griffiths M. Medicines management. Nurs Stand. Nov. 17-23. 2010;25(11):28. Exclusion Code: X1. [pmid: 21189818].
129 Griffiths M. Medicines management. Clear criteria are needed for any dose adjustment. Nurs Stand. Jan. 13-19. 2010;24(19):28. Exclusion Code: X1. [pmid: 20175358].
130 Gruffydd-Jones K, Hollinghurst S, Ward S, et al. Targeted routine asthma care in general practice using telephone triage. (Structured abstract). Br J Gen Pract. 2005;(1):918-23. Exclusion Code: X2. [pmid: 16378560].
131 Guirguis AB, Zingone MM. Medication therapy management and cost-related medication nonadherence. JAMA. Sep. 10. 2008;300(10):1130. author reply -1. Exclusion Code: X1. [pmid: 18780839].
132 Haines LA, Putney KS, Varkey DA, et al. Pilot of a patient-centered pharmacy practice model. Am J Health Syst Pharm. Nov. 1. 2012;69(21):1860-1. Exclusion Code: X5. [pmid: 23111668].
133 Hall D, Buchanan J, Helms B, et al. Health care expenditures and therapeutic outcomes of a pharmacist-managed anticoagulation service versus usual medical care. Pharmacotherapy. Jul. 2011;31(7):686-94. Exclusion Code: X2. [pmid: 21923456].
134 Hall DL, Pater KS. Implementation of a Medication Therapy Management Program in a Hospital-Based Outpatient Pharmacy. 512. Exclusion Code: X4.
135 Hallam A. Does peer review improve patient care and documentation in medication therapy management?. Kaiser Permanente. 1-33. Exclusion Code: X2.
136 Hardin HC, Hall AM, Roane TE, et al. An Advanced Pharmacy Practice Experience in a Student-Staffed Medication Therapy Management Call Center. p. NIL. Exclusion Code: X4.
137 Harris A, Gospodarevskaya E, Callaghan J, et al. The cost effectiveness of a pharmacist reviewing medication among the elderly in the community. Australas J Ageing. 2001;20(4):179-86. Exclusion Code: X2.
138 Harris IM, Westberg SM, Frakes MJ, et al. Outcomes of medication therapy review in a family medicine clinic. J Am Pharm Assoc (2003). Sep-Oct. 2009;49(5):623-7. Exclusion Code: X4. [pmid: 19748869].
139 Harrison JJ, Wang J, Cervenko J, et al. Pilot study of a pharmaceutical care intervention in an outpatient lung transplant clinic. Clin Transplant. Mar-Apr. 2012;26(2):E149-57. Exclusion Code: X7. [pmid: 22507355].
140 Hassol A, Shoemaker SJ. Exploratory Research on Medication Therapy Management. (Prepared by Abt Associates under Contract #HHSM-500-2005-00181/TO#3). Baltimore, MD. Centers for Medicare & Medicaid Services. July. 8. 2008. http://www.cms.gov/Research-Statistics-Data-and-Systems/Statistics-Trends-and-Reports/Reports/downloads/blackwell.pdf. Exclusion Code: X4.
141 Hata M, Klotz R, Sylvies R, et al. Medication therapy management services provided by student pharmacists. Am J Pharm Educ. Apr. 10. 2012;76(3):51. Exclusion Code: X4. [pmid: 22544968].
142 Hellstrom LM, Bondesson A, Hoglund P, et al. Impact of the Lund Integrated Medicines Management (LIMM) model on medication appropriateness and drug-related hospital revisits. Eur J Clin Pharmacol. Jul. 2011;67(7):741-52. Exclusion Code: X2. [pmid: 21318595].
143 Hemens BJ, Holbrook A, Tonkin M, et al. Computerized clinical decision support systems for drug prescribing and management: a decision-maker-researcher partnership systematic review. Implement Sci. 2011;6:89. Exclusion Code: X2. [pmid: 21824383].
144 Hilario Deguzman LF. Intervening On Hospital Discharge Patients: Results from a Medicare Part D MTM program. Kaiser Permanente. 2013:1-32. Exclusion Code: X2.
145 Hogan EG, Leal S, Slack M, et al. Comparison of pharmacist led collaborative drug therapy management to standard physician provided therapy for type 2 diabetes mellitus. ASHP Midyear Clinical Meeting. 2005;40:P518E. Exclusion Code: X2.
146 Holloway KA, Ivanovska V, Wagner AK, et al. Have we improved use of medicines in developing and transitional countries and do we know how to? Two decades of evidence. Trop Med Int Health. Jun. 2013;18(6):656-64. Exclusion Code: X2. [pmid: 23648177].
147 Holtorf AP, McAdam-Marx C, Schaaf D, et al. Systematic review on quality control for drug management programs: is quality reported in the literature?. BMC Health Serv Res. 2009;9:38. Exclusion Code: X2. [pmid: 19243591].
148 Hong N, Jackson L, Pisupati R. Evaluation of clinical pharmacy services in an ambulatory care HIV/AIDS Clinic. 056. Exclusion Code: X4.
149 Howard-Thompson A, Farland MZ, Byrd DC, et al. Pharmacist-Physician Collaboration for Diabetes Care: Cardiovascular Outcomes. Ann Pharmacother. 47:1471. Exclusion Code: X2. [pmid: 24285763].
150 Humphries TL, Carroll N, Chester EA, et al. Evaluation of an electronic critical drug interaction program coupled with active pharmacist intervention. Ann Pharmacother. Dec. 2007;41(12):1979-85. Exclusion Code: X2. [pmid: 17986517].
151 Hunteman LM. Potential role of medication therapy management for bariatric surgery patients. J Am Pharm Assoc (2003). Jul-Aug. 2008;48(4):440-2. Exclusion Code: X1. [pmid: 18653412].
152 Hussein M, Benner JS, Lee D, et al. Propensity score matching in the evaluation of drug therapy management programs: an illustrative analysis of a program for patients with hepatitis C virus. Qual Manag Health Care. Jan-Mar. 2010;19(1):25-33. Exclusion Code: X2. [pmid: 20042931].
153 Isetts BJ. Evaluating Effectiveness of the Minnesota Medication Therapy Management Care Program: Final Report. University of Minnesota College of Pharmacy. Minneapolis, MN. 2007. Exclusion Code: X4.
154 Isetts BJ, Brown LM, Schondelmeyer SW, et al. Quality assessment of a collaborative approach for decreasing drug-related morbidity and achieving therapeutic goals. Arch Intern Med. Aug. 11-25. 2003;163(15):1813-20. Exclusion Code: X4. [pmid: 12912717].
155 Isetts BJ, Brummel AR, de Oliveira DR, et al. Managing drug-related morbidity and mortality in the patient-centered medical home. Med Care. Nov. 2012;50(11):997-1001. Exclusion Code: X2. [pmid: 23047790].
156 Isetts BJ, Schondelmeyer SW, Heaton AH, et al. Effects of collaborative drug therapy management on patients' perceptions of care and health-related quality of life. Res Social Adm Pharm. Mar. 2006;2(1):129-42. Exclusion Code: X2. [pmid: 17138505].
157 Jaber LA, Halapy H, Fernet M, et al. Evaluation of a pharmaceutical care model on diabetes management. Ann Pharmacother. Mar. 1996;30(3):238-43. Exclusion Code: X2. [pmid: 8833557].
158 Jack BW, Chetty VK, Anthony D, et al. A reengineered hospital discharge program to decrease rehospitalization: a randomized trial. Ann Intern Med. 2009;(3):178-87. Exclusion Code: X2. [pmid: 19189907].
159 Jackevicius CA, Li P, Tu JV. Prevalence, predictors, and outcomes of primary nonadherence after acute myocardial infarction. Circulation. Feb. 26. 2008;117(8):1028-36. Exclusion Code: X2. [pmid: 18299512].
160 Jackson GL, Oddone EZ, Olsen MK, et al. Racial differences in the effect of a telephone-delivered hypertension disease management program. J Gen Intern Med. Dec. 2012;27(12):1682-9. Exclusion Code: X2. [pmid: 22865016].
161 Jameson JP, VanNoord GR. Pharmacotherapy consultation on polypharmacy patients in ambulatory care. Ann Pharmacother. Jul-Aug. 2001;35(7-8):835-40. Exclusion Code: X2. [pmid: 11485129].
162 Jayaprakash A. ASCP reports. Consult Pharm. Feb. 2010;25(2):128. Exclusion Code: X1. [pmid: 20211826].
163 Johnson CL, Nicholas A, Divine H, et al. Outcomes from DiabetesCARE: a pharmacist-provided diabetes management service. J Am Pharm Assoc (2003). Nov-Dec. 2008;48(6):722-30. Exclusion Code: X4. [pmid: 19019800].
164 Johnson JA, Bootman JL. Drug-related morbidity and mortality and the economic impact of pharmaceutical care. Am J Health Syst Pharm. Mar. 1. 1997;54(5):554-8. Exclusion Code: X2. [pmid: 9066865].
165 Johnston AM, Doane K, Phipps S, et al. Outcomes of pharmacists' cognitive services in the long-term care setting. Consult Pharm. 1996;11:41-50. Exclusion Code: X4.
166 Kaboli PJ, Fernandes O. Medication reconciliation: moving forward. Arch Intern Med. Jul. 23. 2012;172(14):1069-70. Exclusion Code: X1. [pmid: 22733283].
167 Karapinar-Carkit F, Borgsteede SD, Zoer J, et al. The effect of the COACH program (Continuity Of Appropriate pharmacotherapy, patient Counselling and information transfer in Healthcare) on readmission rates in a multicultural population of internal medicine patients. BMC Health Serv Res. 2010;10:39. Exclusion Code: X7. [pmid: 20156368].
168 Kimberlin CL, Berardo DH, Pendergast JF, et al. Effects of an education program for community pharmacists on detecting drug-related problems in elderly patients. Med Care. May. 1993;31(5):451-68. Exclusion Code: X2. [pmid: 8501992].
169 Kliethermes MA. Adherence in an MTM clinic. 2009:204. Exclusion Code: X8.
170 Klimek JS. MTM services standards improve patient safety. Medication therapy management safeguards, systems and services can reduce the total number of medication-related complications. Health Manag Technol. Jul. 2009;30(7):20-1. Exclusion Code: X1. [pmid: 19739561].
171 Kocarnik BM, Liu CF, Wong ES, et al. Does the presence of a pharmacist in primary care clinics improve diabetes medication adherence?. BMC Health Serv Res. 2012;12:391. Exclusion Code: X2. [pmid: 23148570].
172 Krass I, Taylor SJ, Smith C, et al. Impact on medication use and adherence of Australian pharmacists' diabetes care services. J Am Pharm Assoc (2003). Jan-Feb. 2005;45(1):33-40. Exclusion Code: X2. [pmid: 15730115].
173 Kripalani S, Roumie CL, Dalal AK, et al. Effect of a pharmacist intervention on clinically important medication errors after hospital discharge: a randomized trial. Ann Intern Med. Jul. 3. 2012;157(1):1-10. Exclusion Code: X7. [pmid: 22751755].
174 Kucukarslan SN, Hagan AM, Shimp LA, et al. Integrating medication therapy management in the primary care medical home: A review of randomized controlled trials. Am J Health Syst Pharm. Feb. 15. 2011;68(4):335-45. Exclusion Code: X6. [pmid: 21289329].
175 Kumbera P. A new addition to pharmacy's alphabet soup: MTMS. Pharmacy Times (USA). 2005;71(Mar):90. Exclusion Code: X1.
176 Kuzuya M, Hirakawa Y, Suzuki Y, et al. Association between unmet needs for medication support and all-cause hospitalization in community-dwelling disabled elderly people. J Am Geriatr Soc. May. 2008;56(5):881-6. Exclusion Code: X2. [pmid: 18384585].
177 Kwint HF, Bermingham L, Faber A, et al. The relationship between the extent of collaboration of general practitioners and pharmacists and the implementation of recommendations arising from medication review: a systematic review. Drugs Aging. Feb. 2013;30(2):91-102. Exclusion Code: X2. [pmid: 23322285].
178 Lai LL, Sorkin AL. Cost benefit analysis of pharmaceutical care in a Medicaid population\M/from a budgetary perspective. J Manag Care Pharm. 1998;4(May-Jun):303-8. Exclusion Code: X6.
179 Lai PS, Chua SS, Chan SP. Pharmaceutical care issues encountered by post-menopausal osteoporotic women prescribed bisphosphonates. J Clin Pharm Ther. 2012;37(5):536-43. Exclusion Code: X2. [pmid: 22380577].
180 Lam A. Practice innovations: Delivering medication therapy management services via videoconference interviews. Consultant pharmacist. 2011;(10):764-73. Exclusion Code: X4. [pmid: 22005142].
181 Lam A, Odegard PS, Gardner J. School of pharmacy-based medication therapy management program: development and initial experience. J Am Pharm Assoc (2003). May-Jun. 2012;52(3):398-404. Exclusion Code: X4. [pmid: 22618981].
182 Lam S, Ruby CM. Impact of an interdisciplinary team on drug therapy outcomes in a geriatric clinic. Am J Health Syst Pharm. Mar. 15. 2005;62(6):626-9. Exclusion Code: X2. [pmid: 15757885].
183 LaMarr B, Valdez C, Driscoll K, et al. Influence of pharmacist intervention on prescribing of angiotensin-converting-enzyme inhibitors, angiotensin II-receptor blockers, and aspirin for diabetic patients. Am J Health Syst Pharm. Feb. 15. 2010;67(4):290-4. Exclusion Code: X2. [pmid: 20133534].
184 Lambert-Kerzner A, Del Giacco EJ, Fahdi IE, et al. Patient-centered adherence intervention after acute coronary syndrome hospitalization. Circ Cardiovasc Qual Outcomes. Jul. 1. 2012;5(4):571-6. Exclusion Code: X6. [pmid: 22811499].
185 Lapane KL, Hughes CM. Pharmacotherapy interventions undertaken by pharmacists in the Fleetwood phase III study: the role of process control. Ann Pharmacother. Sep. 2006;40(9):1522-6. Exclusion Code: X5. [pmid: 16882872].
186 Lapane KL, Hughes CM, Christian JB, et al. Evaluation of the fleetwood model of long-term care pharmacy. J Am Med Dir Assoc. Jun. 2011;12(5):355-63. Exclusion Code: X2. [pmid: 21450170].
187 Lau DT. Consumer medication management and error. Clin Ther. Nov. 2008;30(11):2156-8. Exclusion Code: X1. [pmid: 19108803].
188 Ledwidge M, Barry M, Cahill J, et al. Is multidisciplinary care of heart failure cost-beneficial when combined with optimal medical care?. (Structured abstract). Eur J Heart Fail. 2003;(3):381-9. Exclusion Code: X2. [pmid: 12798838].
189 Lee E, Braund R, Tordoff J. Examining the first year of Medicines Use Review services provided by pharmacists in New Zealand: 2008. N Z Med J. Apr. 24. 2009;122(1293):3566. Exclusion Code: X6. [pmid: 19448788].
190 Lee JK, Grace KA, Taylor AJ. Effect of a pharmacy care program on medication adherence and persistence, blood pressure, and low-density lipoprotein cholesterol: a randomized controlled trial. JAMA. Dec. 6. 2006;296(21):2563-71. Exclusion Code: X2. [pmid: 17101639].
191 Lee KL, Peng YL, Chou JL, et al. Economic evaluation of therapeutic drug monitoring services in renal transplant recipients treated with cyclosporine. (Structured abstract). Transplant Proc. 2000;(7):1801-6. Exclusion Code: X3. [pmid: 11119944].
192 Lee M, Kemp JA, Canning A, et al. A randomized controlled trial of an enhanced patient compliance program for Helicobacter pylori therapy. Arch Intern Med. Oct. 25. 1999;159(19):2312-6. Exclusion Code: X3. [pmid: 10547171].
193 Leikola SN, Virolainen J, Tuomainen L, et al. Comprehensive medication reviews for elderly patients: findings and recommendations to physicians. J Am Pharm Assoc (2003). Sep-Oct. 2012;52(5):630-3. Exclusion Code: X4. [pmid: 23023843].
194 Lemay G. Medication therapy management in community pharmacy practice. Med Health R I. Sep. 2012;95(9):281-2. Exclusion Code: X1. [pmid: 23094424].
195 Li X, Mao M, Ping Q. Effect of pharmaceutical care programs on glycemic control in patients with diabetes mellitus: a meta-analysis of randomized controlled trials. (Structured abstract). J Pharm Technol. 2010;(5):255-63. Exclusion Code: X2.
196 Liang C. The Impact of Post-Discharge Medication Therapy Management (MTM) Encounters on Readmission Rate. Kaiser Permanente. Exclusion Code: X2.
197 Libby EA, Laub JJ. Economic and clinical impact of a pharmacy-based antihypertensive replacement program in primary care. Am J Health Syst Pharm. Sep. 15. 1997;54(18):2079-83. Exclusion Code: X2. [pmid: 9377207].
198 Lin KE, Lei EX, Chretien SD. Pharmacotherapy assessment and education for newly enrolled patients in a primary care clinic. ASHP Midyear Clinical Meeting. 2001;36(Dec). P-E. Exclusion Code: X3.
199 Lingaratnam S, Aranda S, Pearce T, et al. A controlled before and after study to evaluate a patient and health professional partnership model towards effective medication reconciliation. J Oncol Pharm Pract. Mar. 2013;19(1):48-56. Exclusion Code: X4. [pmid: 22849967].
200 Linton A, Bacon TA, Trice S, et al. Results from a mailed promotion of medication reviews among Department of Defense beneficiaries receiving 10 or more chronic medications. J Manag Care Pharm. Oct. 2010;16(8):578-92. Exclusion Code: X2. [pmid: 20866163].
201 Lipton HL, Bero LA, Bird JA, et al. The impact of clinical pharmacists' consultations on physicians' geriatric drug prescribing. A randomized controlled trial. Med Care. Jul. 1992;30(7):646-58. Exclusion Code: X2. [pmid: 1614233].
202 Lobeck F, Traxler WT, Bobinet DD. The cost-effectiveness of a clinical pharmacy service in an outpatient mental health clinic. Hosp Community Psychiatry. Jun. 1989;40(6):643-5. Exclusion Code: X2. [pmid: 2500390].
203 Lu Z, Cao S, Chai Y, et al. Effectiveness of interventions for hypertension care in the community: a meta-analysis of controlled studies in China. (Provisional abstract). DARE. 2012;(4). Exclusion Code: X2.
204 Ma CB, Nakasato SK. Effectiveness of an educational program to improve patient understanding of and compliance with drug therapies used to treat HIV disease. ASHP Midyear Clinical Meeting. 1991;26(Dec). P-R. Exclusion Code: X2.
205 Maack B, Miller DR, Johnson T, et al. Economic impact of a pharmacy resident in an assisted living facility-based medication therapy management program. Ann Pharmacother. Nov. 2008;42(11):1613-20. Exclusion Code: X4. [pmid: 18940921].
206 Malaeb DN, Aoun J. Physician community pharmacist collaborative care in diabetes management. 2011. P. Exclusion Code: X2.
207 Martinez AS, Saef J, Paszczuk A, et al. Implementation of a pharmacist-managed heart failure medication titration clinic. Am J Health Syst Pharm. Jun. 15. 2013;70(12):1070-6. Exclusion Code: X4. [pmid: 23719886].
208 McAdam-Marx C, Schaaf DT, Holtorf AP, et al. Systematic analysis of outcomes evaluations applied to drug management programs. Am J Manag Care. Nov. 2008;14(11 Suppl):SP36-45. Exclusion Code: X2. [pmid: 18991480].
209 McAllister D, Schommer JC, McAuley JW, et al. Comparison of skilled nursing and assisted living residents to determine potential benefits of pharmacist intervention. Consultant Pharmacist (USA). 2000;15(Nov):1110-6. Exclusion Code: X2.
210 McCall N, Cromwell J, Urato C. Evaluation of Medicare Care Management for High Cost Beneficiaries (CMHCB) Demonstration: VillageHealth's Key to Better Health (KTBH). (Prepared by RTI International under CMS Contract No #500-00-0024/TO#25). Baltimore, MD. Centers for Medicare & Medicaid Services. 2010. Exclusion Code: X2.
211 McCombs JS, Liu G, Shi J, et al. The Kaiser Permanente/USC Patient Consultation Study: change in use and cost of health care services. Am J Health Syst Pharm. Dec. 1. 1998;55(23):2485-99. Exclusion Code: X2. [pmid: 9853633].
212 McCord AD. Clinical impact of a pharmacist-managed diabetes mellitus drug therapy management service. Pharmacotherapy. Feb. 2006;26(2):248-53. Exclusion Code: X2. [pmid: 16466329].
213 McDonough RP. Medication therapy management and collaborative practice: How to make it work. Drug Topics. 155:52. Exclusion Code: X1.
214 McDonough RP, Doucette WR. Drug therapy management: an empirical report of drug therapy problems, pharmacists' interventions, and results of pharmacists' actions. J Am Pharm Assoc (2003). Jul-Aug. 2003;43(4):511-8. Exclusion Code: X2. [pmid: 12952316].
215 McFarland M, Davis K, Wallace J, et al. Use of home telehealth monitoring with active medication therapy management by clinical pharmacists in veterans with poorly controlled type 2 diabetes mellitus. Pharmacotherapy. May. 2012;32(5):420-6. Exclusion Code: X2. [pmid: 22488512].
216 McIntosh K. Medicines management. Nurs Times. Nov. 4-10. 2008;104(44):18-20. Exclusion Code: X1. [pmid: 19014127].
217 McKibbon KA, Lokker C, Handler SM, et al. The effectiveness of integrated health information technologies across the phases of medication management: a systematic review of randomized controlled trials. J Am Med Inform Assoc. Jan-Feb. 2012;19(1):22-30. Exclusion Code: X2. [pmid: 21852412].
218 McLean W, Gillis J, Waller R. The BC Community Pharmacy Asthma Study: A study of clinical, economic and holistic outcomes influenced by an asthma care protocol provided by specially trained community pharmacists in British Columbia. Can Respir J. May-Jun. 2003;10(4):195-202. Exclusion Code: X2. [pmid: 12851665].
219 McMahan R. Medication therapy management services: assessing year 1, gauging year 2. J Am Pharm Assoc (2003). Nov-Dec. 2006;46(6):680-1. Exclusion Code: X1. [pmid: 17176682].
220 Meindl CL, Duncan AL, Achusim LE, et al. Impact of a clinical pharmacist in an internal medicine resident clinic. ASHP Midyear Clinical Meeting. 1998;33(Dec). P-R. Exclusion Code: X4.
221 Michaels NM, Jenkins GF, Pruss DL, et al. Retrospective analysis of community pharmacists' recommendations in the North Carolina Medicaid medication therapy management program. J Am Pharm Assoc (2003). May-Jun. 2010;50(3):347-53. Exclusion Code: X4. [pmid: 20452907].
222 Michel B, Quelennec B, Andres E. Medication reconciliation practices and potential clinical impact of unintentional discrepancies. JAMA Intern Med. Feb. 11. 2013;173(3):246-7. Exclusion Code: X2. [pmid: 23400661].
223 Midlov P, Bahrani L, Seyfali M, et al. The effect of medication reconciliation in elderly patients at hospital discharge. Int J Clin Pharm. Feb. 2012;34(1):113-9. Exclusion Code: X2. [pmid: 22207271].
224 Monte SV, Slazak EM, Albanese NP, et al. Clinical and economic impact of a diabetes clinical pharmacy service program in a university and primary care-based collaboration model. J Am Pharm Assoc (2003). Mar-Apr. 2009;49(2):200-8. Exclusion Code: X4. [pmid: 19289346].
225 Mort J. Medication therapy management: a Medicare Part D benefit available to qualifying beneficiaries. S D Med. Mar. 2007;60(3):121. Exclusion Code: X1. [pmid: 17455583].
226 Mortimer C, Emmerton L, Lum E. The impact of an aged care pharmacist in a department of emergency medicine. J Eval Clin Pract. Jun. 2011;17(3):478-85. Exclusion Code: X3. [pmid: 21040247].
227 Motz J. The implementation of MTM in community pharmacies - Communication and planning are key factors for success. J Pharm Soc Wis. 2007;(SEP-OCT):11-2. Exclusion Code: X1.
228 Mueller SK, Kripalani S, Stein J, et al. A toolkit to disseminate best practices in inpatient medication reconciliation: multi-center medication reconciliation quality improvement study (MARQUIS). Jt Comm J Qual Patient Saf. Aug. 2013;39(8):371-82. Exclusion Code: X2. [pmid: 23991510].
229 Mueller SK, Sponsler KC, Kripalani S, et al. Hospital-based medication reconciliation practices: a systematic review. Arch Intern Med. Jul. 23. 2012;172(14):1057-69. Exclusion Code: X2. [pmid: 22733210].
230 Murphy P, Cocohoba J, Tang A, et al. Impact of HIV-specialized pharmacies on adherence and persistence with antiretroviral therapy. Aids Patient Care STDS. Sep. 2012;26(9):526-31. Exclusion Code: X2. [pmid: 22860900].
231 Murray MD, Young J, Hoke S, et al. Pharmacist intervention to improve medication adherence in heart failure: a randomized trial. Ann Intern Med. May. 15. 2007;146(10):714-25. Exclusion Code: X2. [pmid: 17502632].
232 Nau DP, Pacholski AM. Impact of pharmacy care services on patients' perceptions of health care quality for diabetes. J Am Pharm Assoc (2003). May-Jun. 2007;47(3):358-65. Exclusion Code: X4. [pmid: 17510030].
233 Nguyen J. Evaluating the Medication Therapy Management Program Impact on Hospital and ED Visits. Kaiser Permanente. 1-34. Exclusion Code: X7.
234 Nguyen J, Matsuoka B, Morodomi L, et al. Evaluating the Medication Therapy Management Program impact. CA J Health-Sys Pharm. 2011;23:11. Exclusion Code: X8.
235 Nkansah N, Mostovetsky O, Yu C, et al. Effect of outpatient pharmacists' non-dispensing roles on patient outcomes and prescribing patterns. Cochrane Database Syst Rev. 2010(7). CD000336. Exclusion Code: X6. [pmid: 20614422].
236 Nola KM, Gourley DR, Portner TS, et al. Clinical and humanistic outcomes of a lipid management program in the community pharmacy setting. J Am Pharm Assoc (Wash). 2000;(2):166-73. Exclusion Code: X2. [pmid: 10730020].
237 Osterberg L, Blaschke T. Adherence to medication. N Engl J Med. Aug. 4. 2005;353(5):487-97. Exclusion Code: X1. [pmid: 16079372].
238 Oyetayo OO, James C, Martinez A, et al. The Hispanic Diabetes Management Program: Impact of community pharmacists on clinical outcomes. J Am Pharm Assoc (2003). Sep-Oct. 2011;51(5):623-6. Exclusion Code: X4. [pmid: 21896461].
239 Packard K, Herink M, Kuhlman P. Pharmacist's role in an interdisciplinary cardiac rehabilitation team. J Allied Health. Fall. 2012;41(3):113-7. 7a. 7b. Exclusion Code: X4. [pmid: 22968772].
240 Padiyara RS, Rabi SM. Physician perceptions of pharmacist provision of outpatient medication therapy management services. J Am Pharm Assoc (2003). Nov-Dec. 2006;46(6):660. 3. Exclusion Code: X4. [pmid: 17176679].
241 Pakes GE. Group medication counseling conducted by a pharmacist for severely disturbed clients. Hosp Community Psychiatry. Apr. 1979;30(4):237-8. Exclusion Code: X2. [pmid: 422130].
242 Parks PM. A patient medication counseling group in an adult psychiatric facility. Hosp Pharm. Feb. 1977;12(2):63-4. Exclusion Code: X4. [pmid: 10305432].
243 Patel P, Roberts S, Cooper S, et al. Evaluation of Medication Therapy Management Program in a Health Maintenance Organization. Kaiser Permanente. 1-13. Exclusion Code: X4.
244 Patterson SM, Hughes C, Kerse N, et al. Interventions to improve the appropriate use of polypharmacy for older people. Cochrane Database Syst Rev. 2012;5. CD008165. Exclusion Code: X2. [pmid: 22592727].
245 Pecora PG, Flint NB, Aleman MA. Improving disease control in patients with hypertension and/or diabetes mellitus with the implementation of ambulatory clinical pharmacy services. ASHP Midyear Clinical Meeting. 1998;33(Dec). P-E. Exclusion Code: X2.
246 Perera PN, Guy MC, Sweaney AM, et al. Evaluation of prescriber responses to pharmacist recommendations communicated by fax in a medication therapy management program (MTMP). J Manag Care Pharm. Jun. 2011;17(5):345-54. Exclusion Code: X4. [pmid: 21657804].
247 Persell SD, Eder M, Friesema E, et al. EHR-based medication support and nurse-led medication therapy management: rationale and design for a three-arm clinic randomized trial. J Am Heart Assoc. Oct. 2013;2(5):e000311. Exclusion Code: X6. [pmid: 24157649].
248 Petty DR, Zermansky AG, Raynor DK, et al. Clinical medication review by a pharmacist of elderly patients on repeat medications in general practice - Pharmacist interventions and review outcomes. Int J Pharm Pract. 2002;(1):39-45. Exclusion Code: X5.
249 Pickard AS, Johnson JA, Farris KB. The impact of pharmacist interventions on health-related quality of life. Ann Pharmacother. Nov. 1999;33(11):1167-72. Exclusion Code: X2. [pmid: 10573313].
250 Pinto SL, Bechtol RA, Partha G. Evaluation of outcomes of a medication therapy management program for patients with diabetes. 519. Exclusion Code: X4.
251 Pinto SL, Kumar J, Partha G, et al. Pharmacist-Provided Medication Therapy Management (MTM) Program Impacts Outcomes for Employees With Diabetes. Popul Health Manag. 2013. Jul. 12. Exclusion Code: X4. [pmid: 23848476].
252 Pinto SL, Kumar J, Partha G, et al. Improving the economic and humanistic outcomes for diabetic patients: making a case for employer-sponsored medication therapy management. Clinicoecon Outcomes Res. 2013;5:153-9. Exclusion Code: X4. [pmid: 23610526].
253 Ponnusankar S, Surulivelrajan M, Anandamoorthy N, et al. Assessment of impact of medication counseling on patients' medication knowledge and compliance in an outpatient clinic in South India. Patient Educ Couns. Jul. 2004;54(1):55-60. Exclusion Code: X2. [pmid: 15210260].
254 Powers MF. Recently approved medicare provisions for prescription drugs and medication management services. J Pharm Tech. 2005;21(Feb):63-8. Exclusion Code: X2.
255 Raimondi GA, Menga G, Botas C, et al. Decline of outpatient asthma management in Argentina. Respirology. Jan. 2008;13(1):134-7. Exclusion Code: X2. [pmid: 18197924].
256 Reinke T. Medication therapy management program in N.C. saves $13 million. Manag Care. Oct. 2011;20(10):17-8. Exclusion Code: X1. [pmid: 22111478].
257 Rennke S, Nguyen OK, Shoeb MH, et al. Hospital-initiated transitional care interventions as a patient safety strategy: a systematic review. (Structured abstract). DARE. 2013;(4):433-40. Exclusion Code: X2.
258 Riley D, Dodson P. Medicine management for the elderly. Tex Hosp. Apr. 1983;38(11):20. Exclusion Code: X1. [pmid: 10317312].
259 Roberts S, Gainsbrugh R. Medication therapy management and collaborative drug therapy management. J Manag Care Pharm. Jan-Feb. 2010;16(1):67-8. Exclusion Code: X6. [pmid: 20044847].
260 Rodgers S, Avery AJ, Meechan D, et al. Controlled trial of pharmacist intervention in general practice: the effect on prescribing costs. Br J Gen Pract. Sep. 1999;49(446):717-20. Exclusion Code: X2. [pmid: 10756613].
261 Ross LA, Bloodworth LS. Patient-centered health care using pharmacist-delivered medication therapy management in rural Mississippi. JAPhA. 52:802. Exclusion Code: X4. [pmid: 23229968].
262 Roughead EE, Barratt JD, Ramsay E, et al. Collaborative home medicines review delays time to next hospitalization for warfarin associated bleeding in Australian war veterans. J Clin Pharm Ther. Feb. 2011;36(1):27-32. Exclusion Code: X2. [pmid: 21108651].
263 Roughead EE, Semple SJ, Vitry AI. Pharmaceutical care services: a systematic review of published studies, 1990 to 2003, examining effectiveness in improving patient outcomes. (Structured abstract). Int J Pharm Pract. 2005;(1):53-70. Exclusion Code: X3.
264 Rozenfeld V, Pflomm J, Singh KK, et al. Assessing the impact of medication consultations with a Medication Event Monitoring System. Hosp Pharm. 1999;(5):539-49. Exclusion Code: X2.
265 Rucker NL. Medicare Part D's Medication Therapy Management: Shifting from Neutral to Drive. AARP Public Policy Institute. Washington, DC. 2012. Exclusion Code: X1.
266 Sadler MA, Force RW. Pharmacy services in an ambulatory FFS setting can increase physician revenue. Formulary (USA). 2002;37(Feb):97-01. Exclusion Code: X2.
267 Saez-Benito L, Fernandez-Llimos F, Feletto E, et al. Evidence of the clinical effectiveness of cognitive pharmaceutical services for aged patients. Age Ageing. Jul. 2013;42(4):442-9. Exclusion Code: X2. [pmid: 23676212].
268 Saini B, Filipovska J, Bosnic-Anticevich S, et al. An evaluation of a community pharmacy-based rural asthma management service. Aust J Rural Health. Apr. 2008;16(2):100-8. Exclusion Code: X2. [pmid: 18318852].
269 Saini B, Krass I, Armour C. Development, implementation, and evaluation of a community pharmacy-based asthma care model. (Structured abstract). Ann Pharmacother. 2004;(11):1954-60. Exclusion Code: X2. [pmid: 15479780].
270 Salvador CH, Ruiz-Sanchez A, Gonzalez de Mingo MA, et al. Evaluation of a telemedicine-based service for the follow-up and monitoring of patients treated with oral anticoagulant therapy. IEEE Trans Inf Technol Biomed. Nov. 2008;12(6):696-706. Exclusion Code: X2. [pmid: 19000948].
271 Sando KR, Elliott J, Stanton ML, et al. An educational tool for teaching medication history taking to pharmacy students. Am J Pharm Educ. Jun. 12. 2013;77(5):105. Exclusion Code: X2. [pmid: 23788816].
272 Schnipper JL, Roumie CL, Cawthon C, et al. Rationale and design of the Pharmacist Intervention for Low Literacy in Cardiovascular Disease (PILL-CVD) study. Circulation. 2010;(2):212-9. Exclusion Code: X7. [pmid: 20233982].
273 Schroeder SD. Quality focus: medication therapy management services. A multi-state collaborative. S D Med. Dec. 2007;60(12):499. Exclusion Code: X4. [pmid: 18232257].
274 Schulz M. Pharmacist care for reactive airway disease. JAMA. Mar. 5. 2003;289(9):1104. author reply 5-6. Exclusion Code: X1. [pmid: 12622576].
275 Schulz M, Verheyen F, Muhlig S, et al. Pharmaceutical care services for asthma patients: a controlled intervention study. J Clin Pharmacol. Jun. 2001;41(6):668-76. Exclusion Code: X2. [pmid: 11402636].
276 Schulz RM, Porter C, Lane M, et al. Impact of a medication management system on nursing home admission rate in a community-dwelling nursing home-eligible Medicaid population. Am J Geriatr Pharmacother. Feb. 2011;9(1):69-79. Exclusion Code: X2. [pmid: 21459310].
277 Scott A, Tinelli M, Bond C. Costs of a community pharmacist-led medicines management service for patients with coronary heart disease in England: healthcare system and patient perspectives. Pharmacoeconomics. 2007;25(5):397-411. Exclusion Code: X2. [pmid: 17488138].
278 Shah C, Coyne T. Medicines management programme for non-medical prescribers. Nurs Manag (Harrow). Dec. 2012;19(8):34-7. Exclusion Code: X2. [pmid: 23285791].
279 Shillam CR, Orton VJ, Waring D, et al. Faith community nurses & brown bag events help older adults manage meds. J Christ Nurs. Apr-Jun. 2013;30(2):90-6. Exclusion Code: X4. [pmid: 23607155].
280 Simon GE, Ludman EJ, Operskalski BH. Randomized trial of a telephone care management program for outpatients starting antidepressant treatment. Psychiatr Serv. Oct. 2006;57(10):1441-5. Exclusion Code: X2. [pmid: 17035563].
281 Simpson SH, Johnson JA, Tsuyuki RT. Economic impact of community pharmacist intervention in cholesterol risk management: an evaluation of the study of cardiovascular risk intervention by pharmacists. Pharmacotherapy. May. 2001;21(5):627-35. Exclusion Code: X2. [pmid: 11349751].
282 Singhal PK, Raisch DW, Gupchup GV. The impact of pharmaceutical services in community and ambulatory care settings: evidence and recommendations for future research. Ann Pharmacother. Dec. 1999;33(12):1336-55. Exclusion Code: X4. [pmid: 10630834].
283 Sklenicka JM, Proffitt LS, Dare D. The role of a geriatric clinical pharmacist in improving medication safety in outpatient clinics. ASHP Midyear Clinical Meeting. 2005;40. P-D. Exclusion Code: X4.
284 Smith CP, Christensen DB. Identification and clarification of drug therapy problems by Indian health service pharmacists. Ann Pharmacother. Feb. 1996;30(2):119-24. Exclusion Code: X4. [pmid: 8835041].
285 Smith DH, Fassett WE, Christensen DB. Washington State CARE Project: downstream cost changes associated with the provision of cognitive services by pharmacists. J Am Pharm Assoc (Wash). Sep-Oct. 1999;39(5):650-7. Exclusion Code: X2. [pmid: 10533346].
286 Smith SR, Catellier DJ, Conlisk EA, et al. Effect on health outcomes of a community-based medication therapy management program for seniors with limited incomes. Am J Health Syst Pharm. Feb. 15. 2006;63(4):372-9. Exclusion Code: X2. [pmid: 16452523].
287 Smith SR, Clancy CM. Medication therapy management programs: forming a new cornerstone for quality and safety in medicare. Am J Med Qual. Jul-Aug. 2006;21(4):276-9. Exclusion Code: X1. [pmid: 16849785].
288 Soller RW, Vogt E. Positioning patient counselling as a measurable cornerstone of medication therapy management. Int J Pharm Pract. Oct. 2010;18(5):249-51. Exclusion Code: X1. [pmid: 20840679].
289 Solomon DK, Portner TS, Bass GE, et al. Clinical and economic outcomes in the hypertension and COPD arms of a multicenter outcomes study. J Am Pharm Assoc (Wash). 1998;(5):574-85. Exclusion Code: X2. [pmid: 9782691].
290 Solow B. Medication therapy management--not just for seniors anymore. Manag Care. Oct. 2009;18(10):7. Exclusion Code: X1. [pmid: 19902682].
291 Sperling S, Neal K, Hales K, et al. A quality improvement project to reduce falls and improve medication management. Home Health Care Serv Q. 2005;24(1-2):13-28. Exclusion Code: X3. [pmid: 16236656].
292 Spooner JJ. Medication therapy management programs: when will the outcomes come out?. J Manag Care Pharm. Apr. 2007;13(3):276-7. Exclusion Code: X1. [pmid: 17407394].
293 Stang P, Morris L, Kempf J, et al. The coprescription of contraindicated drugs with statins: continuing potential for increased risk of adverse events. Am J Ther. Jan-Feb. 2007;14(1):30-40. Exclusion Code: X2. [pmid: 17303973].
294 Stebbins MR, Kaufman DJ, Lipton HL. The PRICE clinic for low-income elderly: a managed care model for implementing pharmacist-directed services. J Manag Care Pharm. May. 2005;11(4):333-41. Exclusion Code: X4. [pmid: 15871644].
295 Stefanacci RG, Haimowitz D. Medication management in assisted living. Geriatr Nurs. Jul-Aug. 2012;33(4):304 e1-12. Exclusion Code: X1. [pmid: 22841458].
296 Stell R, Bonollo M, Fiddes K, et al. Successful integration of a clinical pharmacist into a disease management unit. J Pharm Pract Res. 2008;38(Feb):132-6. Exclusion Code: X2.
297 Stemer G, Lemmens-Gruber R. Clinical pharmacy services and solid organ transplantation: a literature review. (Structured abstract). Pharm World Sci. 2010;(1):7-18. Exclusion Code: X2. [pmid: 20012363].
298 Stergachis A, Gardner JS, Anderson MT, et al. Improving pediatric asthma outcomes in the community setting: does pharmaceutical care make a difference?. J Am Pharm Assoc (Wash). Sep-Oct. 2002;42(5):743-52. Exclusion Code: X3. [pmid: 12269709].
299 Stewart S, Pearson S, Luke CG, et al. Effects of home-based intervention on unplanned readmissions and out-of-hospital deaths. (Structured abstract). J Am Geriatr Soc. 1998;(2):174-80. Exclusion Code: X2. [pmid: 9475445].
300 Stockl KM, Shin JS, Gong S, et al. Improving patient self-management of multiple sclerosis through a disease therapy management program. Am J Manag Care. Feb. 2010;16(2):139-44. Exclusion Code: X2. [pmid: 20148619].
301 Stockl KM, Tjioe D, Gong S, et al. Effect of an intervention to increase statin use in medicare members who qualified for a medication therapy management program. J Manag Care Pharm. Jul-Aug. 2008;14(6):532-40. Exclusion Code: X5. [pmid: 18693777].
302 Strand LM, Cipolle RJ, Morley PC, et al. The impact of pharmaceutical care practice on the practitioner and the patient in the ambulatory practice setting: twenty-five years of experience. Curr Pharm Des. 2004;10(31):3987-4001. Exclusion Code: X4. [pmid: 15579084].
303 Stratton TP, Cernohous T, Hager K, et al. College of pharmacy-based medication therapy management program for a university system. J Am Pharm Assoc (2003). Sep-Oct. 2012;52(5):653-60. Exclusion Code: X4. [pmid: 23023847].
304 Strom BL, Hennessy S. Pharmacist care and clinical outcomes for patients with reactive airways disease. JAMA. Oct. 2. 2002;288(13):1642-3. Exclusion Code: X1. [pmid: 12350196].
305 Summers KH. Medication therapy management versus drug regimen review. J Manag Care Pharm. Jan-Feb. 2007;13(1):68-9. Exclusion Code: X1. [pmid: 17269840].
306 Swims MP, Reed P. A pharmacotherapy clinic in a neurologic practice. J Pharm Tech. 2006;22(May):254-60. Exclusion Code: X4.
307 Tarn YH, Chou SF, Wang TY. Drug regimen review at nursing homes in Taiwan (CPS-O-013). Int Pharm Fed. 2002;62:78. Exclusion Code: X2.
308 Taylor J, Davies P. The medicines management needs of carers during an episode of mental health crisis. J Psychiatr Ment Health Nurs. Mar. 2012;19(2):190-2. Exclusion Code: X1. [pmid: 22070543].
309 Tett SE, Higgins GM, Armour CL. Impact of pharmacist interventions on medication management by the elderly: a review of the literature. Ann Pharmacother. Jan. 1993;27(1):80-6. Exclusion Code: X2. [pmid: 8431627].
310 Thomas MC. A Practical Approach to Medication Reconciliation by Pharmacists in a Community Hospital Emergency Department. 41. Exclusion Code: X1.
311 Thomas R, Kilbey C. Complex medicines management. Nurs Times. Mar. 1-7. 2011;107(8):20-2. Exclusion Code: X4. [pmid: 21667662].
312 Thompson CA. State-paid medication therapy management services succeed. Am J Health Syst Pharm. Mar. 15. 2008;65(6):490. 3. 8. Exclusion Code: X1. [pmid: 18319489].
313 Tinelli M, Bond C, Blenkinsopp A, et al. Patient evaluation of a community pharmacy medications management service. Ann Pharmacother. Dec. 2007;41(12):1962-70. Exclusion Code: X2. [pmid: 17971403].
314 Tinelli M, Ryan M, Bond C, et al. Valuing benefits to inform a clinical trial in pharmacy: do differences in utility measures at baseline affect the effectiveness of the intervention?. Pharmacoeconomics. Feb. 2013;31(2):163-71. Exclusion Code: X2. [pmid: 23329427].
315 Touchette DR. Improving adherence in the community and clinic pharmacy settings: an emerging opportunity. Pharmacotherapy. May. 2010;30(5):425-7. Exclusion Code: X1. [pmid: 20411993].
316 Trask SJ, Szabo SA. Polypharmacy intervention program in a tertiary care VA medical center. ASHP Midyear Clinical Meeting. 1991;26(Dec). P-R. Exclusion Code: X2.
317 Traynor K. Maryland School of Pharmacy, XLHealth team up on medication management project. Am J Health Syst Pharm. Jun. 1. 2010;67(11):868. 70. Exclusion Code: X1. [pmid: 20484207].
318 Triller DM, Hamilton RA. Effect of pharmaceutical care services on outcomes for home care patients with heart failure. Am J Health Syst Pharm. Nov. 1. 2007;64(21):2244-9. Exclusion Code: X7. [pmid: 17959576].
319 Truong AC. Evaluating the impact of a medication teaching clinic in a hospital based outpatient pharmacy. ASHP Midyear Clinical Meeting. 2006;41. Exclusion Code: X4.
320 Trygstad TK, Christensen D, Garmise J, et al. Pharmacist response to alerts generated from Medicaid pharmacy claims in a long-term care setting: results from the North Carolina polypharmacy initiative. J Manag Care Pharm. Sep. 2005;11(7):575-83. Exclusion Code: X2. [pmid: 16137215].
321 Trygstad TK, Christensen DB, Wegner SE, et al. Analysis of the North Carolina long-term care polypharmacy initiative: a multiple-cohort approach using propensity-score matching for both evaluation and targeting. Clin Ther. Sep. 2009;31(9):2018-37. Exclusion Code: X2. [pmid: 19843492].
322 Tsuyuki RT, Johnson JA, Teo KK, et al. A randomized trial of the effect of community pharmacist intervention on cholesterol risk management: the Study of Cardiovascular Risk Intervention by Pharmacists (SCRIP). Arch Intern Med. May. 27. 2002;162(10):1149-55. Exclusion Code: X2. [pmid: 12020186].
323 VanHaaren A. Pharmaceutical care in a multi-site medical group practice: reaching goals in the treatment of hyperlipidemia and diabetes. ASHP Midyear Clinical Meeting. 2006;41(Dec). Exclusion Code: X4.
324 Vinks TH, Egberts TC, de Lange TM, et al. Pharmacist-based medication review reduces potential drug-related problems in the elderly: the SMOG controlled trial. Drugs Aging. 2009;26(2):123-33. Exclusion Code: X2. [pmid: 19220069].
325 Viswanathan M, Golin CE, Jones CD, et al. Medication Adherence Interventions: Comparative Effectiveness. Closing the Quality Gap: Revisiting the State of the Science. Evidence Report No. 208. Rockville, MD. Agency for Healthcare Research and Quality. September. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm. Exclusion Code: X1.
326 Vuong T, Marriott JL, Kong DCM, et al. Implementation of a community liaison pharmacy service: a randomised controlled trial. Int J Pharm Pract. 2008;(3):127-35. Exclusion Code: X2.
327 Walberg SJ, Haight R. Discharge follow-up with a pharmacist study: Incorporating pharmacist-provided discharge education and medication reconciliation with an outpatient follow-up service for patients with psychiatric illness discharged to an outpatient day treatment program. J Pharm Pract. 2008;21(Jan):75-6. Exclusion Code: X4.
328 Walker S, Willey CW. Impact on drug costs and utilization of a clinical pharmacist in a multisite primary care medical group. J Manag Care Pharm. Jul-Aug. 2004;10(4):345-54. Exclusion Code: X2. [pmid: 15298532].
329 WALTON T, HOLLOWAY KP, KNAUSS MD. Pharmacist-managed anemia program in an outpatient hemodialysis population. Hosp Pharm. 2005;40(12):1051-6. Exclusion Code: X2.
330 Ward MA, Xu Y. Pharmacist-provided telephonic medication therapy management in an MAPD plan. Am J Manag Care. Oct. 2011;17(10):e399-409. Exclusion Code: X2. [pmid: 21999720].
331 Watkins JL, Landgraf A, Barnett CM, et al. Evaluation of pharmacist-provided medication therapy management services in an oncology ambulatory setting. J Am Pharm Assoc (2003). Mar-Apr. 2012;52(2):170-4. Exclusion Code: X4. [pmid: 22370379].
332 Weinberger M, Murray MD, Marrero DG, et al. Effectiveness of pharmacist care for patients with reactive airways disease: a randomized controlled trial. JAMA. Oct. 2. 2002;288(13):1594-602. Exclusion Code: X2. [pmid: 12350190].
333 Weinhandl ED, Arneson TJ, St Peter WL. Clinical outcomes associated with receipt of integrated pharmacy services by hemodialysis patients: a quality improvement report. Am J Kidney Dis. Sep. 2013;62(3):557-67. Exclusion Code: X2. [pmid: 23597860].
334 Wessell AM, Ornstein SM, Jenkins RG, et al. Medication Safety in Primary Care Practice: results from a PPRNet quality improvement intervention. Am J Med Qual. Jan-Feb. 2013;28(1):16-24. Exclusion Code: X2. [pmid: 22679129].
335 Westfall GR, Narducci WA. A community-pharmacy-based callback program for antibiotic therapy. J Am Pharm Assoc (Wash). May-Jun. 1997;NS37(3):330-4. Exclusion Code: X2. [pmid: 9170810].
336 While A. Making the most of good medicines management. Br J Community Nurs. Sep. 2007;12(9):434. Exclusion Code: X1. [pmid: 18026009].
337 White B, Truax D. The long and winding road. Arriving at safe medication management in LTC setting. Adv Nurse Pract. Sep. 2007;15(9):28-35. quiz -6. Exclusion Code: X1. [pmid: 19998897].
338 Wilk JE, West JC, Rae DS, et al. Medicare Part D prescription drug benefits and administrative burden in the care of dually eligible psychiatric patients. Psychiatr Serv. Jan. 2008;59(1):34-9. Exclusion Code: X2. [pmid: 18182537].
339 Williams A. Medicine management. Nurs Mirror. Oct. 3. 1984;159(12):i-iii. vi. Exclusion Code: X1. [pmid: 6567175].
340 Williams BR, Lopez S. Reaching the homebound elderly: the Prescription Intervention and Lifelong Learning (PILL) program. Home Health Care Serv Q. 2005;24(1-2):61-72. Exclusion Code: X4. [pmid: 16236659].
341 Williams T, Acton C, Hicks RW. Deploying med reconciliation. Nurs Manage. Apr. 2008;39(4):54-7. Exclusion Code: X1. [pmid: 18391828].
342 Williford SL, Johnson DF. Impact of pharmacist counseling on medication knowledge and compliance. Mil Med. Nov. 1995;160(11):561-4. Exclusion Code: X2. [pmid: 8538891].
343 Wilson J. Breaking down barriers. Am Pharm. 2005;127(Sep):24-6. Exclusion Code: X1.
344 Wolfe SC, Schirm V. Medication counseling for the elderly: effects on knowledge and compliance after hospital discharge. Geriatr Nurs. May-Jun. 1992;13(3):134-8. Exclusion Code: X2. [pmid: 1319935].
345 Wong E. CDTM and smoking cessation. Hosp Pharm. 1999;34(Nov):1295-303. Exclusion Code: X1.
346 Wong MC, Kong AP, So WY, et al. Pharmacoepidemiological profiles of oral hypoglycemic agents among 28,773 Chinese patients with diabetes. Diabetes Res Clin Pract. Jun. 2012;96(3):319-25. Exclusion Code: X2. [pmid: 22305941].
347 Wu JC, Chin M, Pitcher K, et al. Identifying hospitalization risk factors to prioritize medication therapy management enrollment. CA J Health-Sys Pharm. 22:19. Exclusion Code: X2.
348 Yamamura K, Osada T, Yano K, et al. Evaluation of pharmacist-managed anticoagulation classroom. ASHP Midyear Clinical Meeting. 2006;41(Dec). Exclusion Code: X2.
349 Yeoh TT, Si P, Chew L. The impact of medication therapy management in older oncology patients. Support Care Cancer. May. 2013;21(5):1287-93. Exclusion Code: X4. [pmid: 23179492].
350 Young D. Pharmaceutical case management helps Iowa Medicaid patients. Am J Health Syst Pharm. Mar. 1. 2003;60(5):414. 6. Exclusion Code: X1. [pmid: 12635443].
351 Zagaria MA. Medication therapy management services. US Pharmacist (USA). 2004;30(Apr):35-42. Exclusion Code: X1.
352 Zarowitz BJ, Stebelsky LA, Muma BK, et al. Reduction of high-risk polypharmacy drug combinations in patients in a managed care setting. Pharmacotherapy. Nov. 2005;25(11):1636-45. Exclusion Code: X4. [pmid: 16232025].
353 Zellmer WA. Collaborative drug therapy management. Am J Health Syst Pharm. Aug. 1. 1995;52(15):1732. Exclusion Code: X1. [pmid: 7583839].
354 Zermansky AG, Petty DR, Raynor DK, et al. Randomised controlled trial of clinical medication review by a pharmacist of elderly patients receiving repeat prescriptions in general practice. BMJ. Dec. 8. 2001;323(7325):1340-3. Exclusion Code: X2. [pmid: 11739221].
355 Zermansky AG, Petty DR, Raynor DK, et al. Clinical medication review by a pharmacist of patients on repeat prescriptions in general practice: a randomised controlled trial. Health Technol Assess. 2002;6(20):1-86. Exclusion Code: X2. [pmid: 12234455].
356 Zierler-Brown S, Coll RE, Llewellyn K. Implementation and evaluation of a pharmacist-managed ambulatory, indigent care practice, focused on cardiovascular disease (CVD) prevention and management. ASHP Midyear Clinical Meeting. 2005;40. P-R. Exclusion Code: X4.
357 Zillich AJ, Jaynes HA, Snyder ME, et al. Evaluation of specialized medication packaging combined with medication therapy management: adherence, outcomes, and costs among Medicaid patients. Med Care. Jun. 2012;50(6):485-93. Exclusion Code: X2. [pmid: 22498687].
358 Zillich AJ, Sutherland JM, Kumbera PA, et al. Hypertension outcomes through blood pressure monitoring and evaluation by pharmacists (HOME study). J Gen Intern Med. Dec. 2005;20(12):1091-6. Exclusion Code: X2. [pmid: 16423096].