# Abstract and Full-Text Review Form Templates

Abstract Review Form

Ref ID | Author | Year | Include or Exclude? (separate exclusion codes for publication type, PICOTS, and study design) | If ineligible, is manual review or hand search of full-text needed? | If ineligible, potential background reference? | NOTE: The following columns apply only to studies meeting our inclusion criteria | Study Design (RCT, NRCT, Other Study Design) | If “Other Study Design”, which specific design does it use? (Cohort, Case-Control, Nonconcurrent Time Series, Other – describe in Comments column) | Comments (e.g., if reviewer included an abstract due to a lack of clarity within the abstract)

Full-Text Review Form

Ref ID | First author's last name | Year | Study name (if applicable) | Include or Exclude? (separate exclusion codes for publication type, PICOTS, and study design) | Hand search references? (If so, marked with an “X”) | BKG? (If so, marked with an “X”) | Comments for INELIGIBLE studies (e.g., additional detail about exclusion reasons) | NOTE: The following columns apply only to studies meeting our inclusion criteria | Study Design (Dropdown list options: RCT, NRCT, Cohort, Case-Control) | KQ(s) (separate sub-columns for KQs 1, 2a, 2b, 2c, 3, 4, and 5, and relevant questions marked with an “X”) | Comments for ELIGIBLE studies (e.g., for reviewers to describe “Other” study designs)