# Literature Search Strategies

## Published Literature

### PubMed. Total of 1961 records retrieved; 1709 records imported after removing duplicates

PubMed Search Update 1-9-14

211 additional results; 49 imported

Search String | Search Terms | Number of Results
#1 | Search “Medication Therapy Management”[Mesh] | 610
#2 | Search “medication therapy management” | 795
#3 | Search “comprehensive medication review” | 22
#4 | Search “personal medication record” | 14
#5 | Search (“medication” AND “action plan”) | 152
#6 | Search “medication therapy review” | 11
#7 | Search “Medication Reconciliation”[Mesh] | 252
#8 | Search (med* AND reconciliation) | 335
#9 | Search “medication-related problems” | 218
#10 | Search MTMP | 34
#11 | Search prescriber intervention* | 243
#12 | Search “drug utilization management” | 6
#13 | Search “chronic care improvement” | 13
#14 | Search “drug therapy services” | 4
#15 | Search (“utilization management strategies” OR “utilization management strategy”) | 22
#16 | Search “optimized treatment outcomes” | 6
#17 | Search ((patient OR patients) AND “medication understanding”) | 12
#18 | Search (“drug therapy outcome” OR “drug therapy outcomes”) | 34
#19 | Search “medication counseling” | 133
#20 | Search “pharmaceutical case management” | 12
#21 | Search “drug therapy management” | 105
#22 | Search (“drug therapy problem” OR “drug therapy problems”) | 90
#23 | Search (“medicine management”[tiab] OR “medicines management”[tiab]) | 223
#25 | Search (#1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17 or #18 or #19 or #20 or #21 or #22 or #23) Filters: Humans | 2113
#26 | Search (#1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17 or #18 or #19 or #20 or #21 or #22 or #23) Filters: Humans; English | 1961
#27 | Search ((#1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17 or #18 or #19 or #20 or #21 or #22 or #23) AND (“retraction”[All Fields] OR “Retracted Publication”[pt])) Filters: Humans; English | 0
#28 | Search (#1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17 or #18 or #19 or #20 or #21 or #22 or #23) Filters: Publication date from 2012/11/04 to 2014/12/31; Humans; English | 211

PubMed Search Update 11-4-13

390 additional results; 236 imported

Search String | Search Terms | Number of Results
#1 | Search “Medication Therapy Management”[Mesh] | 579
#2 | Search “medication therapy management” | 765
#3 | Search “comprehensive medication review” | 22
#4 | Search “personal medication record” | 13
#5 | Search (“medication” AND “action plan”) | 149
#6 | Search “medication therapy review” | 11
#7 | Search “Medication Reconciliation”[Mesh] | 234
#8 | Search (med* AND reconciliation) | 326
#9 | Search “medication-related problems” | 215
#10 | Search MTMP | 34
#11 | Search prescriber intervention* | 242
#12 | Search “drug utilization management” | 6
#13 | Search “chronic care improvement” | 13
#14 | Search “drug therapy services” | 4
#15 | Search (“utilization management strategies” OR “utilization management strategy”) | 22
#16 | Search “optimized treatment outcomes” | 6
#17 | Search (patient OR patients) AND “medication understanding”) | 12
#18 | Search (“drug therapy outcome” OR “drug therapy outcomes”) | 33
#19 | Search “medication counseling” | 130
#20 | Search “pharmaceutical case management” | 12
#21 | Search “drug therapy management” | 105
#22 | Search (“drug therapy problem” OR “drug therapy problems”) | 88
#23 | Search (“medicine management”[tiab] OR “medicines management”[tiab]) | 218
#24 | Search (#1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17 or #18 or #19 or #20 or #21 or #22 or #23) | 2414
#25 | Search (#1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17 or #18 or #19 or #20 or #21 or #22 or #23) Filters: Humans | 2042
#26 | Search (#1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17 or #18 or #19 or #20 or #21 or #22 or #23) Filters: Humans; English | 1894
#27 | Search (#1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17 or #18 or #19 or #20 or #21 or #22 or #23) Filters: Publication date from 2012/02/27 to 2013/12/31; Humans; English | 390

PubMed search revision 6-27-13: added British terms for MTM to account for the MEDMAN study

149 additional results; all imported

Search String | Search Terms | Number of Results
#1 | Search “medicine management”[tiab] OR “medicines management”[tiab] Filters: Humans; English | 149

PubMed search revision 2-27-13: search re-run while keeping “wildcard” search terms

26 additional results; all imported

Search String | Search Terms | Number of Results
#1 | Search “Medication Therapy Management”[Mesh] | 475
#2 | Search “medication therapy management” | 622
#3 | Search “comprehensive medication review” | 18
#4 | Search “personal medication record” | 13
#5 | Search (“medication” AND “action plan”) | 139
#6 | Search “medication therapy review” | 10
#7 | Search “Medication Reconciliation”[Mesh] | 168
#8 | Search (med* AND reconciliation) | 27
#9 | Search “medication-related problems” | 197
#10 | Search MTMP | 31
#11 | Search prescriber intervention* | 223
#12 | Search “drug utilization management” | 5
#13 | Search “chronic care improvement” | 13
#14 | Search “drug therapy services” | 4
#15 | Search (“utilization management strategies” OR “utilization management strategy”) | 17
#16 | Search “optimized treatment outcomes” | 6
#17 | Search ((patient OR patients) AND “medication understanding”) | 12
#18 | Search (“drug therapy outcome” OR “drug therapy outcomes”) | 33
#19 | Search “medication counseling” | 122
#20 | Search “pharmaceutical case management” | 11
#21 | Search “drug therapy management” | 97
#22 | Search (“drug therapy problem” OR “drug therapy problems”) | 82
#23 | Search (#1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17 or #18 or #19 or #20 or #21 or #22) | 1694
#24 | Search #23 Filters: Humans | 1491
#25 | Search #23 Filters: Humans; English | 1387
#26 | Search (#25 AND (2012/10:2013/12[edat])) | 26

PubMed search revision 2-18-13: updated final PubMed/Medline “specific” MTM-and-MTM-components search conducted on 11/26/12 by using Entrez date limit of October 2012 to February 2013, which is the date each record was entered into PubMed, as opposed to limiting by publication date

17 additional results; all imported

Search String | Search Terms | Number of Results
#1 | Search “Medication Therapy Management”[Mesh] | 472
#2 | Search “medication therapy management” | 621
#3 | Search “comprehensive medication review” | 18
#4 | Search “personal medication record” | 13
#5 | Search (“medication” AND “action plan”) | 139
#6 | Search “medication therapy review” | 10
#7 | Search “Medication Reconciliation”[Mesh] | 162
#8 | Search (med* AND reconciliation) | 27
#9 | Search “medication-related problems” | 197
#10 | Search MTMP | 31
#11 | Search prescriber intervention* | 223
#12 | Search “drug utilization management” | 5
#13 | Search “chronic care improvement” | 13
#14 | Search “drug therapy services” | 4
#15 | Search (“utilization management strategies” OR “utilization management strategy”) | 17
#16 | Search “optimized treatment outcomes” | 6
#17 | Search ((patient OR patients) AND “medication understanding”) | 12
#18 | Search (“drug therapy outcome” OR “drug therapy outcomes”) | 33
#19 | Search “medication counseling” | 122
#20 | Search “pharmaceutical case management” | 11
#21 | Search “drug therapy management” | 97
#22 | Search (“drug therapy problem” OR “drug therapy problems”) | 82
#23 | Search (#1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17 or #18 or #19 or #20 or #21 or #22) | 1687
#24 | Search #23 Filters: Humans | 1476
#25 | Search #23 Filters: Humans; English | 1372
#26 | Search (#25 AND (2012/10:2013/02[edat])) | 17

PubMed primary search 11-26-12 – 1190 results, all imported

Search String | Search Terms | Number of Results
#1 | Search “Medication Therapy Management”[Mesh] | 433
#2 | Search “medication therapy management” | 582
#3 | Search “comprehensive medication review” | 17
#4 | Search “personal medication record” | 13
#5 | Search (“medication” AND “action plan”) | 134
#6 | Search “medication therapy review” | 10
#7 | Search “Medication Reconciliation”[Mesh] | 135
#8 | Search (med* AND reconciliation) | 27
#9 | Search “medication-related problems” | 193
#10 | Search MTMP | 31
#11 | Search prescriber intervention* | 217
#12 | Search “drug utilization management” | 5
#13 | Search “chronic care improvement” | 13
#14 | Search “drug therapy services” | 4
#15 | Search (“utilization management strategies” OR “utilization management strategy”) | 17
#16 | Search “optimized treatment outcomes” | 6
#17 | Search ((patient OR patients) AND “medication understanding”) | 9
#18 | Search (“drug therapy outcome” OR “drug therapy outcomes”) | 33
#19 | Search “medication counseling” | 120
#20 | Search “pharmaceutical case management” | 11
#21 | Search (#1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17 or #18 or #19 or #20) | 1473
#22 | Search (#1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17 or #18 or #19 or #20) Filters: Humans | 1280
#23 | Search (#1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17 or #18 or #19 or #20) Filters: Humans; English MTM terms and specific component terms. | 1190

### Cochrane Library. Total of 408 records retrieved; 299 imported after removing duplicates

Cochrane Library search update 1-10-2014 – 97 results, 9 imported

Search String | Search Terms | Number of Results
#1 | MeSH descriptor: [Medication Therapy Management] explode all trees | 31
#2 | “medication therapy management” | 43
#3 | “comprehensive medication review” | 4
#4 | “personal medication record” | 1
#5 | “medication” and “action plan” | 94
#6 | “medication therapy review” | 0
#7 | MeSH descriptor: [Medication Reconciliation] explode all trees | 18
#8 | “medication reconciliation” | 45
#9 | “medication-related problems” | 35
#10 | MTMP | 0
#11 | “prescriber intervention” or “prescriber interventions” | 0
#12 | “drug utilization management” | 0
#13 | “chronic care improvement” | 0
#14 | “drug therapy services” | 0
#15 | “utilization management strategies” or “utilization management strategy” | 0
#16 | “optimized treatment outcomes” | 0
#17 | (patient or patients) and “medication understanding” | 3
#18 | “drug therapy outcome” or “drug therapy outcomes” | 156
#19 | “medication counseling” | 21
#20 | “pharmaceutical case management” | 1
#21 | “drug therapy problem” or “drug therapy problems” | 16
#22 | “drug therapy management” | 10
#23 | (“medicine management”:ti or “medicine management”:ab or “medicines management”:ti or “medicines management”:ab) | 23
#24 | #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17 or #18 or #19 or #20 or #21 or #22 or #23 | 421
#25 | MeSH descriptor: [Congresses] explode all trees | 4
#26 | MeSH descriptor: [Congresses as Topic] explode all trees | 40
#27 | congresses:pt | 45
#28 | #25 or #26 or #27 | 85
#29 | #24 not #28 from 2012 to 2014 | 97

Cochrane search update 11-4-2013 – 84 results, 40 imported

Search String | Search Terms | Number of Results
#1 | MeSH descriptor: [Medication Therapy Management] explode all trees | 29
#2 | “medication therapy management” | 41
#3 | “comprehensive medication review” | 4
#4 | “personal medication record” | 1
#5 | “medication” and “action plan” | 92
#6 | “medication therapy review” | 0
#7 | MeSH descriptor: [Medication Reconciliation] explode all trees | 16
#8 | “medication reconciliation” | 42
#9 | “medication-related problems” | 35
#10 | MTMP | 0
#11 | “prescriber intervention” or “prescriber interventions” | 0
#12 | “drug utilization management” | 0
#13 | “chronic care improvement” | 0
#14 | “drug therapy services” | 0
#15 | “utilization management strategies” or “utilization management strategy” | 0
#16 | “optimized treatment outcomes” | 0
#17 | (patient or patients) and “medication understanding” | 3
#18 | “drug therapy outcome” or “drug therapy outcomes” | 152
#19 | “medication counseling” | 21
#20 | “pharmaceutical case management” | 1
#21 | “drug therapy problem” or “drug therapy problems” | 16
#22 | “drug therapy management” | 9
#23 | (“medicine management”:ti or “medicine management”:ab or “medicines management”:ti or “medicines management”:ab) | 23
#24 | #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17 or #18 or #19 or #20 or #21 or #22 or #23 | 410
#25 | MeSH descriptor: [Congresses] explode all trees | 4
#26 | MeSH descriptor: [Congresses as Topic] explode all trees | 40
#27 | congresses:pt | 45
#28 | #25 or #26 or #27 | 85
#29 | #24 not #28 | 410
#30 | #24 not #28 from 2012 to 2014 | 84

Cochrane Library search revision 6-27-13: added British terms for MTM to account for the MEDMAN study

21 additional results; all imported

Search String | Search Terms | Number of Results
#1 | “medicine management”:ti or “medicine management”:ab or “medicines management”:ti or “medicines management”:ab | 21

Cochrane Library search revision 2-27-13: search re-run while removing “wildcard” search terms and conference papers and abstracts

338 additional results; 337 imported

Search String | Search Terms | Number of Results
#1 | MeSH descriptor: [Medication Therapy Management] explode all trees | 19
#2 | “medication therapy management” | 30
#3 | “comprehensive medication review” | 3
#4 | “personal medication record” | 1
#5 | “medication” and “action plan” | 81
#6 | “medication therapy review” | 0
#7 | MeSH descriptor: [Medication Reconciliation] explode all trees | 5
#8 | “medication reconciliation” | 21
#9 | “medication-related problems” | 32
#10 | MTMP | 0
#11 | “prescriber intervention” or “prescriber interventions” | 0
#12 | “drug utilization management” | 0
#13 | “chronic care improvement” | 0
#14 | “drug therapy services” | 0
#15 | “utilization management strategies” or “utilization management strategy” | 0
#16 | “optimized treatment outcomes” | 0
#17 | (patient or patients) and “medication understanding” | 3
#18 | “drug therapy outcome” or “drug therapy outcomes” | 142
#19 | “medication counseling” | 19
#20 | “pharmaceutical case management” | 1
#21 | “drug therapy problem” or “drug therapy problems” | 16
#22 | “drug therapy management” | 8
#23 | #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17 or #18 or #19 or #20 or #21 or #22 | 338
#24 | MeSH descriptor: [Congresses] explode all trees | 4
#25 | MeSH descriptor: [Congresses as Topic] explode all trees | 38
#26 | congresses:pt | 45
#27 | #24 or #25 or #26 | 83
#28 | #23 not #27 | 338

Cochrane Library primary search 2-18-13: run concurrently with revised PubMed search, but eventually replaced with 2-27-13 search described above

534 additional results; 532 imported

Search String | Search Terms | Number of Results
#1 | MeSH descriptor: [Medication Therapy Management] explode all trees | 19
#2 | “medication therapy management” | 30
#3 | “comprehensive medication review” | 3
#4 | “personal medication record” | 1
#5 | “medication” and “action plan” | 81
#6 | “medication therapy review” | 0
#7 | MeSH descriptor: [Medication Reconciliation] explode all trees | 5
#8 | med* and reconciliation | 47
#9 | “medication-related problems” | 32
#10 | MTMP | 0
#11 | prescriber intervention* | 180
#12 | “drug utilization management” | 0
#13 | “chronic care improvement” | 0
#14 | “drug therapy services” | 0
#15 | “utilization management strategies” or “utilization management strategy” | 0
#16 | “optimized treatment outcomes” | 0
#17 | (patient or patients) and “medication understanding” | 3
#18 | “drug therapy outcome” or “drug therapy outcomes” | 142
#19 | “medication counseling” | 19
#20 | “pharmaceutical case management” | 1
#21 | “drug therapy problem” or “drug therapy problems” | 16
#22 | “drug therapy management” | 8
#23 | #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17 or #18 or #19 or #20 or #21 or #22 | 534

### International Pharmaceutical Abstracts (IPA): total of 756 records retrieved; 508 imported after removing duplicates

IPA search update 1-10-2014 – 63 results, 16 imported

Search String | Search Terms | Limiters/Expanders | Last Run Via | Number of Results
S24 | S23 | Limiters - Published Date: 20121101-20141231 Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 63
S23 | S22 | Limiters - Language: English; Articles about Human Studies Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 756
S22 | S1 OR S2 OR S3 OR S4 OR S5 OR S6 OR S7 OR S8 OR S9 OR S10 OR S11 OR S12 OR S13 OR S14 OR S15 OR S16 OR S17 OR S18 OR S19 OR S20 OR S21 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 1,665
S21 | TI ( “medicine management” OR “medicines management” ) AND AB ( “medicine management” OR “medicines management” ) | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 40
S20 | “drug therapy management” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 247
S19 | “drug therapy problem” OR “drug therapy problems” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 149
S18 | “pharmaceutical case management” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 14
S17 | “medication counseling” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 236
S16 | “drug therapy outcome” OR “drug therapy outcomes” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 73
S15 | (patient OR patients) AND “medication understanding” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 4
S14 | “optimized treatment outcomes” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 0
S13 | “utilization management strategies” OR “utilization management strategy” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 6
S12 | “drug therapy services” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 2
S11 | “chronic care improvement” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 3
S10 | “drug utilization management” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 17
S9 | “prescriber intervention” OR “prescriber interventions” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 4
S8 | MTMP | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 10
S7 | “medication-related problems” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 204
S6 | “medication reconciliation” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 367
S5 | “medication therapy review” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 10
S4 | “medication” AND “action plan” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 82
S3 | “personal medication record” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 12
S2 | “comprehensive medication review” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 15
S1 | “medication therapy management” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 315

IPA search update 11-4-13 – 105 results, 40 imported

Search String | Search Terms | Limiters/Expanders | Last Run Via | Number of Results
S24 | S23 | Limiters - Published Date: 20120201-20131231 Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 105
S23 | S22 | Limiters - Language: English; Articles about Human Studies Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 739
S22 | S1 OR S2 OR S3 OR S4 OR S5 OR S6 OR S7 OR S8 OR S9 OR S10 OR S11 OR S12 OR S13 OR S14 OR S15 OR S16 OR S17 OR S18 OR S19 OR S20 OR S21 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 1,648
S21 | TI ( “medicine management” OR “medicines management” ) AND AB ( “medicine management” OR “medicines management” ) | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 40
S20 | “drug therapy management” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 246
S19 | “drug therapy problem” OR “drug therapy problems” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 148
S18 | “pharmaceutical case management” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 14
S17 | “medication counseling” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 235
S16 | “drug therapy outcome” OR “drug therapy outcomes” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 73
S15 | (patient OR patients) AND “medication understanding” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 4
S14 | “optimized treatment outcomes” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 0
S13 | “utilization management strategies” OR “utilization management strategy” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 5
S12 | “drug therapy services” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 2
S11 | “chronic care improvement” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 3
S10 | “drug utilization management” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 17
S9 | “prescriber intervention” OR “prescriber interventions” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 4
S8 | MTMP | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 10
S7 | “medication-related problems” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 202
S6 | “medication reconciliation” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 364
S5 | “medication therapy review” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 10
S4 | “medication” AND “action plan” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 81
S3 | “personal medication record” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 12
S2 | “comprehensive medication review” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 14
S1 | “medication therapy management” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 308

IPA search revision 6-27-13: added British terms for MTM to account for the MEDMAN study

19 additional results; 18 imported

Search String | Search Terms | Limiters/Expanders | Last Run Via | Number of Results
S1 | TI ( “medicine management” OR “medicines management” ) AND AB ( “medicine management” OR “medicines management” ) | Limiters - Language: English; Articles about Human Studies Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 19

IPA search revision 2-27-13: search re-run while removing “wildcard” search terms

673 additional results; 666 imported

Search String | Search Terms | Limiters/Expanders | Last Run Via | Number of Results
S22 | S21 | Limiters - Language: English; Articles about Human Studies Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 673
S21 | S1 OR S2 OR S3 OR S4 OR S5 OR S6 OR S7 OR S8 OR S9 OR S10 OR S11 OR S12 OR S13 OR S14 OR S15 OR S16 OR S17 OR S18 OR S19 OR S20 | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 1,558
S20 | “drug therapy management” | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 243
S19 | “drug therapy problem” OR “drug therapy problems” | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 145
S18 | “pharmaceutical case management” | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 14
S17 | “medication counseling” | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 232
S16 | “drug therapy outcome” OR “drug therapy outcomes” | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 72
S15 | (patient OR patients) AND “medication understanding” | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 4
S14 | “optimized treatment outcomes” | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 0
S13 | “utilization management strategies” OR “utilization management strategy” | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 4
S12 | “drug therapy services” | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 2
S11 | “chronic care improvement” | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 3
S10 | “drug utilization management” | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 16
S9 | “prescriber intervention” OR “prescriber interventions” | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 4
S8 | MTMP | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 10
S7 | “medication-related problems” | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 199
S6 | “medication reconciliation” | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 341
S5 | “medication therapy review” | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 10
S4 | “medication” AND “action plan” | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 80
S3 | “personal medication record” | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 12
S2 | “comprehensive medication review” | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 12
S1 | “medication therapy management” | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 289

IPA primary search 2-18-13: run concurrently with revised PubMed search, but eventually replaced with 2-27-13 search described above

739 additional results; 679 imported

Search String | Search Terms | Limiters/Expanders | Number of Results
S23 | S1 OR S2 OR S3 OR S4 OR S5 OR S6 OR S7 OR S8 OR S9 OR S10 OR S11 OR S12 OR S13 OR S14 OR S15 OR S16 OR S17 OR S18 OR S19 OR S20 OR S21 | Limiters - Language: English; Articles about Human Studies Search modes - Boolean/Phrase | 739
S22 | S1 OR S2 OR S3 OR S4 OR S5 OR S6 OR S7 OR S8 OR S9 OR S10 OR S11 OR S12 OR S13 OR S14 OR S15 OR S16 OR S17 OR S18 OR S19 OR S20 OR S21 | Search modes - Boolean/Phrase | 1,803
S21 | “drug therapy management” | Search modes - Boolean/Phrase | 243
S20 | “drug therapy problem” OR “drug therapy problems” | Search modes - Boolean/Phrase | 145
S19 | “pharmaceutical case management” | Search modes - Boolean/Phrase | 14
S18 | “medication counseling” | Search modes - Boolean/Phrase | 232
S17 | “drug therapy outcome” OR “drug therapy outcomes” | Search modes - Boolean/Phrase | 72
S16 | (patient OR patients) AND “medication understanding” | Search modes - Boolean/Phrase | 4
S15 | “optimized treatment outcomes” | Search modes - Boolean/Phrase | 0
S14 | “utilization management strategies” OR “utilization management strategy” | Search modes - Boolean/Phrase | 4
S13 | “drug therapy services” | Search modes - Boolean/Phrase | 2
S12 | “chronic care improvement” | Search modes - Boolean/Phrase | 3
S11 | “drug utilization management” | Search modes - Boolean/Phrase | 16
S10 | prescriber intervention* | Search modes - Boolean/Phrase | 95
S9 | MTMP | Search modes - Boolean/Phrase | 10
S8 | “medication-related problems” | Search modes - Boolean/Phrase | 199
S7 | med* AND reconciliation | Search modes - Boolean/Phrase | 508
S6 | “medication reconciliation” | Search modes - Boolean/Phrase | 341
S5 | “medication therapy review” | Search modes - Boolean/Phrase | 10
S4 | “medication” AND “action plan” | Search modes - Boolean/Phrase | 80
S3 | “personal medication record” | Search modes - Boolean/Phrase | 12
S2 | “comprehensive medication review” | Search modes - Boolean/Phrase | 12
S1 | “medication therapy management” | Search modes - Boolean/Phrase | 289

## Gray Literature

Search update 11-4-13

Source | Search Terms | Limits or Adjustments | Number of Results Retrieved (Imported)
ClinicalTrials.gov Expert Search Strategy | ( “medication therapy management” OR “comprehensive medication review” OR “Medication Reconciliation” OR “pharmaceutical case management” OR “drug therapy management” OR “drug therapy problem” OR “drug therapy problems” OR “medicine management” OR “medicines management” ) | [ALL-FIELDS] AND ( NOT NOTEXT ) [FIRST-RECEIVED-RESULTS-DATE] AND ( “03/04/2013” : “11/04/2013” ) [FIRST-RECEIVED-DATE] | 5 (5)
WHO ICTRP | [underlined: Title search]: “medication therapy management” OR “comprehensive medication review” OR “Medication Reconciliation” OR “pharmaceutical case management” OR “drug therapy management” OR “drug therapy problem” OR “drug therapy problems” OR “medicine management” OR “medicines management” [underlined: Intervention search]: “medication therapy management” | Registered from 3/4/2013 to 11/4/13 | 5 (5) (Title search); 2 (1) (Intervention search)
HSRProj Advanced search | “medication therapy management” OR “comprehensive medication review” OR “personal medication record” OR (medication AND “action plan”) OR “medication therapy review” OR “Medication Reconciliation” OR “medication-related problems” OR “prescriber intervention” OR “drug utilization management” OR “chronic care improvement” OR “drug therapy services” OR “utilization management strategies” OR “utilization management strategy” OR “optimized treatment outcomes” OR ((patients OR patient) AND “medication understanding”) OR “drug therapy outcome” OR “drug therapy outcomes” OR “medication counseling” OR “pharmaceutical case management” OR “drug therapy management” OR “drug therapy problem” OR “drug therapy problems” OR “medicine management” OR “medicines management” [Limited to Ongoing/Completed status] | Initial Year Range = 2011 – 2013 | 18 (7)
DOPHER (Database of Promoting Health Effectiveness Reviews) | medication therapy management OR comprehensive medication review OR personal medication record OR (medication AND action plan) OR medication therapy review OR Medication Reconciliation OR medication-related problems OR medication relation problems OR prescriber intervention OR drug utilization management OR chronic care improvement OR drug therapy services OR utilization management strategies OR utilization management strategy OR optimized treatment outcomes OR (patients OR patient) AND medication understanding) OR drug therapy outcome OR drug therapy outcomes OR medication counseling OR pharmaceutical case management OR drug therapy management OR drug therapy problem OR drug therapy problems 2) “MTM” or “Medication Therapy Management” | None | 0
New York Academy of Medicine Gray Literature Report (greylit.org) | 1) medication therapy management OR comprehensive medication review OR personal medication record OR (medication AND action plan) OR medication therapy review OR Medication Reconciliation OR medication-related problems OR medication relation problems OR prescriber intervention OR drug utilization management OR chronic care improvement OR drug therapy services OR utilization management strategies OR utilization management strategy OR optimized treatment outcomes OR (patients OR patient) AND medication understanding) OR drug therapy outcome OR drug therapy outcomes OR medication counseling OR pharmaceutical case management OR drug therapy management OR drug therapy problem OR drug therapy problems 2) “MTM” or “Medication Therapy Management” | Published from 2012-2013 | 0 for search string #1; 1 (0) for search string #2
CMS.gov | 1) allintitle: “medication therapy management” site:cms.gov | “allintitle”, which limited results to those in which “medication therapy management” appeared in title of retrieved websites | 82 (82) total: 82 through CMS.gov directly; 6 indirectly through Google

Search revision 6-28-13: added British terms (“medicine management” OR “medicines management”) for MTM to account for the MEDMAN study

Total of 14 records retrived, 13 imported after initial screening.

Source | Search Terms | Limits or Adjustments | Number of Results Retrieved (Imported)
ClinicalTrials.gov Expert Search Strategy | “medicine management” OR “medicines management” | [ALL-FIELDS] AND ( NOT NOTEXT ) [FIRST-RECEIVED-RESULTS-DATE] | 2 (2)
WHO ICTRP | “medicine management” OR “medicines management” | None | 10 (10)
HSRProj Advanced search | “medicine management” OR “medicines management” | None | 0
NIH RePORTER Advanced search | “medicine management” OR “medicines management” | None | 0
DOPHER (Database of Promoting Health Effectiveness Reviews) | “medicine management” OR “medicines management” | None | 0
New York Academy of Medicine Gray Literature Report (greylit.org) | “medicine management” OR “medicines management” | None | 0
CMS.gov | “medicine management” OR “medicines management” | “allintitle”, which limited results to those in which “medication therapy management” appeared in title of retrieved websites | 2 (1)

Primary searches 3-4-13: 750 records retrieved, 596 imported after removing duplicates

Source | Search Terms | Limits or Adjustments | Number of Results Retrieved (Imported)
ClinicalTrials.gov Expert Search Strategy | ( “medication therapy management” OR “comprehensive medication review” OR “Medication Reconciliation” OR “pharmaceutical case management” OR “drug therapy management” OR “drug therapy problem” OR “drug therapy problems” ) | [ALL-FIELDS] AND ( NOT NOTEXT ) [FIRST-RECEIVED-RESULTS-DATE] | 119 (119)
WHO ICTRP | [underlined: Title search]: medication therapy management OR comprehensive medication review OR Medication Reconciliation OR pharmaceutical case management OR drug therapy management OR drug therapy problem OR drug therapy problems [underlined: Intervention search]: was either 41,000+, with the shorter search (see Search Strings #1c and #1d), or no results for “medication therapy management” by itself. | None | 5 (5) (Title search); 0 (Intervention search)
HSRProj Advanced search | “medication therapy management” OR “comprehensive medication review” OR “personal medication record” OR (medication AND “action plan”) OR “medication therapy review” OR “Medication Reconciliation” OR “medication-related problems” OR “prescriber intervention” OR “drug utilization management” OR “chronic care improvement” OR “drug therapy services” OR “utilization management strategies” OR “utilization management strategy” OR “optimized treatment outcomes” OR ((patients OR patient) AND “medication understanding”) OR “drug therapy outcome” OR “drug therapy outcomes” OR “medication counseling” OR “pharmaceutical case management” OR “drug therapy management” OR “drug therapy problem” OR “drug therapy problems” [Limited to Ongoing/Completed status] | None | 87 (82)
NIH RePORTER Advanced search | medication therapy management OR comprehensive medication review OR personal medication record OR (medication AND action plan) OR medication therapy review OR Medication Reconciliation OR medication-related problems OR medication relation problems OR prescriber intervention OR drug utilization management OR chronic care improvement OR drug therapy services OR utilization management strategies OR utilization management strategy OR optimized treatment outcomes OR (patients OR patient) AND medication understanding) OR drug therapy outcome OR drug therapy outcomes OR medication counseling OR pharmaceutical case management OR drug therapy management OR drug therapy problem OR drug therapy problems | None | 234 (85)
DOPHER (Database of Promoting Health Effectiveness Reviews) | 1) medication therapy management OR comprehensive medication review OR personal medication record OR (medication AND action plan) OR medication therapy review OR Medication Reconciliation OR medication-related problems OR medication relation problems OR prescriber intervention OR drug utilization management OR chronic care improvement OR drug therapy services OR utilization management strategies OR utilization management strategy OR optimized treatment outcomes OR (patients OR patient) AND medication understanding) OR drug therapy outcome OR drug therapy outcomes OR medication counseling OR pharmaceutical case management OR drug therapy management OR drug therapy problem OR drug therapy problems 2) “MTM” or “Medication Therapy Management” | None | 0 for all search strings
New York Academy of Medicine Gray Literature Report (greylit.org) | 1) medication therapy management OR comprehensive medication review OR personal medication record OR (medication AND action plan) OR medication therapy review OR Medication Reconciliation OR medication-related problems OR medication relation problems OR prescriber intervention OR drug utilization management OR chronic care improvement OR drug therapy services OR utilization management strategies OR utilization management strategy OR optimized treatment outcomes OR (patients OR patient) AND medication understanding) OR drug therapy outcome OR drug therapy outcomes OR medication counseling OR pharmaceutical case management OR drug therapy management OR drug therapy problem OR drug therapy problems 2) “MTM” or “Medication Therapy Management” | None | 0 for search string #1; 1 (1) for search string #2
CMS.gov | 1) “medication therapy management” OR “comprehensive medication review” OR “personal medication record” OR (medication AND “action plan”) OR “medication therapy review” OR “Medication Reconciliation” OR “medication-related problems” OR “prescriber intervention” OR “drug utilization management” OR “chronic care improvement” OR “drug therapy services” OR “utilization management strategies” OR “utilization management strategy” OR “optimized treatment outcomes” OR ((patients OR patient) AND “medication understanding”) OR “drug therapy outcome” OR “drug therapy outcomes” OR “medication counseling” OR “pharmaceutical case management” OR “drug therapy management” OR “drug therapy problem” OR “drug therapy problems” 2) allintitle: “medication therapy management” site:cms.gov | “allintitle”, which limited results to those in which “medication therapy management” appeared in title of retrieved websites | 304 (304) total: 295 through CMS.gov directly; 9 indirectly through Google