# References

1 Manning-Courtney P, Murray D, Currans K, et al. Autism spectrum disorders. Curr Probl Pediatr Adolesc Health Care. Jan. 2013;43(1):2-11. [pmid: 23332397].
2 Ozonoff S, Goodlin-Jones BL, Solomon M. Evidence-based assessment of autism spectrum disorders in children and adolescents. J Clin Child Adolesc Psychol. Sep. 2005;34(3):523-40. [pmid: 16083393].
3 American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders. Fifth ed. Washington DC. American Psychiatric Association. 2013.
4 Zwaigenbaum L, Bryson S, Lord C, et al. Clinical assessment and management of toddlers with suspected autism spectrum disorder: insights from studies of high-risk infants. Pediatrics. May. 2009;123(5):1383-91. [pmid: 19403506].
5 Myers SM, Johnson CP. Management of children with autism spectrum disorders. Pediatrics. Nov. 2007;120(5):1162-82. [pmid: 17967921].
6 Myers SM. The status of pharmacotherapy for autism spectrum disorders. Expert Opin Pharmacother. Aug. 2007;8(11):1579-603. [pmid: 17685878].
7 Developmental Disabilities Monitoring Network Surveillance Year Principal I. Prevalence of autism spectrum disorder among children aged 8 years - autism and developmental disabilities monitoring network, 11 sites, United States, 2010. MMWR Surveill Summ. Mar. 28. Suppl 2. 2014;63:1-21. [pmid: 24670961].
8 Fecteau S, Mottron L, Berthiaume C, et al. Developmental changes of autistic symptoms. Autism. Sep. 2003;7(3):255-68. [pmid: 14516059].
9 Shattuck PT, Seltzer MM, Greenberg JS, et al. Change in autism symptoms and maladaptive behaviors in adolescents and adults with an autism spectrum disorder. J Autism Dev Disord. Oct. 2007;37(9):1735-47. [pmid: 17146700].
10 McGovern CW, Sigman M. Continuity and change from early childhood to adolescence in autism. J Child Psychol Psychiatry. Apr. 2005;46(4):401-8. [pmid: 15819649].
11 Seltzer MM, Shattuck P, Abbeduto L, et al. Trajectory of development in adolescents and adults with autism. Ment Retard Dev Disabil Res Rev. 2004;10(4):234-47. [pmid: 15666341].
12 Ballaban-Gil K, Rapin I, Tuchman R, et al. Longitudinal examination of the behavioral, language, and social changes in a population of adolescents and young adults with autistic disorder. Pediatr Neurol. Oct. 1996;15(3):217-23. [pmid: 8916159].
13 Billstedt E, Gillberg C, Gillberg C. Autism after Adolescence: Population-Based 13- to 22-Year Follow-Up Study of 120 Individuals with Autism Diagnosed in Childhood. J Autism Dev Disord. Jun. 2005;35(3):351-60. [pmid: 16119476].
14 Eaves LC, Ho HH. Young Adult Outcome of Autism Spectrum Disorders. J Autism Dev Disord. Apr. 2008;38(4):739-47. [pmid: 17764027].
15 Howlin P, Goode S, Hutton J, et al. Adult outcome for children with autism. J Child Psychol Psychiatry. Feb. 2004;45(2):212-29. [pmid: 14982237].
16 Taylor JL, Seltzer MM. Employment and post-secondary educational activities for young adults with autism spectrum disorders during the transition to adulthood. J Autism Dev Disord. May. 2011;41(5):566-74. [pmid: 20640591].
17 Ganz ML. The lifetime distribution of the incremental societal costs of autism. Arch Pediatr Adolesc Med. Apr. 2007;161(4):343-9. [pmid: 17404130].
18 Folstein SE, Rosen-Sheidley B. Genetics of autism: complex aetiology for a heterogeneous disorder. Nat Rev Genet. Dec. 2001;2(12):943-55. [pmid: 11733747].
19 Bailey A, Le Couteur A, Gottesman I, et al. Autism as a strongly genetic disorder: evidence from a British twin study. Psychol Med. Jan. 1995;25(1):63-77. [pmid: 7792363].
20 Marshall CR, Scherer SW. Detection and characterization of copy number variation in autism spectrum disorder. Methods Mol Biol. 2012;838:115-35. [pmid: 22228009].
21 Geschwind DH. Genetics of autism spectrum disorders. Trends Cogn Sci. Sep. 2011;15(9):409-16. [pmid: 21855394].
22 Hallmayer J, Cleveland S, Torres A, et al. Genetic heritability and shared environmental factors among twin pairs with autism. Arch Gen Psychiatry. Nov. 2011;68(11):1095-102. [pmid: 21727249].
23 Bristol MM, Cohen DJ, Costello EJ, et al. State of the science in autism: report to the National Institutes Health. J Autism Dev Disord. Apr. 1996;26(2):121-54. [pmid: 8744475].
24 Krakowiak P, Walker CK, Bremer AA, et al. Maternal metabolic conditions and risk for autism and other neurodevelopmental disorders. Pediatrics. May. 2012;129(5):e1121-8. [pmid: 22492772].
25 Dodds L, Fell DB, Shea S, et al. The role of prenatal, obstetric and neonatal factors in the development of autism. J Autism Dev Disord. Jul. 2011;41(7):891-902. [pmid: 20922473].
26 Sandin S, Hultman CM, Kolevzon A, et al. Advancing maternal age is associated with increasing risk for autism: a review and meta-analysis. J Am Acad Child Adolesc Psychiatry. May. 2012;51(5):477-86 e1. [pmid: 22525954].
27 Shelton JF, Tancredi DJ, Hertz-Picciotto I. Independent and dependent contributions of advanced maternal and paternal ages to autism risk. Autism Res. Feb. 2010;3(1):30-9. [pmid: 20143326].
28 Bhandari A, Sandlow JI, Brannigan RE. Risks to offspring associated with advanced paternal age. J Androl. Mar-Apr. 2011;32(2):121-2. [pmid: 20467047].
29 Cheslack-Postava K, Liu K, Bearman PS. Closely spaced pregnancies are associated with increased odds of autism in California sibling births. Pediatrics. Feb. 2011;127(2):246-53. [pmid: 21220394].
30 Gunnes N, Suren P, Bresnahan M, et al. Interpregnancy interval and risk of autistic disorder. Epidemiology. Nov. 2013;24(6):906-12. [pmid: 24045716].
31 Shelton JF, Hertz-Picciotto I, Pessah IN. Tipping the balance of autism risk: potential mechanisms linking pesticides and autism. Environ Health Perspect. Jul. 2012;120(7):944-51. [pmid: 22534084].
32 Schultz ST. Does thimerosal or other mercury exposure increase the risk for autism? A review of current literature. Acta Neurobiol Exp (Wars). 2010;70(2):187-95. [pmid: 20628442].
33 Ozonoff S, Young GS, Carter A, et al. Recurrence risk for autism spectrum disorders: a Baby Siblings Research Consortium study. Pediatrics. Sep. 2011;128(3):e488-95. [pmid: 21844053].
34 Gronborg TK, Schendel DE, Parner ET. Recurrence of autism spectrum disorders in full- and half-siblings and trends over time: a population-based cohort study. JAMA Pediatr. Oct. 2013;167(10):947-53. [pmid: 23959427].
35 Seida JK, Ospina MB, Karkhaneh M, et al. Systematic reviews of psychosocial interventions for autism: an umbrella review. Dev Med Child Neurol. Feb. 2009;51(2):95-104. [pmid: 19191842].
36 Ospina MB, Krebs Seida J, Clark B, et al. Behavioural and developmental interventions for autism spectrum disorder: a clinical systematic review. PLoS One. 2008;3(11):e3755. [pmid: 19015734].
37 Parr J. Autism. Clin Evid (Online). 2008. [pmid: 19450315].
38 National Standards Report National Autism Center. Randolph, MA. National Autism Center. 2009. Available at: http://www.nationalautismcenter.org/pdf/NAC%20Standards%20Report.pdf.
39 Warren Z, Veenstra-VanderWeele J, Stone W, Bruzek JL, Nahmias AS, Foss-Feig JH, Jerome RN, Krishnaswami S, Sathe NA, Glasser AM, Surawicz T, McPheeters ML. Therapies for Children With Autism Spectrum Disorders. Comparative Effectiveness Review No. 26 (Prepared by the Vanderbilt Evidence-based Practice Center under Contract No. 290-2007-10065-I.). AHRQ Publication No. 11-EHC029-EF. Rockville, MD. Agency for Healthcare Research and Quality. April. 2011. Available at: www.effectivehealthcare.ahrq.gov/reports/final.cfm.
40 Committee on Educational Interventions for Children with Autism Educating Children with Autism. Washington DC. National Academies Press. 2001. Available at: http://www.nap.edu/openbook.php?record_id=10017&page=R2.
41 Lovaas OI. Behavioral treatment and normal educational and intellectual functioning in young autistic children. J Consult Clin Psychol. Feb. 1987;55(1):3-9. [pmid: 3571656].
42 Bryson SE, Rogers SJ, Fombonne E. Autism spectrum disorders: early detection, intervention, education, and psychopharmacological management. Can J Psychiatry. Sep. 2003;48(8):506-16. [pmid: 14574826].
43 Rogers SJ, Vismara LA. Evidence-Based Comprehensive Treatments for Early Autism. Journal of Clinical Child and Adolescent Psychology. Jan. 2008;37(1):8-38. [pmid: 18444052].
44 Reichow B, Wolery M. Comprehensive Synthesis of Early Intensive Behavioral Interventions for Young Children with Autism Based on the UCLA Young Autism Project Model. J Autism Dev Disord. Jan. 2009;39(1):23-41. [pmid: 18535894].
45 Reichow B, Barton EE, Boyd BA, et al. Early intensive behavioral intervention (EIBI) for young children with autism spectrum disorders (ASD). Cochrane Database Syst Rev. 2012;10:CD009260. [pmid: 23076956].
46 Warren Z, McPheeters ML, Sathe N, et al. A systematic review of early intensive intervention for autism spectrum disorders. Pediatrics. May. 2011;127(5):e1303-11. [pmid: 21464190].
47 Spreckley M, Boyd R. Efficacy of Applied Behavioral Intervention in Preschool Children with Autism for Improving Cognitive, Language, and Adaptive Behavior: A Systematic Review and Meta-analysis. J Pediatr. 2008. Oct. 22. [pmid: 18950798].
48 McConachie H, Diggle T. Parent implemented early intervention for young children with autism spectrum disorder: a systematic review. J Eval Clin Pract. Feb. 2007;13(1):120-9. [pmid: 17286734].
49 Eldevik S, Hastings RP, Hughes JC, et al. Meta-analysis of Early Intensive Behavioral Intervention for children with autism. J Clin Child Adolesc Psychol. May. 2009;38(3):439-50. [pmid: 19437303].
50 Howlin P, Magiati I, Charman T. Systematic Review of Early Intensive Behavioral Interventions for Children with Autism. American Journal on Intellectual and Developmental Disabilities. Jan. 2009;114(1):23-41. [pmid: 19143460].
51 Makrygianni MK, Reed P. A Meta-Analytic Review of the Effectiveness of Behavioural Early Intervention Programs for Children with Autistic Spectrum Disorders. 2010;4:577-93.
52 Virues-Ortega J. Applied behavior analytic intervention for autism in early childhood: meta-analysis, meta-regression and dose-response meta-analysis of multiple outcomes. Clin Psychol Rev. Jun. 2010;30(4):387-99. 44.44. Reichow B, Wolery M. Comprehensive Synthesis of Early Intensive Behavioral Interventions for Young Children with Autism Based on the UCLA Young Autism Project Model. J Autism Dev Disord 2009 Jan;39(1):23-41. [pmid: 20223569].
53 Horner RH CE, Halle J, McGee G, Odom S, Wolery M. The use of single subject research to identify evidence-based practice in special education. Except Child. 2005;71:165-79.
54 Chou R, Aronson N, Atkins D, et al. AHRQ series paper 4: assessing harms when comparing medical interventions: AHRQ and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):502-12. [pmid: 18823754].
55 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. January. 2014. Chapters available at: www.effectivehealthcare.ahrq.gov.
56 Berkman ND, Lohr KN, Ansari M, McDonagh M, Balk E, Whitlock E, Reston J, Bass E, Butler M, Gartlehner G, Hartling L, Kane R, McPheeters M, Morgan L, Morton SC, Viswanathan M, Sista P, Chang S. Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality An Update. Methods Guide for Comparative Effectiveness Reviews (Prepared by the RTI -UNC Evidence-based Practice Center under Contract No. 290-2007-10056-I). AHRQ Publication No. 13(4)-EHC130-EF. Rockville, MD. Agency for Healthcare Research and Quality. November. 2013. Available at: www.effectivehealthcare.ahrq.gov/reports/final.cfm.
57 Smith T, Groen AD, Wynn JW. Randomized trial of intensive early intervention for children with pervasive developmental disorder. Am J Ment Retard. Jul. 2000;105(4):269-85. [pmid: 10934569].
58 Eldevik S, Eikeseth S, Jahr E, et al. Effects of low-intensity behavioral treatment for children with autism and mental retardation. J Autism Dev Disord. Feb. 2006;36(2):211-24. [pmid: 16477514].
59 Farrell P, Trigonaki N, Webster D. An exploratory evaluation of two early intervention programmes for young children with autism. Educational and Child Psychology. 2005;22(4):29-40.
60 Cohen H, Amerine-Dickens M, Smith T. Early intensive behavioral treatment: replication of the UCLA model in a community setting. J Dev Behav Pediatr. Apr. 2006;27(2 Suppl):S145-55. [pmid: 16685181].
61 Howard JS, Sparkman CR, Cohen HG, et al. A comparison of intensive behavior analytic and eclectic treatments for young children with autism. Res Dev Disabil. Jul-Aug. 2005;26(4):359-83. [pmid: 15766629].
62 Zachor DA, Ben-Itzchak E, Rabinovich A-L, et al. Change in Autism Core Symptoms with Early Intervention: predictors and outcomes. Research in Autism Spectrum Disorders. 2009;3:967-76.
63 Zachor DA, Ben-Itzchak E, Rabinovich A-L, et al. Change in autism core symptoms with intervention. Research in Autism Spectrum Disorders. 2007;1(4):304-17.
64 Reed P, Osborne LA, Corness M. Brief report: relative effectiveness of different home-based behavioral approaches to early teaching intervention. J Autism Dev Disord. Oct. 2007;37(9):1815-21. [pmid: 17180714].
65 Eikeseth S, Smith T, Jahr E, et al. Intensive behavioral treatment at school for 4- to 7-year-old children with autism. A 1-year comparison controlled study. Behav Modif. Jan. 2002;26(1):49-68. [pmid: 11799654].
66 Eikeseth S, Smith T, Jahr E, et al. Outcome for children with autism who began intensive behavioral treatment between ages 4 and 7: a comparison controlled study. Behav Modif. May. 2007;31(3):264-78. [pmid: 17438342].
67 Hayward D, Eikeseth S, Gale C, et al. Assessing progress during treatment for young children with autism receiving intensive behavioural interventions. Autism. Nov. 2009;13(6):613-33. [pmid: 19933766].
68 Eikeseth S, Hayward D, Gale C, et al. Intensity of Supervision and Outcome for Preschool Aged Children Receiving Early and Intensive Behavioral Interventions: A Preliminary Study. Research in Autism Spectrum Disorders. Jan. 2009;3(1):67-73.
69 Drew A, Baird G, Baron-Cohen S, et al. A pilot randomised control trial of a parent training intervention for pre-school children with autism. Preliminary findings and methodological challenges. Eur Child Adolesc Psychiatry. Dec. 2002;11(6):266-72. [pmid: 12541005].
70 Stahmer AC, Gist K. The effects of an accelerated parent education program on technique mastery and child outcome. Journal of Positive Behavior Interventions. Spr. 2001;3(2):75-82.
71 Green J, Charman T, McConachie H, et al. Parent-mediated communication-focused treatment in children with autism (PACT): a randomised controlled trial. Lancet. 2010. May. 20.
72 Aldred C, Green J, Adams C. A new social communication intervention for children with autism: pilot randomised controlled treatment study suggesting effectiveness. J Child Psychol Psychiatry. Nov. 2004;45(8):1420-30. [pmid: 15482502].
73 Dawson G, Rogers S, Munson J, et al. Randomized, Controlled Trial of an Intervention for Toddlers With Autism: The Early Start Denver Model. Pediatrics. 2010. January. 2010.
74 McConachie H, Randle V, Hammal D, et al. A controlled trial of a training course for parents of children with suspected autism spectrum disorder. J Pediatr. Sep. 2005;147(3):335-40. [pmid: 16182672].
75 Sallows GO, Graupner TD. Intensive behavioral treatment for children with autism: four-year outcome and predictors. Am J Ment Retard. Nov. 2005;110(6):417-38. [pmid: 16212446].
76 Peters-Scheffer N, Didden R, Mulders M, et al. Low intensity behavioral treatment supplementing preschool services for young children with autism spectrum disorders and severe to mild intellectual disability. Res Dev Disabil. Nov-Dec. 2010;31(6):1678-84. [pmid: 20627451].
77 Eldevik S, Hastings RP, Jahr E, et al. Outcomes of behavioral intervention for children with autism in mainstream pre-school settings. J Autism Dev Disord. Feb. 2012;42(2):210-20. [pmid: 21472360].
78 Eikeseth S, Klintwall L, Jahr E, et al. Outcome for Children with Autism Receiving Early and Intensive Behavioral Intervention in Mainstream Preschool and Kindergarten Settings. Research in Autism Spectrum Disorders. 2012;6(2):829-35.
79 Kovshoff H, Hastings RP, Remington B. Two-year outcomes for children with autism after the cessation of early intensive behavioral intervention. Behav Modif. Sep. 2011;35(5):427-50. [pmid: 21586502].
80 Remington B, Hastings RP, Kovshoff H, et al. Early intensive behavioral intervention: outcomes for children with autism and their parents after two years. Am J Ment Retard. Nov. 2007;112(6):418-38. [pmid: 17963434].
81 Itzchak EB, Zachor DA. Who Benefits from Early Intervention in Autism Spectrum Disorders?. Research in Autism Spectrum Disorders. 2011;5(1):345-50.
82 Zachor DA, Itzchak EB. Treatment Approach, Autism Severity and Intervention Outcomes in Young Children. Research in Autism Spectrum Disorders. 2010;4(3):425-32.
83 Boyd BA, Hume K, McBee MT, et al. Comparative Efficacy of LEAP, TEACCH and Non-Model-Specific Special Education Programs for Preschoolers with Autism Spectrum Disorders. J Autism Dev Disord. 2013. Jun. 28. [pmid: 23812661].
84 Strain PS, Bovey EH. Randomized, Controlled Trial of the Leap Model of Early Intervention for Young Children with Autism Spectrum Disorders. Topics in Early Childhood Special Education. 2011;31(3):133-54.
85 Dawson G, Jones EJ, Merkle K, et al. Early behavioral intervention is associated with normalized brain activity in young children with autism. J Am Acad Child Adolesc Psychiatry. Nov. 2012;51(11):1150-9. [pmid: 23101741].
86 Flanagan HE, Perry A, Freeman NL. Effectiveness of large-scale community-based intensive Behavioral Intervention: A waitlist comparison study exploring outcomes and predictors. Research in Autism Spectrum Disorders. 2012;6(2):673-82.
87 Shine R, Perry A. The relationship between parental stress and intervention outcome of children with autism. Journal on Developmental Disabilities. 2010;16(2):64-6.
88 Freeman N, Perry A. Outcomes of intensive behavioural intervention in the Toronto Preschool Autism Service. Journal on Developmental Disabilities. 2010;16(2):17-32.
89 Perry A, Cummings A, Geier JD, et al. Effectiveness of Intensive Behavioral Intervention in a Large, Community-Based Program. Research in Autism Spectrum Disorders. Oct. 2008;2(4):621-42.
90 Perry A, Cummings A, Geier JD, et al. Predictors of Outcome for Children Receiving Intensive Behavioral Intervention in a Large, Community-Based Program. Research in Autism Spectrum Disorders. 2011;5(1):592-603.
91 Peters-Scheffer N, Didden R, Mulders M, et al. Effectiveness of low intensity behavioral treatment for children with autism spectrum disorder and intellectual disability. Research in Autism Spectrum Disorders. 2013;7(9):1012-25.
92 Pajareya K, Nopmaneejumruslers K. A pilot randomized controlled trial of DIR/Floortime parent training intervention for pre-school children with autistic spectrum disorders. Autism. Sep. 2011;15(5):563-77. [pmid: 21690083].
93 Carter AS, Messinger DS, Stone WL, et al. A randomized controlled trial of Hanen's ‘More Than Words’ in toddlers with early autism symptoms. J Child Psychol Psychiatry. Jul. 2011;52(7):741-52. [pmid: 21418212].
94 Oosterling I, Visser J, Swinkels S, et al. Randomized controlled trial of the focus parent training for toddlers with autism: 1-year outcome. J Autism Dev Disord. Dec. 2010;40(12):1447-58. [pmid: 20440639].
95 Reed P, Osborne L. Impact of Severity of Autism and Intervention Time-Input on Child Outcomes: Comparison across Several Early Interventions. British Journal of Special Education. 2012;39(3):130-6.
96 Roberts J, Williams K, Carter M, et al. A Randomised Controlled Trial of Two Early Intervention Programs for Young Children with Autism: Centre-Based with Parent Program and Home-Based. Research in Autism Spectrum Disorders. 2011;5(4):1553-66.
97 McConkey R, Truesdale-Kennedy M, Crawford H, et al. Preschoolers with Autism Spectrum Disorders: Evaluating the Impact of a Home-Based Intervention to Promote Their Communication. Early Child Development and Care. 2010;180(3):299-315.
98 Rogers SJ, Estes A, Lord C, et al. Effects of a brief Early Start Denver Model (ESDM)–based parent intervention on toddlers at risk for autism spectrum disorders: A randomized controlled trial. Journal of the American Academy of Child & Adolescent Psychiatry. 2012;51(10):1052-65. [pmid: 23021480].
99 Wong VCN, Kwan QK. Randomized controlled trial for early intervention for autism: A pilot study of the Autism 1-2-3 project. J Autism Dev Disord. 2010;40(6):677-88. [pmid: 20020319].
100 Keen D, Couzens D, Muspratt S, et al. The effects of a parent-focused intervention for children with a recent diagnosis of autism spectrum disorder on parenting stress and competence. Research in Autism Spectrum Disorders. 2010;4(2):229-41.
101 Strauss K, Vicari S, Valeri G, et al. Parent inclusion in Early Intensive Behavioral Intervention: the influence of parental stress, parent treatment fidelity and parent-mediated generalization of behavior targets on child outcomes. Res Dev Disabil. Mar-Apr. 2012;33(2):688-703. [pmid: 22188793].
102 Fava L, Strauss K, Valeri G, et al. The Effectiveness of a Cross-Setting Complementary Staff- and Parent-Mediated Early Intensive Behavioral Intervention for Young Children with ASD. Research in Autism Spectrum Disorders. 2011;5(4):1479-92.
103 Landa RJ, Holman KC, O'Neill AH, et al. Intervention targeting development of socially synchronous engagement in toddlers with autism spectrum disorder: a randomized controlled trial. J Child Psychol Psychiatry. Jan. 2011;52(1):13-21. [pmid: 21126245].
104 Landa RJ, Kalb LG. Long-term outcomes of toddlers with autism spectrum disorders exposed to short-term intervention. Pediatrics. Nov. Suppl 2. 2012;130:S186-90. [pmid: 23118250].
105 Aldred C, Green J, Emsley R, et al. Mediation of treatment effect in a communication intervention for pre-school children with autism. J Autism Dev Disord. 2012;42(3):447-54. [pmid: 21512834].
106 Estes A, Vismara L, Mercado C, et al. The Impact of Parent-Delivered Intervention on Parents of Very Young Children with Autism. J Autism Dev Disord. 2013. Jul. 10.
107 Casenhiser DM, Shanker SG, Stieben J. Learning through interaction in children with autism: preliminary data from asocial-communication-based intervention. Autism. Mar. 2013;17(2):220-41. [pmid: 21949005].
108 Reed P, Osborne LA, Makrygianni M, et al. Evaluation of the Barnet Early Autism Model (BEAM) Teaching Intervention Programme in a “Real World” Setting. Research in Autism Spectrum Disorders. June. 2013. 2013;7(6):631-8.
109 Schreibman L, Stahmer AC. A Randomized Trial Comparison of the Effects of Verbal and Pictorial Naturalistic Communication Strategies on Spoken Language for Young Children with Autism. J Autism Dev Disord. 2013. Nov. 23. [pmid: 24272416].
110 Perry A, Blacklock K, Dunn Geier J. The relative importance of age and IQ as predictors of outcomes in Intensive Behavioral Intervention. Research in Autism Spectrum Disorders. 2013;7(9):1142-50.
111 Reed P, Osborne LA, Corness M. The Real-World Effectiveness of Early Teaching Interventions for Children with Autism Spectrum Disorder. Exceptional Children. Sum. 2007;73(4):417-33.
112 Reed P, Osborne LA, Corness M. Effectiveness of Special Nursery Provision for Children with Autism Spectrum Disorders. Autism: The International Journal of Research and Practice. 2010;14(1):67-82. [pmid: 20124504].
113 Banda DR, Grimmett E. Enhancing Social and Transition Behaviors of Persons with Autism through Activity Schedules: A Review. Education and Training in Developmental Disabilities. Sep. 2008;43(3):324-33.
114 Quirmbach LM, Lincoln AJ, Feinberg-Gizzo MJ, et al. Social stories: mechanisms of effectiveness in increasing game play skills in children diagnosed with autism spectrum disorder using a pretest posttest repeated measures randomized control group design. J Autism Dev Disord. Feb. 2009;39(2):299-321. [pmid: 18704672].
115 Lopata C, Thomeer ML, Volker MA, et al. Effectiveness of a manualized summer social treatment program for high-functioning children with autism spectrum disorders. J Autism Dev Disord. May. 2008;38(5):890-904. [pmid: 18058012].
116 Solomon M, Goodlin-Jones BL, Anders TF. A social adjustment enhancement intervention for high functioning autism, Asperger's syndrome, and pervasive developmental disorder NOS. J Autism Dev Disord. Dec. 2004;34(6):649-68. [pmid: 15679185].
117 Frankel F, Myatt R, Sugar C, et al. A Randomized Controlled Study of Parent-assisted Children's Friendship Training with Children having Autism Spectrum Disorders. J Autism Dev Disord. 2010. Jan. 8. [pmid: 20058059].
118 Beaumont R, Sofronoff K. A multi-component social skills intervention for children with Asperger syndrome: the Junior Detective Training Program. J Child Psychol Psychiatry. Jul. 2008;49(7):743-53. [pmid: 18503531].
119 Kroeger KA, Schultz JR, Newsom C. A Comparison of Two Group-Delivered Social Skills Programs for Young Children with Autism. J Autism Dev Disord. May. 2007;37(5):808-17. [pmid: 16927011].
120 Owens G, Granader Y, Humphrey A, et al. LEGO therapy and the social use of language programme: an evaluation of two social skills interventions for children with high functioning autism and Asperger Syndrome. J Autism Dev Disord. Nov. 2008;38(10):1944-57. [pmid: 18566882].
121 Golan O, Ashwin E, Granader Y, et al. Enhancing Emotion Recognition in Children with Autism Spectrum Conditions: An Intervention Using Animated Vehicles with Real Emotional Faces. J Autism Dev Disord. Mar. 2010;40(3):269-79. [pmid: 19763807].
122 Legoff DB, Sherman M. Long-Term Outcome of Social Skills Intervention Based on Interactive LEGO[C] Play. Autism: The International Journal of Research & Practice. 2006;10(4):317-29. [pmid: 16908476].
123 Williams BT, Gray KM, Tonge BJ. Teaching Emotion Recognition Skills to Young Children with Autism: A Randomised Controlled Trial of an Emotion Training Programme. Journal of Child Psychology and Psychiatry. 2012;53(12):1268-76. [pmid: 22881991].
124 Koenig K, White SW, Pachler M, et al. Promoting social skill development in children with pervasive developmental disorders: a feasibility and efficacy study. J Autism Dev Disord. Oct. 2010;40(10):1209-18. [pmid: 20204689].
125 Kasari C, Rotheram-Fuller E, Locke J, et al. Making the connection: randomized controlled trial of social skills at school for children with autism spectrum disorders. J Child Psychol Psychiatry. Apr. 2012;53(4):431-9. [pmid: 22118062].
126 DeRosier ME, Swick DC, Davis NO, et al. The efficacy of a Social Skills Group Intervention for improving social behaviors in children with High Functioning Autism Spectrum disorders. J Autism Dev Disord. Aug. 2011;41(8):1033-43. [pmid: 21042870].
127 Lopata C, Thomeer ML, Volker MA, et al. RCT of a manualized social treatment for high-functioning autism spectrum disorders. J Autism Dev Disord. Nov. 2010;40(11):1297-310. [pmid: 20232240].
128 Begeer S, Gevers C, Clifford P, et al. Theory of mind training in children with autism: A randomized controlled trial. J Autism Dev Disord. 2011;41(8):997-1006. [pmid: 20976617].
129 Lerner MD, Mikami AY. A preliminary randomized controlled trial of two social skills interventions for youth with high-functioning autism spectrum disorders. Focus on Autism and Other Developmental Disabilities. 2012;27(3):147-57.
130 Sutton SK, Burnette CP, Mundy PC, et al. Resting cortical brain activity and social behavior in higher functioning children with autism. J Child Psychol Psychiatry. Feb. 2005;46(2):211-22. [pmid: 15679529].
131 Castorina LL, Negri LM. The inclusion of siblings in social skills training groups for boys with Asperger syndrome. J Autism Dev Disord. Jan. 2011;41(1):73-81. [pmid: 20461452].
132 Young RL, Posselt M. Using the transporters DVD as a learning tool for children with Autism Spectrum Disorders (ASD). J Autism Dev Disord. Jun. 2012;42(6):984-91. [pmid: 21822764].
133 Paynter J, Peterson CC. Further Evidence of Benefits of Thought-Bubble Training for Theory of Mind Development in Children with Autism Spectrum Disorders. Research in Autism Spectrum Disorders 2013 February. 2013;7(2):344-8.
134 Mandelberg J, Frankel F, Cunningham T, et al. Long-term outcomes of parent-assisted social skills intervention for high-functioning children with autism spectrum disorders. Autism. 2013. Aug. 30. [pmid: 23996903].
135 Ichikawa K, Takahashi Y, Ando M, et al. TEACCH-based group social skills training for children with high-functioning autism: a pilot randomized controlled trial. Biopsychosoc Med. 2013;7(1):14. [pmid: 24083413].
136 Thomeer ML, Lopata C, Volker MA, et al. Randomized clinical trial replication of a psychosocial treatment for children with high-functioning autism spectrum disorders. Psychology in the Schools. 2012;49(10):942-54.
137 Cihak DF, Smith CC, Cornett A, et al. The Use of Video Modeling with the Picture Exchange Communication System to Increase Independent Communicative Initiations in Preschoolers with Autism and Developmental Delays. Focus on Autism and Other Developmental Disabilities. 2012;27(1):3-11.
138 White SW, Koenig K, Scahill L. Group Social Skills Instruction for Adolescents with High-Functioning Autism Spectrum Disorders. Focus on Autism and Other Developmental Disabilities. 2010;25(4):209-19.
139 Solomon M, Ono M, Timmer S, et al. The effectiveness of parent-child interaction therapy for families of children on the autism spectrum. J Autism Dev Disord. Oct. 2008;38(9):1767-76. [pmid: 18401693].
140 Kasari C, Paparella T, Freeman S, et al. Language outcome in autism: randomized comparison of joint attention and play interventions. J Consult Clin Psychol. Feb. 2008;76(1):125-37. [pmid: 18229990].
141 Kasari C, Freeman S, Paparella T. Joint attention and symbolic play in young children with autism: a randomized controlled intervention study. J Child Psychol Psychiatry. Jun. 2006;47(6):611-20. [pmid: 16712638].
142 Field T, Sanders C, Nadel J. Children with autism display more social behaviors after repeated imitation sessions. Autism. Sep. 2001;5(3):317-23. [pmid: 11708590].
143 Heimann M, Laberg KE, Nordoen B. Imitative Interaction Increases Social Interest and Elicited Imitation in Non-verbal Children with Autism. Infant and Child Development. Special Issue: Imitation and Socio-Emotional Processes: Implications for Communicative Development and Interventions. May-Jun. 2006;15(3):297-309.
144 Escalona A, Field T, Nadel J, et al. Brief report: Imitation effects on children with autism. J Autism Dev Disord. Apr. 2002;32(2):141-4. [pmid: 12058842].
145 Gulsrud AC, Kasari C, Freeman S, et al. Children with autism's response to novel stimuli while participating in interventions targeting joint attention or symbolic play skills. Autism. Nov. 2007;11(6):535-46. [pmid: 17947289].
146 Whittingham K, Sofronoff K, Sheffield J, et al. Stepping Stones Triple P: An RCT of a Parenting Program with Parents of a Child Diagnosed with an Autism Spectrum Disorder. Journal of Abnormal Child Psychology. May. 2009;37(4):469-80. [pmid: 19023654].
147 Whittingham K, Sofronoff K, Sheffield J, et al. Do Parental Attributions Affect Treatment Outcome in a Parenting Program? An Exploration of the Effects of Parental Attributions in an RCT of Stepping Stones Triple P for the ASD Population. Research in Autism Spectrum Disorders. Jan. 2009;3(1):129-44.
148 Kasari C, Gulsrud A, Freeman S, et al. Longitudinal follow-up of children with autism receiving targeted interventions on joint attention and play. J Am Acad Child Adolesc Psychiatry. May. 2012;51(5):487-95. [pmid: 22525955].
149 Lawton K, Kasari C. Brief Report: Longitudinal Improvements in the Quality of Joint Attention in Preschool Children with Autism. J Autism Dev Disord. 2012;42(2):307-12. [pmid: 22187107].
150 Kasari C, Gulsrud AC, Wong C, et al. Randomized controlled caregiver mediated joint engagement intervention for toddlers with autism. J Autism Dev Disord. 2010;40(9):1045-56. [pmid: 20145986].
151 Goods KS, Ishijima E, Chang Y-C, et al. Preschool Based JASPER Intervention in Minimally Verbal Children with Autism: Pilot RCT. J Autism Dev Disord. May. 2013. 2013;43(5):1050-6. [pmid: 22965298].
152 Ingersoll B. Brief report: effect of a focused imitation intervention on social functioning in children with autism. J Autism Dev Disord. Aug. 2012;42(8):1768-73. [pmid: 22146934].
153 Ingersoll B. Brief report: Pilot randomized controlled trial of reciprocal imitation training for teaching elicited and spontaneous imitation to children with autism. J Autism Dev Disord. 2010;40(9):1154-60. [pmid: 20155309].
154 Venker CE, McDuffie A, Weismer SE, et al. Increasing Verbal Responsiveness in Parents of Children with Autism: A Pilot Study. Autism: The International Journal of Research and Practice. 2012;16(6):568-85. [pmid: 21846665].
155 Kaale A, Smith L, Sponheim E. A randomized controlled trial of preschool-based joint attention intervention for children with autism. J Child Psychol Psychiatry. Jan. 2012;53(1):97-105. [pmid: 21883204].
156 Siller M, Hutman T, Sigman M. A Parent-Mediated Intervention to Increase Responsive Parental Behaviors and Child Communication in Children with ASD: A Randomized Clinical Trial. J Autism Dev Disord. 2013;43(3):540-55. [pmid: 22825926].
157 Lawton K, Kasari C. Teacher-implemented joint attention intervention: pilot randomized controlled study for preschoolers with autism. J Consult Clin Psychol. Aug. 2012;80(4):687-93. [pmid: 22582764].
158 Wong CS. A play and joint attention intervention for teachers of young children with Autism: A randomized controlled pilot study. Autism. May. 2013. 2013;17(3):340-57. [pmid: 23610236].
159 Warreyn P, Roeyers H. See what I see, do as I do: Promoting joint attention and imitation in preschoolers with autism spectrum disorder. Autism. 2013. Oct. 8. [pmid: 24104513].
160 Schertz HH, Odom SL, Baggett KM, et al. Effects of Joint Attention Mediated Learning for Toddlers with Autism Spectrum Disorders: An Initial Randomized Controlled Study. Early Childhood Research Quarterly 2013. 2013;28(2):249-58.
161 Murdock LC, Hobbs JQ. Picture Me Playing: Increasing Pretend Play Dialogue of Children with Autism Spectrum Disorders. J Autism Dev Disord. 2011;41(7):870-8. [pmid: 20872061].
162 Sofronoff K, Dark E, Stone V. Social vulnerability and bullying in children with Asperger syndrome. Autism. May. 2011;15(3):355-72. [pmid: 21430018].
163 Sofronoff K, Attwood T, Hinton S, et al. A randomized controlled trial of a cognitive behavioural intervention for anger management in children diagnosed with Asperger syndrome. J Autism Dev Disord. Aug. 2007;37(7):1203-14. [pmid: 17082978].
164 Sofronoff K, Attwood T, Hinton S. A randomised controlled trial of a CBT intervention for anxiety in children with Asperger syndrome. J Child Psychol Psychiatry. Nov. 2005;46(11):1152-60. [pmid: 16238662].
165 Wood JJ, Drahota A, Sze K, et al. Cognitive Behavioral Therapy for Anxiety in Children with Autism Spectrum Disorders: A Randomized, Controlled Trial. Journal of Child Psychology and Psychiatry. Mar. 2009;50(3):224-34. [pmid: 19309326].
166 Wood JJ, Drahota A, Sze K, et al. Brief Report: Effects of Cognitive Behavioral Therapy on Parent-Reported Autism Symptoms in School-Age Children with High-Functioning Autism. J Autism Dev Disord. Nov. 2009;39(11):1608-12. [pmid: 19562475].
167 Aman MG, McDougle CJ, Scahill L, et al. Medication and Parent Training in Children With Pervasive Developmental Disorders and Serious Behavior Problems: Results From a Randomized Clinical Trial. J Am Acad Child Adolesc Psychiatry. 2009. Oct. 23. [pmid: 19858761].
168 Reaven JA, Blakeley-Smith A, Nichols S, et al. Cognitive-Behavioral Group Treatment for Anxiety Symptoms in Children with High-Functioning Autism Spectrum Disorders: A Pilot Study. Focus on Autism and Other Developmental Disabilities. 2009;24(1):27-37.
169 Sofronoff K. A Cognitive Behaviour Therapy intervention for anxiety in children with Asperger's syndrome. Good Autism Practice. 2003;4:2-8.
170 Sofronoff K, Leslie A, Brown W. Parent management training and Asperger syndrome: a randomized controlled trial to evaluate a parent based intervention. Autism. Sep. 2004;8(3):301-17. [pmid: 15358872].
171 Chalfant AM, Rapee R, Carroll L. Treating anxiety disorders in children with high functioning autism spectrum disorders: a controlled trial. J Autism Dev Disord. Nov. 2007;37(10):1842-57. [pmid: 17171539].
172 Sofronoff K, Farbotko M. The effectiveness of parent management training to increase self-efficacy in parents of children with Asperger syndrome. Autism. Sep. 2002;6(3):271-86. [pmid: 12212918].
173 Reaven J, Blakeley-Smith A, Culhane-Shelburne K, et al. Group cognitive behavior therapy for children with high-functioning autism spectrum disorders and anxiety: a randomized trial. J Child Psychol Psychiatry. Apr. 2012;53(4):410-9. [pmid: 22435114].
174 Sung M, Ooi YP, Goh TJ, et al. Effects of cognitive-behavioral therapy on anxiety in children with autism spectrum disorders: a randomized controlled trial. Child Psychiatry Hum Dev. Dec. 2011;42(6):634-49. [pmid: 21660428].
175 Scarpa A, Reyes NM. Improving emotion regulation with CBT in young children with high functioning autism spectrum disorders: a pilot study. Behav Cogn Psychother. Jul. 2011;39(4):495-500. [pmid: 21457605].
176 McNally Keehn RH, Lincoln AJ, Brown MZ, et al. The Coping Cat program for children with anxiety and autism spectrum disorder: A pilot randomized controlled trial. J Autism Dev Disord. 2013;43(1):57-67. [pmid: 22588377].
177 Storch EA, Arnold EB, Lewin AB, et al. The effect of cognitive-behavioral therapy versus treatment as usual for anxiety in children with autism spectrum disorders: A randomized, controlled trial. Journal of the American Academy of Child & Adolescent Psychiatry. 2013;52(2):132-42. [pmid: 23357440].
178 Drahota A, Wood JJ, Sze KM, et al. Effects of cognitive behavioral therapy on daily living skills in children with high-functioning autism and concurrent anxiety disorders. J Autism Dev Disord. Mar. 2011;41(3):257-65. [pmid: 20508979].
179 Farmer C, Lecavalier L, Yu S, et al. Predictors and moderators of parent training efficacy in a sample of children with autism spectrum disorders and serious behavioral problems. J Autism Dev Disord. Jun. 2012;42(6):1037-44. [pmid: 21822762].
180 Scahill L, McDougle CJ, Aman MG, et al. Effects of risperidone and parent training on adaptive functioning in children with pervasive developmental disorders and serious behavioral problems. J Am Acad Child Adolesc Psychiatry. Feb. 2012;51(2):136-46. [pmid: 22265360].
181 Arnold LE, Aman MG, Li X, et al. Research units of pediatric psychopharmacology (RUPP) autism network randomized clinical trial of parent training and medication: One-year follow-Up. Journal of the American Academy of Child & Adolescent Psychiatry. 2012;51(11):1173-84. [pmid: 23101743].
182 Fujii C, Renno P, McLeod BD, et al. Intensive cognitive behavioral therapy for anxiety disorders in school-aged children with autism: A preliminary comparison with treatment-as-usual. School Mental Health. 2013;5(1):25-37.
183 Kenworthy L, Anthony LG, Naiman DQ, et al. Randomized controlled effectiveness trial of executive function intervention for children on the autism spectrum. J Child Psychol Psychiatry. 2013. Nov. 21. [pmid: 24256459].
184 Handen BL, Johnson CR, Butter EM, et al. Use of a Direct Observational Measure in a Trial of Risperidone and Parent Training in Children with Pervasive Developmental Disorders. J Dev Phys Disabil. Jun. 1. 2013;25(3):355-71. [pmid: 23730123].
185 Doyle T, Arnedillo-Sanchez I. Using Multimedia to Reveal the Hidden Code of Everyday Behaviour to Children with Autistic Spectrum Disorders (ASDs). Computers & Education. 2011;56(2):357-69.
186 Coben R, Padolsky I. Assessment-guided neurofeedback for autistic spectrum disorder. Journal of Neurotherapy. 2007;11(1):5-23.
187 Jarusiewicz B. Efficacy of Neurofeedback for Children in the Autistic Spectrum: A Pilot Study. Journal of Neurotherapy. 2002;6(4):39-49.
188 Adkins KW, Molloy C, Weiss SK, et al. Effects of a standardized pamphlet on insomnia in children with autism spectrum disorders. Pediatrics. Nov. Suppl 2. 2012;130:S139-44. [pmid: 23118244].
189 Cortesi F, Giannotti F, Sebestiani T, et al. Controlled-release melatonin, singly and combined with cognitive behavioural therapy, for persistent insomnia in children with autism spectrum disorders: A randomized placebo-controlled trial. Journal of Sleep Research. 2012;21(6):700-9. [pmid: 22616853].
190 Malow BA, Adkins KW, Reynolds A, et al. Parent-Based Sleep Education for Children with Autism Spectrum Disorders. J Autism Dev Disord. 2013. Jun. 11. [pmid: 23754339].
191 Sharp WG, Burrell TL, Jaquess DL. The Autism MEAL Plan: A parent-training curriculum to manage eating aversions and low intake among children with autism. Autism. 2013. Oct. 7. [pmid: 24101716].
192 Kouijzer MEJ, van Schie HT, de Moor JMH, et al. Neurofeedback treatment in autism. Preliminary findings in behavioral, cognitive, and neurophysiological functioning. Research in Autism Spectrum Disorders. 2010;4(3):386-99.
193 Manente CJ, Maraventano JC, LaRue RH, et al. Effective Behavioral Intervention for Adults on the Autism Spectrum: Best Practices in Functional Assessment and Treatment Development. Behavior Analyst Today. 2010;11(1):36-48.
194 Kouijzer MEJ, de Moor JMH, Gerrits BJL, et al. Neurofeedback Improves Executive Functioning in Children with Autism Spectrum Disorders. Research in Autism Spectrum Disorders. Jan. 2009;3(1):145-62.
195 Kouijzer MEJ, de Moor JMH, Gerrits BJL, et al. Long-term effects of neurofeedback treatment in autism. Research in Autism Spectrum Disorders. 2009;3(2):496-501.
196 Charlop-Christy MH, Haymes LK. Using obsessions as reinforcers with and without mild reductive procedures to decrease inappropriate behaviors of children with autism. J Autism Dev Disord. Oct. 1996;26(5):527-46. [pmid: 8906454].
197 Peters-Scheffer N, Didden R, Korzilius H, et al. A Meta-Analytic Study on the Effectiveness of Comprehensive ABA-Based Early Intervention Programs for Children with Autism Spectrum Disorders. Research in Autism Spectrum Disorders. 2011;5(1):60-9.
198 Kuppens S, Onghena P. Sequential Meta-Analysis to Determine the Sufficiency of Cumulative Knowledge: The Case of Early Intensive Behavioral Intervention for Children with Autism Spectrum Disorders. Research in Autism Spectrum Disorders. 2012;6(1):168-76.
199 Reichow B. Overview of Meta-Analyses on Early Intensive Behavioral Intervention for Young Children with Autism Spectrum Disorders. J Autism Dev Disord. 2012;42(4):512-20. [pmid: 21404083].
200 Autism Speaks. Autism Speaks: State initiatives. Available at: http://www.autismspeaks.org/advocacy/states. 04/14/2014.
201 Bolte EE, Diehl JJ. Measurement tools and target symptoms/skills used to assess treatment response for individuals with autism spectrum disorder. J Autism Dev Disord. Nov. 2013;43(11):2491-501. [pmid: 23479074].