# Methods

## Topic Development and Refinement

The 2011 report was nominated by Autism Speaks in a public process. We drafted the initial Key Questions and analytic framework and refined them with input from key informants and a focus group of family members of children with autism spectrum disorder (ASD). After review from the Agency for Healthcare Research and Quality (AHRQ), the questions and framework were posted to a public Web site. After reviewing the public commentary, we drafted final Key Questions and submitted them to AHRQ for review. The need for an update of that report was documented through an ongoing update assessment project at AHRQ.

For the current update, we identified technical experts on the topic of ASD in children to provide input during the project. Technical Expert Panel (TEP) members represented the clinical and research communities from a range of perspectives. TEP members included both researchers and clinicians with expertise in behavioral, social, and psychological issues. To ensure robust, scientifically relevant work, we called on the TEP to provide reactions to work in progress. TEP members participated in conference calls and discussions through email to:

- Refine the analytic framework and Key Questions to ensure that they continued to represent important decisional dilemmas;
- Discuss the preliminary assessment of the literature, including inclusion/exclusion criteria;
- Ensure that we had captured seminal studies addressing interventions for children with ASD.

After discussions with the TEP and our initial scan of the literature, we retained all of the Key Questions (KQ) from the earlier review in the current report, modifying them slightly to reflect a focus on behavioral interventions. The protocol for the current update is available on the AHRQ Effective Health Care web site.

### Role of the AHRQ Task Order Officer

The Task Order Officer (TOO) was responsible for overseeing all aspects of this project. The TOO helped to develop a common understanding among all parties involved in the project, resolved questions and ambiguities, and addressed our queries regarding the scope and processes of the project. The TOO reviewed the report for consistency, clarity, and to ensure that it conforms to AHRQ standards.

## Analytic Framework

Figure 1 illustrates the placement of the review's Key Questions within the context of treatment choice, potential outcomes, and characteristics that may affect outcomes. Circled numbers indicate the KQs, and their placement indicates the points in the treatment process where they are likely to arise. This update focuses on behavioral interventions for children with ASD or considered to be at risk for ASD. The population of interest is patients 0–12 years diagnosed with ASD. A child entering treatment may be between the ages of 0 and 2 and at risk for diagnosis of ASD or ages 0 to 12 with a diagnosis of ASD. Diagnoses may occur before age 2; thus the represented age ranges overlap. Individuals engage in behavioral interventions, which may lead to specific outcomes (KQ 1). Outcomes may be modified by characteristics of the child/family or of the intervention (KQ 2). KQ 3 involves identifiable changes early in the treatment process that may affect outcomes. KQ 4 involves the relationship between targeted outcomes in the treatment setting and functional outcomes outside the treatment setting. KQ 5 involves generalization of interventions to other contexts, and KQ 6 addresses components of treatments that may drive outcomes, the “active ingredients” of treatments. KQ 7 addresses treatments for very young children considered to be at risk for ASD. Target outcomes in the treatment setting include ASD symptom severity, language/communication, academic skill development, maladaptive behaviors, distress, adaptive skills development, and social skills/interaction. Functional outcomes outside the treatment setting include adaptive independence, academic engagement/attainment, psychological well-being, and psychosocial adaptation; for children considered to be at risk, the outcomes include changes in ASD symptom severity or diagnostic outcome, motor skills, and cognitive skills. Long-term outcomes include quality of life, social integration, and appropriate level of independence. Harms of intervention are also considered.

Figure 1 Analytic framework for behavioral interventions for children with ASD

ASD = autism spectrum disorder; KQ = Key Question

Note: Numbers in circles on diagram represent placement of Key Questions.

The analytic framework illustrates the placement of the review's key questions within the context of treatment choice, potential outcomes, and characteristics that may affect outcomes. Circled numbers indicate the key questions (KQ), and their placement indicates the points in the treatment process where they are likely to arise. This update focuses on behavioral interventions for children with ASD or considered to be at risk for ASD. The population of interest is patients 0–12 years diagnosed with ASD. A child entering treatment may be between the ages of 0 and 2 and at risk for diagnosis of ASD or ages 0 to 12 with a diagnosis of ASD. Diagnoses may occur before age 2; thus the represented age ranges overlap. Individuals engage in behavioral interventions, which may lead to specific outcomes (KQ 1). Outcomes may be modified by characteristics of the child/family or of the intervention (KQ 2). KQ 3 involves identifiable changes early in the treatment process that may affect outcomes. KQ 4 involves the relationship between targeted outcomes in the treatment setting and functional outcomes outside the treatment setting. KQ 5 involves generalization of interventions to other contexts, and KQ 6 addresses components of treatments that may drive outcomes, the “active ingredients” of treatments. KQ 7 addresses treatments for very young children considered to be at risk for ASD. Target outcomes in the treatment setting include ASD symptom severity, language/communication, academic skill development, maladaptive behaviors, distress, adaptive skills development, and social skills/interaction. Functional outcomes outside the treatment setting include adaptive independence, academic engagement/attainment, psychological well-being, and psychosocial adaptation; for children considered to be at risk, the outcomes include changes in ASD symptom severity or diagnostic outcome, motor skills, and cognitive skills. Long-term outcomes include quality of life, social integration, and appropriate level of independence. Harms of intervention are also considered.

## Literature Search Strategy

### Databases

A librarian employed search strategies provided in Appendix A to retrieve research on interventions for children with ASD. Our primary literature search employed three databases: MEDLINE^®^ via the PubMed interface, PsycINFO^®^ (psychology and psychiatry literature), and the Educational Resources Information Clearinghouse. Our search strategies used a combination of subject heading terms appropriate for each database and key words relevant to ASD (e.g., autism, Asperger). We limited searches to the English language and literature published since the development of the 2011 review.

We also manually searched the reference lists of included studies and of recent narrative and systematic reviews and meta-analyses addressing ASD. We also invited TEP members to provide additional citations.

### Grey Literature and Hand Searching

As the review focuses on behavioral interventions, we did not search for regulatory information. As noted, we hand searched the reference lists of included studies and recent reviews.

### Search Terms

Controlled vocabulary terms served as the foundation of our search in each database (e.g., MEDLINE vocabulary terms including autistic disorder, child development disorders, pervasive), complemented by additional keyword phrases (e.g., Asperger, autism). We also limited searches to items published in English. Our searches were executed in July 2013. Appendix A provides our search terms and the yield from each database. We imported all citations into an electronic database.

## Process for Study Selection

### Inclusion and Exclusion Criteria

We developed criteria for inclusion and exclusion based on the patient populations, interventions, outcome measures, and types of evidence specified in the Key Questions and in consultation with the TEP. Table 1 summarizes criteria.

Table 1 Inclusion criteria

Category | Criteria
Study population | Children ages 0–12 with ASD or 0–2 considered to be at risk for ASD based on sibling status or early developmental/behavioral vulnerabilities highly suspicious of ASD
Publication languages | English only
Admissible evidence (study design and other criteria) | [underlined: Admissible designs] Randomized controlled trials, prospective and retrospective cohort studies, and nonrandomized controlled trials [underlined: Other criteria] Studies must be original research studies providing sufficient detail regarding methods and results to enable use and aggregation of the data and results Studies must have relevant population and ≥10 participants with ASD Studies must address one or more of the following for ASD:; - Behavioral treatment modality; - Predictors of treatment outcomes; - Generalization of treatment outcomes to other contexts; - Drivers of treatment outcomes; Relevant outcomes must be able to be abstracted from data in the papers Data must be presented in the aggregate (vs. individual participant data)

ASD = autism spectrum disorder

#### Study Population

Studies needed to provide adequate information to ensure that participants fell within the target age range. For studies with populations including individuals with ASD in our target range and over age 12, we retained the study if we could infer that at least 80 percent of the study participants were in the 0 to 12 age range or if the mean age of participants did not exceed 12 years and 11 months. Similarly, for studies including individuals with ASD and those with other developmental disabilities, we retained the study if we could isolate data on those participants with ASD.

#### Sample Size

We included studies with at least 10 individuals with ASD between the ages of 0 to 12 years. Our goal was to identify and review the best evidence for assessing the efficacy and effectiveness of therapies for children with ASD, with an eye toward utility in the treatment setting. Interventions to address ASD are frequently behavioral in nature and highly intensive. They are also frequently adapted to be targeted to specific study participants given the significant heterogeneity of individuals with ASD. In part because this makes behavioral research quite complex and intensive, study sizes tend to be very small. A cutoff sample size of 10 provides a balance, allowing us to review and comment on adequate literature for the review but with studies large enough to suggest effects of the interventions.

With the assistance of our technical experts, we selected a minimum sample size of 10 in order to maximize our ability to describe the state of the current literature, while balancing the need to identify studies that could be used to assess treatment effectiveness.

We recognize that the combination of requiring a comparison group and setting a minimum of 10 participants for studies to be included effectively excluded much of the literature on behavioral interventions using single-subject designs.

Single-subject design studies can be helpful in assessing response to treatment in very short timeframes and under very tightly controlled circumstances, but they typically do not provide information on longer term or functional outcomes, nor are they ideal for external validity without multiple replications.53 They are useful in serving as demonstration projects, yielding initial evidence that an intervention merits further study, and, in the clinical environment, they can be useful in identifying whether a particular approach to treatment is likely to be helpful for a specific child. Our goal was to identify and review the best evidence for assessing the efficacy and effectiveness of behavioral interventions for children with ASD, with an eye toward utility in the treatment setting.

#### Study Design

We accepted any comparative study designs; that is, any study that included both a treatment/intervention and a separate control group. Control participants could receive an alternate intervention, no intervention/waitlist, or placebo. While we recognize that case series and single-subject design studies can be useful for testing hypotheses or piloting interventions, we did not include such studies as the potential for bias associated with the lack of a control group limits the utility of their findings.

#### Outcomes

We assessed outcomes in the broad areas of symptom severity, cognitive skills, motor skills, adaptive behavior, language/communication, maladaptive behavior, distress, social skills, and academic attainment. We considered intermediate outcomes as those that occur directly as a result of the intervention and that may also have longer term implications for the ultimate, functional outcomes that are the long-term goal of therapies. We also assessed the harms of interventions, defined by the AHRQ Effective Health Care program as the totality of adverse consequences of an intervention.54

#### Language

We focused the review on studies published in English. In the opinion of our content experts, most research on ASD is published in English regardless of the native language of the investigators or country of publication.

## Screening of Studies

Once we identified articles through the electronic database searches, review articles, and bibliographies, we examined abstracts of articles to determine whether studies met our criteria. Two reviewers separately evaluated each abstract for inclusion or exclusion, using an Abstract Review Form (Appendix B). If one reviewer concluded that the article could be eligible for the review based on the abstract, we retained it for full text assessment.

Two reviewers independently assessed the full text of each included study using a standardized form (Appendix B) that included questions stemming from our inclusion/exclusion criteria. Disagreements between reviewers were resolved by a third-party adjudicator. The group of abstract and full text reviewers included expert clinicians and researchers and health services researchers.

## Data Extraction and Data Management

The staff members and clinical experts who conducted this review jointly developed the evidence tables, which were used to extract data from the studies. We used table categories and parameters as outlined in the 2011 review. Tables aim to provide sufficient information to enable readers to understand the studies, including issues of study design, descriptions of the study populations (for applicability), description of the intervention, and baseline and outcome data on constructs of interest.

All team members shared the task of initially entering information into the evidence table. Another member of the team also independently reviewed the articles and edited all initial table entries for accuracy, completeness, and consistency. The full research team met regularly during the article extraction period and discussed issues related to data extraction (e.g., optimal level of detail in the description of the intervention). In addition to outcomes related to treatment effectiveness and modifiers of effects, we extracted all data available on harms. Harms encompass the full range of specific negative effects, including the narrower definition of adverse events.

The final evidence tables are presented in their entirety in Appendix C. Studies are presented in the evidence tables alphabetically by the last name of the first author within each year. When possible to identify, analyses resulting from the same study were grouped into a single evidence table. For those studies reported in the 2011 review and with followup data reported here, the evidence table for the original studies can be found in the 2011 report.39

## Individual Study Quality Assessment

We used the approach to assessing the quality of individual studies that was developed for the 2011 review and following methods outlined in the AHRQ Effective Health Care program's “Methods Guide for Effectiveness and Comparative Effectiveness Reviews.”55 We assessed the quality of studies in the domains below using specific questions to evaluate a study's conduct. We rated each domain individually and combined them for an overall quality level as described below and in Appendix D. Three levels were possible: good, fair, and poor (Table 2).

Table 2 Description of study quality levels

Quality Level | Description
Good | Good studies are considered to have the least bias and results are considered valid. A good study has a clear description of the population, setting, interventions, and comparison groups; uses a valid approach to allocate patients to treatments; has a low dropout rate; and uses appropriate means to prevent bias; measure outcomes; analyze and report results.
Fair | Fair studies are susceptible to some bias, but probably not sufficient to invalidate the results. A study may be missing information, making it difficult to assess limitations and potential problems. As the “fair quality” category is broad, studies with this rating vary in their strengths and weaknesses. The results of some fair-quality studies are possibly valid, while others are probably valid.
Poor | Poor studies are subject to significant bias that may invalidate the results. These studies have serious errors in design, analysis, or reporting; have large amounts of missing information; or have discrepancies in reporting. The results of a poor-quality study are at least as likely to reflect flaws in the study design as to indicate true differences between the compared interventions.

Study design
1. Did the study employ a group design (have a comparison group)?
2. Were the groups randomly assigned?
3. If no, was there an appropriate comparison group?
4. If yes, was randomization done correctly?

Diagnostic approach
1. Was a valid diagnostic approach for ASD used within the study, or were referred participants diagnosed using a valid approach?
  A. A clinical diagnosis based on the DSM, in addition to the ADI-R and/or ADOS assessments.
  B. A combination of a DSM clinical diagnosis with one other assessment tool; or the ADOS assessment in combination with one other assessment tool.
  C. Either a clinical DSM-based diagnosis alone or the ADOS assessment alone.
  D. Neither a clinical DSM-based diagnosis nor the ADOS assessment

Participant ascertainment
1. Was the sample clearly characterized (e.g., information provided to characterize participants in terms of impairments associated with their ASD, such as cognitive or developmental level)?
2. Were inclusion and exclusion criteria clearly stated?
3. Do the authors report attrition?
4. Were characteristics of the drop-out group evaluated for differences with the participant group as a whole?

Intervention characteristics
1. Was the intervention fully described?
2. Was treatment fidelity monitored in a systematic way? (for non-medical interventions)
3. Did the authors measure and report adherence to the intended treatment process? (for medical interventions)
4. Did the authors report differences in or hold steady all concomitant interventions?

Outcomes measurement
1. Did outcome measures demonstrate adequate reliability and validity (including inter-observer reliability for behavior observation coding)?
2. Were outcomes coded and assessed by individuals blinded to the intervention status of the participants?

Statistical analysis
1. For RCTs, was there an intent-to-treat analysis?
2. For negative studies, was a power calculation provided?
3. For observational studies, were potential confounders and effect measure modifiers captured?
4. For observational studies, were potential confounders and effect measure modifiers handled appropriately?

### Determining Quality Levels

We assessed each domain described above individually and considered the individual ratings to determine an overall quality assessment of good, fair, or poor. We required that studies receive positive scores questions related to study design and diagnostic approach to be considered good quality. Scores were calculated first by domain and then summed and weighted as described in Table 3 to determine overall study quality. Studies could receive up to two points on the domains of study design, diagnostic approach, participant ascertainment, and intervention, and up to one point on the domains of outcome measurement and statistical analysis.

Table 3 Quality scoring algorithm

Definition and Scoring Algorithm | Rating
Score algorithm for internal validity quality rating
- ≥8/10 points, including a ++ on study design and ++ on diagnostic approach | Good quality
- ≥6/10 points, including at least a + on intervention | Fair quality
- ≤5/10 points | Poor quality

## Data Synthesis

We summarized all data qualitatively using evidence tables. We focused on outcomes related to core ASD symptoms (impairments in communication and social interaction and restricted/repetitive behaviors and interests), outcomes including IQ and adaptive behavior, and key symptoms in studies of interventions targeting conditions commonly associated with ASD (e.g., anxiety). For the update, we describe new comparative studies published since the original report, and we make our conclusions and assess the strength of evidence on the cumulative, comparative evidence across the original report and update.

## Grading the Body of Evidence for Each Key Question

The assessment of the literature is done by considering both the observed effectiveness of interventions and the confidence that we have in the stability of those effects in the face of future research. The degree of confidence that the observed effect of an intervention is unlikely to change is presented as strength of evidence, and it can be regarded as insufficient, low, moderate, or high. Strength of evidence describes the adequacy of the current research, both in terms of quantity and quality, as well as the degree to which the entire body of current research provides a consistent and precise estimate of effect. Interventions that have demonstrated benefit in a small number of studies but have not yet been replicated using the most rigorous study designs will therefore have insufficient or low strength of evidence to describe the body of research. Future research may find that the intervention is either effective or ineffective. Strength of the evidence is assessed for a limited set of critical outcomes, typically those related to effectiveness of an intervention. We assessed the strength of the evidence for studies addressing Key Questions 1 and 7, which deal specifically with the outcomes of intervention.

Methods for applying strength of evidence assessments are established in the “Methods Guide for Effectiveness and Comparative Effectiveness Reviews”55 and are based on consideration of five domains (Table 4): study limitations, consistency in direction of the effect, directness in measuring intended outcomes, precision of effect, and reporting bias. Strength of evidence is assessed separately for major intervention-outcome pairs and incorporates data from the entire body of reviewed evidence on behavioral interventions (i.e., comparative studies—both RCTs and prospective and retrospective cohort studies—reported in the 2011 review39 and studies reported in the current review). We required at least three fair studies to be available to assign a low strength of evidence rather than considering it to be insufficient. We required at least one good study for moderate strength of evidence and two good studies for high strength of evidence. In addition, to be considered “moderate” or higher, intervention-outcome pairs needed a positive response on two out of the three domains other than study limitations.

Table 4 Domains used to assess strength of evidence^a^

Domain | Explanation
Study Limitations | Degree to which included studies for a given outcome have a high likelihood of adequate protection against bias (i.e., good internal validity), assessed through study design and study conduct.
Consistency | Degree to which included studies find either the same direction or similar magnitude of effect. Assessed through two main elements:; - Direction of effect: Effect sizes have the same sign (that is, are on the same side of no effect or a minimally important difference).; - Magnitude of effect: The range of effect sizes is similar.
Directness | Extent to which evidence links interventions directly to a health outcome of specific importance for the review, and for comparative studies, whether the comparisons are based on head-to-head studies. Evidence may be indirect in several situations such as:; - Outcome being graded is considered intermediate in a review that is focused on clinical health outcomes (such as morbidity, mortality).; - Data do not come from head-to-head comparisons but rather from two or more bodies of evidence to compare.; - Data are available only for proxy respondents instead of directly from patients for situations in which patients are capable of self-reporting and self-report is more reliable.
Precision | Degree of certainty surrounding an effect estimate with respect to a given outcome, based on the sufficiency of sample size and number of events. A body of evidence will generally be imprecise if the optimal information size (OIS) is not met. OIS refers to the minimum number of patients (and events when assessing dichotomous outcomes) needed for an evidence base to be considered adequately powered.
Reporting bias | Degree of selective publishing or reporting of research findings based on the favorability of direction or magnitude of effect.

a Excerpted from Berkman et al. 2013^56^

Once we had established the maximum strength of evidence possible based upon these criteria, we assessed the number of studies and range of study designs for a given intervention-outcome pair, and downgraded the rating when the cumulative evidence was not sufficient to justify the higher rating. The possible grades were:

- High: High confidence that the evidence reflects the true effect. Further research is unlikely to change estimates
- Moderate: Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate
- Low: Low confidence that the evidence reflects the true effect. Further research is likely to change confidence in the estimate of effect and is also likely to change the estimate
- Insufficient: Evidence is either unavailable or does not permit a conclusion.

## Applicability

Finally, it is important to consider the ability of the outcomes observed to apply both to other populations and to other settings (especially for those therapies that take place within a clinical/treatment setting but are hoped to change behavior overall). Our assessment of applicability included determining the population, intervention, comparator, and setting in each study and developing an overview of these elements for each intervention category.

## Peer Review and Public Commentary

Researchers and clinicians with expertise in behavioral, medical, social, psychological and educational issues and individuals representing stakeholder and user communities provided external peer review of this report; AHRQ and an associate editor also provided comments. The draft report was posted on the AHRQ Web site for 4 weeks to elicit public comment. We addressed all reviewer comments, revised the text as appropriate, and documented changes and revisions to the report in a disposition of comments report that will be made available 3 months after AHRQ posts the final review on the AHRQ Web site.