# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Grace Baranek, Ph.D., O.T.R./L., FAOTA
  University of North Carolina School of Medicine
  Chapel Hill, NC
- Tony Charman, Ph.D.
  King's College, London
  London, England, UK
- Benjamin Handen, Ph.D.
  University of Pittsburgh
  Pittsburgh, PA
- Patricia Howlin, Ph.D.
  Institute of Psychiatry
  King's College, London
  London, England, UK
- Susan Levy, M.D., M.P.H.
  Children's Hospital of Philadelphia
  Philadelphia, PA
- Doris Lotz, M.D., M.P.H.
  Medicaid Chief Medical Officer, New Hampshire
  Concord, NH
- Rhonda Robinson-Beale, M.D.
  OptumHealth Behavioral Solutions
  Glendale, CA
- Tristram Smith, Ph.D.
  University of Rochester
  Rochester, NY