# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Jessica Kimber, Sanura Latham, Christine Shoaf, and Tanya Surawicz provided extremely helpful assistance with locating papers, initial data extraction, and formatting materials.