# Discussion

In this chapter, we summarize our findings about behavioral interventions for children with autism spectrum disorder (ASD). We provide an overview of the state of the literature by intervention type, detail the strength of evidence for the impact of each major intervention on relevant outcomes, and describe major issues and gaps in the current body of evidence.

Assessing the literature requires consideration of two main components, namely the observed effectiveness of interventions and our confidence that those effects will remain stable in the face of future research. Our confidence that the observed effect is the true effect and that perceived effectiveness is unlikely to change with future research is presented as strength of evidence, and can be insufficient, low, moderate or high. Strength of evidence describes the adequacy of the current research, both quantity and quality, and whether the entire body of current research provides a consistent and precise estimate of effect.

Methods for applying strength of evidence assessments are established in the Evidence-based Practice Centers' “Methods Guide for Effectiveness and Comparative Effectiveness Reviews”55 and are based on consideration of five domains: study limitations, consistency in direction of the effect, directness in measuring intended outcomes, precision of effect, and reporting bias. We considered comparative studies—both RCTs and prospective and retrospective cohort studies—from the prior 2011 review plus the studies identified for the current review in determining strength of the evidence for major outcomes.

We required at least three fair studies to be available to assign a low strength of evidence rather than considering it to be insufficient. We required at least one good study for moderate strength of evidence and two good studies for high strength of evidence. In addition, to be considered “moderate” or higher, intervention-outcome pairs needed a positive response on two out of the three domains other than study limitations.

Once we established the maximum strength of evidence possible based upon these criteria, we assessed the number of studies and range of study designs for a given intervention-outcome pair, and downgraded the strength of evidence rating when the cumulative evidence was not sufficient to justify the higher rating.

## Key Findings and Strength of Evidence

### KQ1 Effects of Behavioral Interventions on Core and Commonly Associated Symptoms in Children With ASD

#### Early Intensive Behavioral and Developmental Interventions

Within this category, we included intensive behavioral and developmental interventions derived from applied behavior analysis (ABA) principles that targeted a broad range of skills and vulnerabilities. As such, this category includes defined manualized approaches that vary substantially in terms of their structure, approach and setting (e.g., University of California, Los Angeles [UCLA]/Lovaas, Early Start Denver Model [ESDM], Learning Experiences and Alternate Program for Preschoolers and their Parents [LEAP]) as well as more eclectically defined and delivered approaches. ABA is an umbrella term describing principles and techniques used in the assessment, treatment and prevention of challenging behaviors and the promotion of new desired behaviors. The goal of ABA is to teach new skills, promote generalization of these skills, and reduce challenging behaviors with systematic reinforcement. The principles and techniques of ABA existed for decades prior to specific application and study within ASD.

An additional set of interventions included here uses the principles of ABA to focus on key pivotal behaviors rather than global improvements. These approaches emphasize parent training (e.g., Pivotal Response Training, Hanen More than Words, social pragmatic intervention, etc.) and may focus on core social-communication skills or specific behaviors, such as initiating activities.

In the 2011 review, we identified 17 comparative studies of early intensive behavioral and developmental intervention57-75 (described in 19 papers), of which six were RCTs (two good quality,73, 75four fair57, 69, 71, 72), five were nonrandomized trials (four fair quality,64-68, 74one poor70), four were prospective cohort studies (three fair60, 61, 63 and one poor quality62), and two were poor quality retrospective cohort studies.58, 59 We located 37 papers comprising 25 unique studies addressing early intensive behavioral and developmental interventions for this review update. Individual studies using intensive UCLA/Lovaas-based interventions, ESDM, the LEAP program, and eclectic variants reported improvements in outcomes for young children. Our strength of the evidence assessment considers studies from both the 2011 and current reviews.

Improvements were most often seen in cognitive abilities and language acquisition with less robust and consistent improvements seen in adaptive skills, core ASD symptom severity, and social functioning. Young children receiving high intensity ABA-based interventions over the course of extended time frames (i.e., 8 months--2 years) commonly display substantial improvement in cognitive functioning and language skills relative to community controls. However, the magnitude of these effects varies across studies and this variation may describe subgroups showing different responses to particular interventions. Intervention response is likely moderated by both treatment and child factors, but exactly how these moderators function is not entirely clear. Despite multiple studies of early intensive treatments, intervention approaches still vary substantially, which makes it difficult to tease apart what these unique treatment and child factors may be. Sample sizes of studies in the current review are typically small (total Ns ranging from 11–284, median=40), and some studies may be considered pilots for larger studies that may better elucidate questions about interventions intensity and moderators of effects. Further, the long-term impact of these early skill improvements is not yet clear, and many studies did not follow children beyond late preschool or early school years.

Studies of high intensity early intervention services also demonstrated improvements in children's early adaptive behavior skills, but these improvements are more variable than those found for early cognitive and language skills. Treatment effects are not consistently maintained across studies. Many studies measure different adaptive behavior domains (which creates within scale variability) and some evidence suggests that adaptive behavior changes may be contingent upon baseline child characteristics, such as cognitive/language and ASD severity.

Evidence for the impact of early intensive intervention on core ASD symptoms is more limited and mixed than its impact on cognitive and adaptive behavior skills. Children's symptom severity often decreased during treatment, but these improvements did not often differ from those of children in control groups. In fact, almost equal numbers of studies report treatment impact versus null treatment effects.

Since our previous review, there have been substantially more studies of well-controlled low intensity interventions that provide parent training in bolstering social communication skills. This growing literature base provides increasing data about the utility of such interventions for younger children with ASD, particularly when targeting social communication and language use. However, although parent training programs reported that parenting behaviors were modified during interactions, data are more limited about improvement in broad developmental skills (such as cognition, adaptive behavior, and ASD symptom severity) beyond language gains for some children. Children receiving low-intensity interventions have not demonstrated the same substantial gains as seen in the early intensive intervention paradigms regarding cognitive and adaptive skills.

##### Strength of the Evidence

A growing evidence base suggests that some children receiving early intensive behavioral and developmental interventions (e.g., many hours of intervention a week over the course of 1–2 years) show substantial improvements in cognitive and language skills over time compared with children receiving low-intensity interventions, community controls, and eclectic non-ABA based intervention approaches. With this growing literature, our confidence (strength of evidence) in the effects of ABA-based early intensive approaches on cognitive and language outcomes is moderate, based on the need for additional research that identifies which groups of children benefit the most from specific high intensity approaches. Our strength of evidence in these high intensity interventions to affect adaptive behavior skills, social skills, and core ASD symptom severity is low. At present it is challenging to understand which approaches to high intensity intervention have the greatest effects for specific children (Table 12).

Table 12 Strength of evidence for ABA-based early intensive behavioral and developmental studies

Outcome Strength of Evidence Grade | Study Design Quality and Number of Studies (N Total Participants) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Finding
IQ/cognitive Moderate for positive effect | RCT: 1 good, 2 fair (360) Prospective cohort: 6 fair, 2 poor (521) nRCT; 1 good, 4 fair (170) Retrospective cohort: 1 fair, 2 poor (182) | Medium | Consistent | Direct | Precise | Undetected | Young children receiving high intensity interventions display improvements in aspects of cognitive functioning. Most studies found that children in treatment and comparison groups both improved on cognitive skills, with children in high intensity early intensive intervention improving more than children receiving other types of services. Not all of these improvements were maintained at long-term followups. Many children display a positive response to this intervention, but the effect is somewhat variable across studies and may be indicative of subgroups with variable response. Across studies where positive effects were seen, the actual treatment impact on skills may vary based on child and intervention factors. A key limitation is that approaches across studies vary substantially, and it is hard to determine the effects of these unique studies on specific groups of children.
Adaptive behavior Low for positive effect | RCT: 1 good, 1 fair (76) Prospective cohort: 7 fair, 2 poor (616) nRCT: 1 good, 4 fair (170) Retrospective cohort: 1 fair, 2 poor (182) | Medium | Inconsistent | Direct | Imprecise | Undetected | Most studies found that children in both treatment and control groups improved on adaptive skills. However, children in high intensity early intensive intervention improved more than children receiving other types of services. Not all group differences were maintained over long-term followup. There was variability within domains, such that some studies found improvement whereas others found declines in domain standard scores. For example, one study found a decrease in the motor skills domain for both treatment and control groups. An important limitation is that adaptive behavior was always measured by parent report (Vineland) rather than objective observation. Some studies suggested that adaptive behavior outcomes were dependent on baseline child characteristics, such as cognitive and verbal abilities and ASD severity.
Symptom severity Low for positive effect | RCT: 1 good, 1 fair (332) nRCT: 1 good, 1 fair (74) Prospective cohort: 4 fair, 2 poor (470) Retrospective cohort: 1 fair (142) | Medium | Inconsistent | Direct | Imprecise | Undetected | Mixed impact on symptom severity; SOE is low for a positive effect on symptom severity because 2 good studies showed positive effects but multiple lower quality studies did not. More studies are needed to confirm results. Most control groups were also receiving treatment and also showed improvement, making it difficult to tease apart the effect of early intensive intervention specifically vs. any kind of intervention. Evidence emerged that baseline symptom severity predicts response to treatment, although the direction is inconsistent.
Language/communication Moderate for positive effect | RCT: 1 good, 2 fair (360) nRCT: 1 good, 3 fair (143) Prospective cohort: 6 fair, 2 poor (616) | Medium | Consistent | Direct | Precise | Undetected | Most studies found a positive effect of treatment on language/communication skills, although the specific domain of improvement (e.g., receptive vs. expressive language) varied across study. Some initial between-group differences disappeared at long-term followup. Some evidence that baseline child factors such as gender and cognitive skills influenced effects of treatment on language outcomes. A limitation is that some studies measured language using direct testing, whereas others only used the Vineland Communication domain.
Social skills/social behavior Low for positive effect | RCT: 1 good, 1 fair (332) nRCT: 1 fair (34) Prospective cohort: 4 fair, 1 poor (406) Retrospective cohort: 1 fair (142) | Medium | Inconsistent | Direct | Imprecise | Undetected | Many studies found that treatment groups improved more than controls on measures of social skills, although a significant minority did not find any treatment effect. A significant limitation is that social skills were assessed almost exclusively using parent-reported standard scores on the Vineland.

ABA-applied behavior analysis; nRCT-nonrandomized controlled trial; RCT-randomized controlled trial

The strength of the evidence for parent training interventions is low for a positive effect of their impact on early language and communication skills and low for a positive impact on ASD symptom severity. The strength of the evidence is low for no effect on early cognition. Data are not yet sufficient in this literature base to understand impact on adaptive behavior skills. Available studies indicate variable responses, with modest improvement for some children in some approaches, but limited improvement in other parent training paradigms (Table 13).

Table 13 Strength of the evidence for early intervention-parent training studies

Outcome Strength of Evidence Grade | Study Design Quality and Number of Studies (N Total Participants) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Finding
IQ/cognitive Low for no effect | RCT: 3 fair (148) Prospective cohort: 1 good, 1 fair, 1 poor (142) | Medium | Inconsistent | Direct | Imprecise | Undetected | Most studies of parent-implemented ABA demonstrated no improvements in IQ relative to community-based interventions; in some studies worse outcomes were reported relative to center-based treatment. SOE is low for no effect due to heterogeneity in interventions and outcomes measured.
Symptom severity Low for positive effect | RCT: 3 good, 3 fair (361) Prospective cohort: 1 good, 1 fair, 2 poor, (203) | Low | Inconsistent | Direct | Imprecise | Undetected | Many studies found that treatment groups had improved ASD symptoms relative to controls. However, a significant limitation is that the measure of symptom severity varied across studies and was inconsistently defined, from videotaped behavioral observations to standardized parent report forms like the GARS to interactive assessments like the ADOS. This makes it difficult to meaningfully compare outcomes across studies.
Language/communication Low for positive effect | RCT: 4 good, 6 fair, 1 poor (664) nRCT: 1 poor (22) Prospective cohort: 2 good, 2 poor (176) | Low | Inconsistent | Direct | Precise | Undetected | Parent training was associated with improvements in language (low SOE for improvements), but interventions and comparators were different across studies, as were the outcome measures. More studies are needed to confirm results. Of studies that assessed language outcomes, two possible child variables influencing treatment efficacy emerged. The first is that younger child age was associated with greater language improvements at followup in two studies. Second, another study found that higher baseline levels of object interest in children were associated with attenuated growth in communication skills.

ADOS = Autism Diagnostic Observation Schedule; GARS = Gilliam Autism Rating Scale; nRCT = nonrandomized controlled trial; RCT = randomized controlled trial

#### Social Skills Studies

In addition to the nine comparative studies assessing social skills included in the 2011 review (eight RCTs of fair114-116 and poor117-121 quality and one poor quality retrospective cohort122),we located 13 studies addressing interventions targeting social skills for this review update. The overall quality of studies improved compared with the previous review with two good quality and 10 fair quality studies, and one of poor quality. Social skills interventions varied widely in terms of scope and intensity. A few studies replicated interventions using the manualized Skillstreaming model; one reported longer term results from research on the Children's Friendship Training model. Other studies incorporated peer-mediated and/or group-based approaches, and still others described interventions that focused on emotion identification and theory of mind training. The studies also varied in intensity, with most interventions consisting of 1–2 hour sessions/week lasting for approximately 4–5 weeks. However, some of the group-based approaches lasted for 15–16 weeks.

Most studies reported some short term gains in either parent-rated social skills or directly tested emotion recognition. However, our confidence (strength of evidence) in that effect is low. While we now have higher quality investigations of social skills interventions demonstrating positive effects, our ability to determine the effectiveness of these interventions continues to be limited by the diversity of the intervention protocols and measurement tools (i.e., no consistent outcome measures used across studies). Maintenance and generalization of these skills beyond the intervention setting is also inconsistent, with parent- and clinician-raters noting variability in performance across settings. No studies reported harms of intervention.

##### Strength of the Evidence

The strength of evidence for the effect of social skills interventions on social outcomes for school aged children with ASD is low. All studies demonstrated benefit on at least one outcome measure, but a lack of consistency in the interventions or measures used makes it difficult to assess consistency or precision. Most studies relied on parent or teacher report of intermediate outcomes, although some studies have attempted to included ratings and outcomes (peer/teacher nominations, social networks/maps) with potential for assessment of generalization (Table 14).

Table 14 Strength of the evidence for social skills studies

Outcome Strength of Evidence Grade | Study Design Quality and Number of Studies (N Total Participants) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Finding
Social skills/social behavior Low for positive effect | RCT: 2 good, 11 fair, 6 poor (730) nRCT: 2 fair (45) Retrospective cohort: 1 poor (117) | Medium | Inconsistent | Direct | Precise | Undetected | School-aged children diagnosed without concomitant cognitive and language deficits demonstrated short-term gains in social skills and emotion recognition. Maintenance and generalization of these skills beyond the treatment context had variable results. Social skills interventions varied widely in terms of scope and intensity.

nRCT = nonrandomized controlled trial; RCT = randomized controlled trial

#### Play-/Interaction-Focused Studies

Studies incorporating play or interaction-based elements have targeted either joint attention skills, early imitation skills, or focused play in younger children. No studies reported harms of intervention. Since our previous review, which included seven (reported in nine publications) comparative studies (two RCTs of fair139-141 and five of poor142-147 quality) addressing play- or interaction-based approaches, there have been substantially more studies of well-controlled joint attention interventions across a range of intervention settings (e.g., clinician, parent, teacher delivered). Regarding joint attention skills, interventions were delivered by parents, teachers, and interventionists over typically short durations (≤ 12 weeks). Three studies reported longer-term followup (≥12 months).140, 141, 148-150, 156As with other studies reported in this review, participants in play/interaction studies often received other early intervention services in addition to the targeted intervention, making disentangling effects of the intervention difficult. This growing evidence base supports positive effects for young and preschool children with ASD, particularly when targeting joint attention skills themselves as well as related social communication and language skills. Although joint attention intervention studies certainly demonstrated changes within this theoretically important domain, data are more limited about their ability to improve broad developmental skills (such as cognition, adaptive behavior, and ASD symptom severity) beyond communication and language gains over time.

Specific and focal training regarding imitation skills utilizing naturalistic approaches to promote imitation (i.e., Reciprocal Imitation Training) has shown positive results in improving not only imitation skills, but potentially other social communication skills such as joint attention as well.152, 153 Additionally, parent training in a variety of play-based interventions is associated with positive outcomes for encouraging early social communication skills (e.g., joint attention, engagement, play interactions), play skills, and early language skills.154, 156, 160

##### Strength of the Evidence

A growing evidence base reports on effects in children receiving early joint attention-related intervention in combination with other interventions show substantial improvements in joint attention and language skills over time. Within this growing literature, our confidence (strength of evidence) in this effect is moderate, based on the need for additional research that identifies which groups of children benefit the most from this approach and how this intervention relates to other ongoing concurrent offered interventions. Results from a variety of play-based interventions also suggest that young children often display short-term improvements in early play, imitation, language, and social interaction skills. However, our confidence in these estimates is low, and substantial evidence that these short-term improvements are linked to broader indices of change over time is lacking (Table 15).

Table 15 Strength of the evidence for play/interaction-based studies

Outcome Strength of Evidence Grade | Study Design Quality and Number of Studies (N Total Participants) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Finding
Joint attention Moderate for positive effect | RCT: 3 good, 6 fair (305) | Low | Consistent | Indirect | Precise | Undetected | Selected joint attention skills consistently increased in treatment arms, but duration of effects is unclear. The SOE is lowered to moderate as children in most studies were also receiving other early intervention and disentangling effects is difficult.
Play skills Low for positive effect | RCT: 3 good, 3 fair, 3 poor (265) Prospective cohort: 1 poor (12) | Medium | Consistent | Direct | Precise | Undetected | Play skills increased in treatment arms but duration of effects is unclear. Imitation skills improved in treatment arms in 4 small, short-term studies and in the treatment and control arms in 1 study.
Language/Communication Low for positive effect | RCT: 4 fair (165) | Medium | Consistent | Direct | Imprecise | Undetected | Expressive but not receptive language skills generally increased in the treatment arms in 2 studies; expressive and receptive language improved in 1 study; prompted but not spontaneous communication improved in 1 study.
Social skills Low for positive effect | RCT: 1 good, 3 fair (173) | Medium | Consistent | Indirect | Precise | Undetected | Joint engagement or positive affect improved in treatment arms in 3 studies.

RCT = randomized controlled trial

#### Interventions Targeting Conditions Commonly Associated With ASD

Most studies in this category evaluated the impact of cognitive behavioral therapy (CBT) on co-occurring conditions, such as problem behaviors or anxiety, rather than core ASD symptoms or broader developmental domains (e.g., cognition, language, adaptive behavior). We identified nine comparative studies addressing interventions targeting conditions/behaviors commonly associated with ASD in the 2011 review. These studies included four RCTs163-167 and one nonrandomized trial168 of fair quality and three RCTs169-171 and one prospective cohort172 of poor quality.

Seven of nine RCTs identified for the current and 2011 review measured anxiety symptoms as a primary outcome.164-166, 169, 171, 173, 174, 176-178, 182 Six of these studies reported significantly greater improvements in anxiety symptoms in the intervention group compared with controls. Two of these studies found positive effects of CBT on the core ASD symptom of socialization. The one RCT that did not find a significant benefit of CBT compared it to social recreational therapy rather than treatment as usual or a waitlisted control group. Although the CBT group had improved anxiety symptoms, this improvement did not significantly differ from participants receiving social recreational therapy.174

The studies examining the effects of CBT on anxiety had largely consistent methodologies and primarily conducted weekly 60–90 minute treatment sessions over a period of 4 months. All studies provided followup data reflecting treatment effects that lasted beyond the period of direct intervention. Two common factors limit the applicability of the results, however. Due to the nature of CBT, which is often language-intensive and requires a certain level of reasoning skills to make abstract connections between concepts, most studies included only children with IQs much greater than 70. This likely restricts the applicability of findings to the general population of people with ASD. Additionally, the CBT interventions described in these studies included both children and parents, suggesting that both components may be necessary for effective treatment.

These studies are encouraging regarding the use of CBT to treat anxiety in children with ASD. They also suggest that CBT could potentially be associated with improvements in socialization and communication, although these results were less robust and it is unclear if these improvements were beyond improvements related to the impact of ameliorated anxiety itself.

Additional data in the current review relate to parent training to address challenging behavior. Specifically, one fair quality study combined a parent training approach with risperidone. This combination significantly reduced irritability, stereotypic behaviors, and hyperactivity, and improved socialization and communication skills. However, these effects were not maintained at one-year post-treatment. The followup sample size also decreased from 124 to 87.^167, 179-181, 184^

##### Strength of the Evidence

A growing evidence base suggests that school-aged children with average to above average intelligence and comorbid anxiety symptoms receiving manualized CBT therapy show substantial improvements in anxiety compared with wait-list controls. Within this population our confidence (strength of evidence) in this effect is high. Our strength of evidence of the impact of this intervention for this same group on ASD symptoms (social communication functioning and repetitive behaviors) is low with future research likely affecting our understanding of the unique impact of this intervention (Table 16). With regard to parent training paradigms to address challenging behavior, results of parent training studies and parent training in addition to treatment with risperidone have demonstrated short-term improvements in terms of the frequency and intensity of challenging behavior. With few higher quality studies in this area, we considered the strength of the evidence to be insufficient (Table 17).

Table 16 Strength of the evidence for studies addressing interventions targeting commonly associated conditions

Intervention/Outcome Strength of Evidence Grade | Study Design Quality and Number of Studies (N Total Participants) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Finding
CBT
Anxiety High for positive effect in older children with IQ ≥70 | RCT: 6 good, 1 fair, 2 poor (413) nRCT: 1 fair (31) | Low | Consistent | Direct | Precise | Undetected | Most studies included older children with average IQs. Improvement in anxiety symptoms for greater for CBT vs. control group in 5/6 studies. The study that did not show improvement compared CBT to an active treatment instead of a waitlisted control. Improvement was maintained at followup. Some evidence emerged that CBT may be more effective for some types of anxiety disorders than others.
Symptom severity Low for positive effect | RCT: 2 good (81) | Low | Consistent | Direct | Imprecise | Undetected | Significant improvement in clinician- and parent-rated measures of anxiety severity in both studies with improvement maintained at followup. SOE is low based on only 2 small studies.

CBT = cognitive behavioral therapy; nRCT = nonrandomized controlled trial; RCT = randomized controlled trial

Table 17 Behavioral interventions/outcomes with insufficient strength of evidence

Intervention | Anger | Adaptive Behavior | Challenging Behavior | Executive Function | Feeding Behaviors | Language/Communication | Outcomes for children age 0–2 yrs at risk for ASD diagnosis | Repetitive Behavior | Symptom Severity | Sleep Parameters | Social Skills
ABA-based early intensive behavioral and developmental interventions | | | | | | | ✓
CBT (commonly associated conditions) | ✓ | ✓ | | ✓
CBT(other behavioral interventions) | | | | | | | | | | ✓
Neurofeedback (other behavioral interventions) | | | | ✓ | | ✓ | | | | | ✓
Parent training (commonly associated conditions) | | ✓ | ✓ | | | | | | ✓
Parent training targeting feeding behaviors (other behavioral interventions) | | | | | ✓
Play/interaction-based interventions | | | ✓
Sleep education pamphlet (other behavioral interventions) | | | | | | | | | | ✓
Social skills | | | | | | ✓ | | ✓ | ✓

ABA = applied behavior analysis; ASD = autism spectrum disorder; CBT = cognitive behavioral therapy; yrs = years

Note: Checked outcome/intervention pairs=insufficient strength of evidence.

#### Other Behavioral Studies

In addition to two poor quality RCTs targeting neurofeedback186, 187 and described fully in the 2011 review, we identified we identified six new studies (seven publications) evaluating interventions targeting sleep behaviors,188-190 feeding difficulties in ASD,191 and neurofeedback. 192-194 The neurofeedback RCTs reported some improvements on parent-rated measures of communication and tests of executive function. The clinical implications of changes in brainwave patterns reported in the studies are unclear, and the studies were small and short-term.192, 194, 195 Three studies reported on sleep-focused interventions, with little positive effect of a sleep education pamphlet for parents in one,188 improvements in sleep quality in treatment arms (melatonin alone, melatonin+CBT) in another,189 and some improvements in time to fall asleep in one short terms RCT of sleep education programs for parents.190 One poor quality study of parent education to mitigate feeding problems reported no significant effects.191

##### Strength of the Evidence

With few studies of additional behavioral interventions, all of limited quality, evidence was insufficient to evaluate the relative effect of other behavioral interventions on targeted outcomes including ASD symptom severity, problem behaviors, and sleep concerns as well as outcomes for Key Question 7 (interventions for very young children at risk for ASD diagnosis). Table 17 outlines interventions/outcomes for which we considered the strength of the evidence to be insufficient.

### KQ2 Modifiers of Treatment Effects

Understanding the degree to which child characteristics (i.e., specific ASD-related difficulties and skills), treatment factors (e.g., type, duration, intensity), and systems (e.g., family, community) influence response to intervention could help professionals target treatments to the appropriate children and circumstances. However, as was reported in the 2011 review, few studies were clearly designed or powered to allow for analysis of heterogeneous effects. Primarily studies in this section are those in which potential correlates were identified that may be moderators, but have not been studied as such. These potential moderators should be assessed in properly designed and powered studies for this purpose.

Among early intensive ABA-based interventions potential modifiers or moderators, younger age at intake was generally associated with better outcomes for children; however, this finding was not present in some other studies.123, 167, 179-181 Higher cognitive skills and higher adaptive behavior scores at baseline also were often associated with better outcomes across behavioral interventions, but the associations were not consistent. In general, children with lower symptom severity or less severe diagnoses improved more than participants with greater impairments. However, many studies (e.g., those of social skills, CBT) often restricted the range of participants' impairment at baseline, limiting understanding of intervention impact on broader populations. Studies assessing parental responsiveness to children's communication typically reported better outcomes in children whose parents were more aligned with the child's communication versus those who attempted to re-direct or were less synchronized with it.

Regarding intervention-related factors, duration of treatment had an inconsistent effect, with some studies reporting improved outcomes with greater intervention time and others reporting no association. Studies have often not been adequately designed or controlled in order to help identify true moderators of treatment. More often post-hoc evaluation of differences across groups has been examined.

### KQ3 Treatment Phase Changes That Predict Outcomes

The reviewed literature offers little information about what specific early changes from baseline measurements of child characteristics might predict long-term outcome and response. Some evidence suggests that the best predictor of long-term outcome is not baseline characteristics at all, but rather the magnitude of change seen over the course of treatment (e.g., cognitive shifts in first years of early intensive treatments).73, 85

### KQ4 Treatment Effects That Predict Long-Term Outcomes

Few studies assess end-of-treatment effects that may predict outcomes. Several early intensive behavioral and developmental intervention paradigms change measures over the course of very lengthy treatments, but such outcomes usually have not been assessed beyond treatment windows. One family of studies140, 141, 148, 149 attempted to follow young children receiving early joint attention intervention until they were school aged, but this study failed to include adequate followup of control conditions. It also involved children were receiving many hours of uncontrolled interventions during the course of study.

### KQ5 Generalization of Treatment Effects

Few studies included in this review explicitly measured generalization of treatment effects to different conditions or locations. Often, early intensive behavioral and developmental interventions attempted to index change by examining standardized cognitive skills, adaptive behavior, and language measures in addition to metrics of ASD symptoms. Presumably, changes measured on these instruments document important skills with potential impact in other areas. However, some caution is warranted: In some instances, the interventions themselves may actually target component skills of these assessments, particularly in the case of cognitive and language assessments.

The majority of the social skills and behavioral intervention studies targeting associated conditions attempted to index outcomes based on parent, self, teacher, and peer report of targeted symptoms (e.g., anxiety, externalizing behaviors, social skills, peer relations) at home, at school, and in the community. While such ratings outside of the clinical setting may be suggestive of generalization in that they improve outcomes in the daily context/life of the child, in most cases, these outcomes are parent reported and not confirmed with direct observation. Behavioral intervention studies rarely measured outcomes beyond the intervention period, and therefore we cannot assume that effects are maintained over time.

### KQ6 Treatment Components That Drive Outcomes

We again did not identify any studies meeting our inclusion criteria that addressed this question.

### KQ7 Treatment Approaches for Children Under Age 2 at Risk for Diagnosis of ASD

In the studies addressing interventions for younger children,93, 97, 99 children who received behavioral interventions seemed to improve regardless of intervention type. None of the fair or good quality studies compared treatment groups to a no treatment control group. One poor quality study found positive differential effects of treatment,97 but the level of intervention intensity varied significantly between groups, making it difficult to differentiate the effects of treatment intensity vs. type. Potential modifiers of treatment efficacy include baseline levels of object interest.93 Most outcome measures of adaptive functioning were based upon parent report, and the effect of parental perception of treatment efficacy on perception (and report) of child functioning was generally not explored.

## Findings in Relation to What Is Already Known

Other reviewers have also synthesized the impact of early intensive behavioral interventions. We rated three meta-analyses evaluating early intervention for children with ASD that were published since the 2011 review as good quality.45, 52, 197 We also summarize two overview meta-analyses (not quality rated) addressing early intervention.198, 199 Findings of other reviews assessing effects of early intensive ABA-based intervention largely align with our evaluation of the strength of evidence. Specifically, other reviews have demonstrated consistent impact on cognitive and language skills with fairly large effect sizes across these somewhat overlapping syntheses. These same investigations have also noted much less consistent changes in adaptive behavior skills. Further, these reviews have highlighted similar methodological concerns as noted in our current review: relatively small sample sizes, inclusion of nonrandomized studies, lack of standardized control groups, errors in interpretation of studies, and wide variations in the early intervention approaches assessed.

One Cochrane review compared early intervention to treatment as usual and included RCTs or controlled trials with participants under 6 years of age at intake.45 The review included 5 studies (one RCT) with a total of 203 participants (mean age range: 30.2 to 42.5 months). The investigators rated all studies as having high risk of bias (low overall quality) and found positive effects for early intervention on all outcomes. Mean difference effect sizes were 0.76 for IQ (95% CI=0.40 to 1.11, p<.0001), 0.69 for adaptive behavior (95% CI=0.38 to 1.01, p<.0001) and ranged from 0.42 to 0.74 for measures of communication, socialization, and daily living skills (p values .0005 to .03). Tests of heterogeneity and small sample sizes precluded assessment of moderators of effects.

One meta-analysis of ABA-based interventions included studies with at least five children with ASD receiving at least 10 hours of intervention per week for 45 weeks. Twenty-two studies met criteria and assessed outcomes including IQ, receptive and expressive language, and adaptive behavior (Vineland composite and subscales). Studies included 323 patients (mean age 22.6 to 66.3 months, 55.6 to 97% male). Study quality was low to moderate, ranging from 1.2 to 3.6 on a five point scale (mean 2.5). Thirteen studies had control groups (six with random/quasi-random assignment). Positive effects were associated with ABA-based intervention in 18 studies assessing the outcome with a pooled effect size of 1.19 (95% CI: 0.91 to 1.47, p<.001). Similarly, ABA was associated with positive effects on language (general, expressive, and receptive, effect sizes from 1.07 to 1.48) and adaptive behavior (communication, socialization, motor skills, daily living skills domains as well as composite scores; pooled effect sizes ranging from 0.61 to 1.45). The effect size for the composite score was 1.09 (95% CI: 0.70 to 1.47, p<.001), and total treatment duration was associated with better adaptive behavior and language outcomes but not IQ. Results restricted to studies with control groups were consistent with results for all studies across outcomes. Across outcomes, effect sizes were generally slightly better for clinic-based approaches vs. parent-delivered. Similarly, the investigators note the potential for publication bias for the outcomes of IQ and language and the adaptive behavior domains of communication and socialization.52

Another meta-analysis of ABA-based early intervention included 11 small comparative studies (one RCT) with 344 children with ASD (mean age 33.56 to 65.68 months, 65.7% male).197 The mean quality of studies as rated on the Downs and Black scale was 24.65 out of 32 (range 23–27). The early intervention group had greater gains on all variables assessed compared with control group participants, with full scale IQ improving by 11.98 points over improvements in the control group. Receptive and expressive language scores for the early intervention group compared with control each improved by more than 13 points, while improvements on Vineland subscales scores ranged from 4.96 to 10.44 points. Total effect sizes for daily living skills improvements were moderate (0.68) and were large for improvements in IQ, language, and adaptive behavior (effect sizes ranging from 0.91 to 2.00). The authors noted some evidence of publication bias. Table 18 outlines key characteristics of these early intervention meta-analyses.

Table 18 Summary of meta-analyses of early intervention approaches

Author, Year | Study Type As Defined In Review (N) Total Participants/Group (N) | Mean Participant Age (Months) | Treatment Intensity, Hours/Week Treatment Duration, Mean Months (Range) | Effect Sizes (95% CI)
Reichow 2012^45^ | RCT: 1 Controlled trial: 4 Early intervention: 116 Comparison: 87 | 30.2–42.5 | >24 hours/week 26.3 months (14–36) | IQ: 0.76 (0.40 to 1.11) Expressive language: 0.50 (0.05 to 0.95) Receptive language: 0.57 (0.20 to 0.94) Vineland adaptive behavior: 0.69 (0.38 to 1.01) Vineland communication: 0.74 (0.30 to 1.18) Vineland socialization: 0.42 (0.11 to 0.73) Vineland daily living: 0.55 (0.24 to 0.87)
Virues-Ortega 2010^52^ | Total studies (type not defined): 22 Early intervention: 323 Comparison: 180 | 22.6–66.3 | 12–45 hours/week 4–34 months | IQ: 1.19 (0.91 to 1.47) Expressive language: 1.47 (0.85 to 2.08) Receptive language: 1.48 (0.96 to 1.97) General language: 1.07 (0.34 to 1.79) Vineland adaptive behavior: 1.09 (0.70 to 1.47) Vineland socialization: 0.95 (0.53 to 1.37) Vineland communication: 1.45 (1.02 to 1.88) Vineland daily living: 0.62 (0.30 to 0.93) Vineland motor skills: 0.71 (0.19 to 1.22)
Peters-Scheffer 2011^197^ | RCT: 1 Pre-test/post-test with control: 10 Early intervention: 168 Comparison: 144 | 33.65–65.68 | 12.5–38.6 hours/week 10–24+ months | IQ: 2.00 Non-verbal IQ: 0.98 Expressive language: 1.10 Receptive language: 2.91 Vineland adaptive behavior: 0.91 Vineland communication: 1.32 Vineland daily living: 0.68 Vineland socialization: 1.49

CI = confidence interval; IQ = intelligence quotient; n = number; RCT = randomized controlled trial

A sequential or cumulative meta-analysis compiled data from 15 studies rated as adequate or high quality in five previously published meta-analyses (Eldevik 2009, Makrygianni 2010, Peters-Scheffer 2011, Reichow 2009, Spreckley 2009).198 The 15 studies included 263 children with ASD. The sequential meta-analysis found a medium treatment benefit for early intervention vs. comparison interventions for the outcomes of intellectual functioning, language, and adaptive behavior. The magnitude of treatment benefit varied for outcomes when assessing pre- to post-differences in the early intervention group. For IQ, the standardized mean difference effect size for group differences was 0.61 (p<.001) and the pre to post differences in the early intervention group was 0.71 (p<.01). Between group effect sizes for adaptive behavior and language were also considered medium (0.60 and 0.72, respectively, p values <.001). Pre to post effect sizes for adaptive behavior (0.35, p=ns) and language (0.69, p<.05) did not reach sufficiency and could not be considered as providing evidence of medium pre to post treatment benefit. The authors note that meta-analyses for pre to post differences in adaptive behavior and language were underpowered.

An overview of four of the same meta-analyses noted above plus one additional (Virues-Ortega 2010) described methodologic limitations across the meta-analyses.199 Limitations included small sample sizes in included studies, inclusion of nonrandomized studies, lack of standardized control groups, errors in interpretation of studies, and variations in the early intervention approaches assessed. Four of the five meta-analyses concluded that early intervention was an effective approach. For IQ, the weighted mean effect size across meta-analyses ranged from 0.38 to 1.19 and from 0.30 to 1.09 for adaptive behavior. Despite the need for additional research, particularly in understanding effective treatment component and child characteristics associated with optimal outcomes, the authors conclude that early intervention can produce significant effects on IQ and adaptive behavior for many young children with ASD.

## Applicability

ASD is characterized by significant heterogeneity within the population. Variation in both core and associated symptoms across and within children over time is substantial. Individual therapies are developed and tested to ameliorate specific symptoms or groups of symptoms, often in a fairly circumscribed subset of children. Ideally, research on therapies for ASD should target specific children most likely to benefit from a particular focus; thus details on the population, intervention, comparator, outcomes, and setting (PICOS) for each intervention category are provided in Appendix G. These data may help to support translation of our findings and assessment of the applicability of each for differing circumstances and children.

Furthermore, although interim, clinically based improvement is important, longer term functional outcomes are the goal for ASD interventions. In terms of followup for assessing durability of effects, most studies report on outcomes collected immediately post-treatment or within 3 months of treatment (roughly 75% of studies in the behavioral literature), although more studies than in our previous report attempt to assess impact over the course of much longer timespans. Additional research is needed on the degree to which changes observed during treatment translate to functional outcomes over time should treatment be discontinued. Importantly, ASD is often construed as a lifespan disorder and there has not yet been research assessing the long-term functional impact of treatment in childhood on lifespan development and functioning.

Studies of early intensive behavioral and developmental interventions were conducted primarily in preschool age and early school age children (i.e., typically children initially ages 1.5–7 years) and as such questions remain about how these approaches apply to and benefit younger children diagnosed with or at-risk for ASD. The cognitive, language, and adaptive behavior profiles of participants included in these studies were generally in line with those seen in the community (i.e., typically marked by substantial impairment/delay, but with some children with more intact early cognitive/language profiles). However, the availability and accessibility of the approaches studied are substantially limited in many community based settings. That is, the studies were often either conducted in highly controlled environments (e.g., university supported intervention trials) or the methodology was not well-described (i.e., non-manualized approaches). Thus, the generalizability (i.e., applicability) of these methods to common practice should be assessed carefully. Even available manualized interventions require high degrees of specialization and training that will likely continue to make translation into common practice difficult.

Studies of parent training interventions and play-based interventions for preschool children, often emphasizing principles of ABA aligned with current practice and the target populations that are typically referred for these services. Training programs often included components to improve social communication skills such as joint attention, play-based interactions, and pragmatic language approaches; interventions were conducted for approximately 1–4 hours/week with parents asked to introduce learned techniques within natural settings. Several programs offered manualized versions of training that can be adopted in other settings with appropriate training. Again the availability of providers capable of translating these programs may be limited in some community settings.

Most studies of social skills interventions targeted elementary school aged children (between 6 and 13 years old) with few studies targeting preschool age children, although such interventions may be important in this younger age group. Most studies also excluded children with IQ falling outside of the average range and certainly those below 70. Therefore, evidence on social skills interventions is likely applicable to older, higher functioning children only. Similarly, CBT for commonly associated conditions was targeted toward older children with gross average cognitive abilities and comorbid anxiety disorders. The effectiveness of both of these types of interventions in other groups of children with ASD is currently unknown.

## Implications for Clinical and Policy Decisionmaking

This review may be useful to groups producing guidelines for practice, including professional organizations, state-level Medicaid medical directors, Federal entities and insurers. It provides an overview of available behavioral interventions and benefits observed to date that clinicians may find useful in making individual clinical recommendations to their patients and patient families. The larger body of literature of higher quality than in the previous review provides continued support for earlier conclusions that behavioral interventions can be beneficial for some children. Guidelines developed on the basis of the prior review warrant updating based on the level of new information and the degree to which strength of evidence shifted in the current review.

The evidence in favor of the efficacy of several types of behavioral interventions has increased, but there remains clinical uncertainty about whether and how individual children will benefit from specific programs of intervention, which creates a challenge for implementation. Further, some interventions are limited in terms of the subset of the ASD population they are designed to treat (e.g., CBT and social skills interventions for older children with relatively intact cognitive abilities). In addition, pragmatic issues such as the availability of skilled providers and interventions themselves, resources to pay for interventions, as well as family considerations and preferences, may influence and guide treatment decisions.

Although there is increasing evidence that children with ASD who receive appropriate behavioral intervention can have substantial improvements in functioning, we have limited knowledge of the actual numbers of families able to access such services on a community level. Young children with ASD (below 36 months) are often eligible for services through Early Intervention (Part C) programs, with all states and eligible territories currently providing such programs. These systems presumably allow children to receive services based on risk prior to diagnosis as well as post-diagnosis, but services may range in intensity and focus. Children who are over age 3 often have access to additional services through their school district, but the nature of appropriate services provided within these systems varies. A majority of U.S. states (estimated at over 35^200^) have enacted ASD insurance reform legislation that provides for specific access to evidence-based intervention services through private insurance. Again the availability and accessibility of resources for referral varies dramatically across communities

## Limitations of the Review Process

We limited this update to comparative studies of behavioral interventions and included only those with at least 10 individuals. Thus, we did not include data from pre-post studies or those with a very small number of children. These would include single-subject design studies that are helpful for understanding focused questions of short-term efficacy in individual children, and that may be useful for explicating mechanisms of action. These studies are less able to contribute to the body of evidence that we sought on population level and generalizable effects. Users of this review may want to take those studies into account as context when applying our findings.

We limited our review to English language studies, not finding evidence that we were missing relevant research in other languages. We did not do a quantitative synthesis given the substantial heterogeneity of the literature base, but we recognize that this lack of synthesis may mitigate the ease with which the findings are applied. Therefore we have tried to provide substantial description that will help end users apply the findings.

## Limitations of the Evidence Base

Despite improvements, the existing literature still has significant methodological concerns that in many ways continue to limit the strength of these conclusions. Evidence for the impact of intensive ABA-based interventions on cognitive, language, adaptive skills, and ASD symptoms also highlights important limitations of current treatment modalities. First, even children who demonstrate clinically significant improvements in these areas often continue to display substantial impairment in these same and other areas. Second, not all children receiving intensive ABA-based intervention showed robust improvements in these domains. Thus, although this updated review makes it clearer that early intensive ABA-based intervention improves early impairment related to ASD, it is still challenging to describe the ultimate effect of these improvements in terms of long-term functional and adaptive outcomes on an individual level. Further, although children receiving early intensive developmental and behavioral intervention commonly display substantial improvements, the magnitude of these effects varies across studies and may indicate subgroups showing variable responses to particular interventions. Intervention response is likely moderated by both treatment and child factors. Despite multiple studies of early intensive treatments, intervention approaches still vary substantially, which makes it difficult to tease apart what these unique treatment and child factors may be. Similarly, data on provider type and qualifications are variably reported, and the impact of provider characteristics on treatment outcomes is unclear. Further, researchers have not commonly utilized explicit methodologies or analyses to help elucidate moderation of treatment response across studies. As such, the current evidence is insufficient to adequately identify and target children most likely to benefit from specific interventions.

When examining treatment outcomes, many early intervention studies found that children in all groups improved on cognitive, adaptive, and ASD symptom measures regardless of intervention type, although the degree of improvement was often greater in the treatment group. Results were often confounded by nonrandom assignment of participants, including assignment based on child characteristics (such as having the skills necessary to participate in intervention setting) or parental preference. The latter is especially problematic when outcomes are measured by parent report, given some evidence that parental stress influenced parent perceptions of child outcomes. Additionally, in most studies, both enrolled and control/waitlisted children were receiving concomitant interventions, the magnitude of which was inconsistently documented and controlled for in analyses.

A remaining significant challenge to interpreting the early intensive intervention literature relates to how interventions are described and implemented (see Appendix F for further characterization of the early intervention studies in this review). Although researchers are increasingly attempting to manualize approaches as well as operationalize and measure treatment fidelity, most of the body of literature categorized in this report as “early intensive behavioral and developmental intervention” remains an eclectic grouping. This category of intervention presently groups different treatment approaches (i.e., developmental, intensive behavioral, center based, and combinations), intensity (12 hours over 3 months vs. 30 hours over 1 week), and duration (weeks to years); varied inclusion and baseline assessment criteria; children of varying ages (intake age ranging from 18 months to 7 years); and many different outcome measurements over different periods of time (weeks to years). Manualizing intensive interventions to be delivered over the months and years for a very heterogeneous patient population is intrinsically challenging. However, recent progress toward this end has shown that children will often respond differentially to early intensive approaches. Unfortunately, we do not yet understand how these specific intervention approaches differentially affect specific subgroups of children with ASD.

Few studies directly compared the effects of well-controlled treatment approaches, instead comparing interventions to non-specific “treatment as usual.” Additionally, little data on the practical effectiveness or feasibility of these treatments beyond research studies exist, and questions remain about whether reported findings would generalize on a larger scale within communities. Furthermore, the studies conducted have used small samples, drastically different treatment approaches and duration, and different outcome measurements. Similarly, no studies in this category reported harms of intervention in terms of child, family, or system impact.

Although there was a fairly robust evidence base on CBT, the literature lacks head to head comparisons of treatment or controlled comparisons of combinations of treatments despite the fact that most children are undergoing multiple concurrent treatments. Although well designed, the sample sizes are quite modest. Additionally, the CBT approaches were modified for children with ASD and oftentimes manualized by the authors themselves, which highlights the need for replication by outside investigators. Lastly, the only study that did not show significant benefit in the CBT intervention group compared with it to an active treatment control as opposed to a waitlist or treatment as usual control.174 This suggests that more studies including active control groups are needed to examine if CBT reduces anxiety more than other treatment modalities.

## Research Gaps and Needs

Several behavioral treatment approaches report positive outcomes in children with ASD, increasingly using rigorous designs. Despite this recent and improved rigor, treatments remain understudied. In addition, few studies have attempted to systematically replicate findings of previous work.

Given the heterogeneity of the expression of ASD within and across children, a critical area for further research is understanding which children are likely to benefit from particular interventions. To date, studies have failed adequately to characterize interventions or children receiving intervention such that we can better understand which children are most likely to experience positive outcomes and why. Further, our understanding of early indicators of treatment response is extremely limited, such that evidence-based changes in treatment planning based on an observed response or lack thereof are not possible. This is important to parents, providers, and families as they often want to know not only when a treatment is working, but when limited benefit of treatments may suggest pursuing other treatment options. Similarly, research is lacking on the durability of treatment gains and approaches needed to maintain gains.

Again the accumulated evidence base suggests that although children receiving early intensive intervention demonstrate substantial gains in several areas of functioning (e.g., cognitive ability, language, adaptive, ASD symptoms) on a group level, not all children receiving early intensive intervention demonstrate robust gains. Currently, the evidence suggests some children will show dramatic improvement, others will display robust improvement in some areas with continued areas of vulnerability in others, and other children will show more moderated response to treatment overall. It is also unclear how similar groups of children will perform at differing levels of intensity of interventions or different treatment approaches and methods.

Child characteristics like baseline cognitive, language, adaptive skill, and ASD symptoms may correlate with treatment outcome; however, such correlational data provides limited information in making predictions of what treatments will work best for individual children. It is possible that meta-analyses of individual patient data may provide additional information for identifying subgroups of responders.

Further, intensive, comprehensive intervention strategies are by their very nature often multi-component. Data on whether specific functional components of the interventions drive effectiveness are currently unavailable as are data on mediators of change. Finally, the intervention research often fails to describe whether treatment effect is modified by family, culture, available resources, and stress. Early intensive behavioral and developmental approaches therefore warrant further research to understand individual response and benefit in the short and long-term across heterogeneous populations. Similarly, evaluations of intervention delivered by community providers are important for comparing effects of such approaches with those of interventions delivered in controlled research environments. Such evaluations are complicated by the complexity of community systems and methodologic challenges including creating similar treatment and control groups and maintaining fidelity; however, they will be increasingly valuable for scaling intervention for ASD. Also important in addressing this gap is improving our currently limited understanding of the effects of provider training and provider characteristics on outcomes of treatment.

A primary methodological concern relates to outcome measurement. Intervention research in the field of ASD has often relied on various and differing ways of marking change, which has limited our ability to understand change within and across individual studies. 201 The manner in which outcomes are operationalized in many studies is often problematic as well. Quite often outcome is operationalized and studied in terms of change on standardized measures of ability referencing normative populations (i.e., IQ measurement, adaptive behavior scores), which may not necessarily be an appropriate or adequate method for measuring or predicting early treatment response, changes in quality of life, or long-term functional outcomes. Such measurement, while providing data that can be compared with that in typically developing populations, may unfortunately miss important information about changes that are relevant within the ASD population. More simply, it is unclear that measures of cognitive ability, language, and ASD diagnostic symptoms are actually ideal or adequately sensitive methods for measuring frequency, intensity, and impairment in children with ASD. Research on appropriate methods to capture meaningful change will be critical to advance our understanding of behavioral interventions. In addition, while studies have improved in reporting a priori determined primary and secondary outcome measures, continued improvements in reporting will benefit the field.

In some aspects of the literature treatments with some replicated studies have emerged. Specifically both social skills interventions and cognitive behavioral interventions for anxiety have demonstrated short-term benefit for some children with ASD. However, this literature focuses almost entirely on older children with ASD and intact cognitive skills. Understanding the impact or lack thereof of such interventions for others with ASD is important. Further, this work has often relied on parent or teacher reports of functioning to gauge change. Such reporting may be useful as a preliminary index or potentially as a component of a broader measurement strategy attempting to index change, but reliance these ratings provides only an intermediate and often biased assessment of change, with potentially very limited value to understanding how interventions translate in to meaningful long-term functional outcomes.

Because the treatment process for ASD is typically intensive and often requires highly specific and well-trained individuals to deliver to fidelity, questions of feasibility and accessibility are pertinent but largely understudied. Explicit evaluation of treatments of highest impact in community settings as well as studies explicitly evaluating settings and providers would benefit our ability to understand impact and implementation.

Finally, this literature lacks comparisons of interventions and combinations of interventions (e.g., medical interventions, with behavioral interventions, with educational interventions, with allied health interventions), despite the fact that most children are undergoing multiple concurrent treatments. The current review also focused solely on behavioral interventions. Systematic reviews of studies of interventions in other categories (e.g., medical, allied health) would provide useful information for clinicians, researchers, policy makers, and families.

## Conclusions

Since our previous review in 2011, we have seen a significant increase in the quality of studies investigating behavioral interventions. Of the 45 comparative studies of behavioral interventions (29 RCTs) in the 2011 review, we considered only two as good quality. Among the new studies of behavioral interventions described in this current review, 19 studies are good quality, and 48 of the 65 included studies are RCTs.

These improvements allow us to make some stronger conclusions about certain elements of the behavioral intervention literature. Considerable and consistent evidence suggests that early behavioral and developmental intervention based on the principles of ABA delivered in intensive (≥15 hours per week) and comprehensive (i.e., addressing numerous areas of functioning) form can significantly affect the development of some children with ASD. The current review includes RCTs of the UCLA/Lovaas-focused approach, a developmentally focused ESDM approach, a school delivered training (LEAP), as well as prospective comparisons of eclectic variants of ABA approaches. Across approaches, children receiving early intensive behavioral and developmental interventions have demonstrated improvements in cognitive, language, adaptive, and ASD impairments compared with children receiving low-intensity interventions and eclectic non-ABA based intervention approaches.

Since our previous review, there have also been substantially more studies of well-controlled low intensity interventions including parent training aimed at social communication skills. This growing evidence base suggests that such interventions may have positive results in very young children's social communication and language use. However, although parent training programs certainly modified parenting behaviors during interactions, data are more limited about their ability to improve broad developmental skills (such as cognition, adaptive behavior, and ASD symptom severity) beyond short-term language gains for some children.

A growing number of studies of improved quality have demonstrated benefit of social skills interventions on at least one outcome measure, but a lack of consistency in the interventions studied and outcome measures utilized makes it difficult to understand the consistency or precision of impact across intervention modes. Further, social skills interventions have also been limited to a restricted range of children to date.

A growing evidence base suggests that children receiving targeted play-based interventions (e.g., joint attention, imitation, play-based interventions) demonstrate improvements in early social communication skills. Children receiving targeted joint attention packages in combination with other interventions show substantial improvements in joint attention and language skills over time. Young children in play-based interventions may display short-term improvements in early play, imitation, joint attention, and interaction skills. However, there is not substantial evidence that these short-term improvements are linked to broader indices of change over time.

CBT for associated conditions such as anxiety has the largest number of high quality studies in the current review. A strong evidence base suggests that school-aged children with average to above average intelligence and comorbid anxiety symptoms receiving manualized CBT therapy show substantial improvements in anxiety compared with wait-list controls. Importantly, CBT therapy is often targeted, delimited, and has numerous manualized approaches available for study. Further, CBT intervention for anxiety has been studied within a restricted population to date (e.g., average to above average cognitive skills with comorbid anxiety).

In sum, a growing evidence base suggests that behavioral interventions are associated with positive outcomes for children with ASD. Despite improvements in the quality of the included literature, a need remains for studies of interventions across settings and continued improvements in methodologic rigor. Substantial scientific advances are needed to enhance our understanding of which interventions are most effective for specific children with ASD and to isolate elements or components of interventions most associated with effects.